# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Darren A. DeWalt, M.D., M.P.H.^a^
  a Indicates Technical Expert Panel member also provided Peer Review commentary and feedback.
  University of North Carolina at Chapel Hill School of Medicine
  Chapel Hill, NC
- Paul A. Heidenreich, M.D., M.S., FACC^a^
  Cardiovascular Research Institute
  Stanford University School of Medicine
  Palo Alto, CA
- Mariell Jessup, M.D.^a^
  Professor of Medicine,
  University of Pennsylvania
  School of Medicine
  Medical Director,
  Penn Heart and Vascular Center
  Philadelphia, PA
- Devan Kansagara, M.D., M.C.R., FACP^a^
  Portland VA Evidence-based Synthesis Program
  Oregon Health and Science University
  Portland, OR
- Gowri Raman, M.D., M.S.^a^
  Assistant Professor of Medicine,
  Tufts University School of Medicine
  Scientific Staff, Center for Clinical
  Evidence Synthesis
  Tufts Medical Center
  Boston, MA
- Juliana Tiongson, M.P.H.
  Center for Medicare & Medicaid Innovation
  Baltimore, MD
- Timothy J. Wilt, M.D., M.P.H.^a^
  Minneapolis VA Center for Chronic
  Disease Outcomes Research
  University of Minnesota School of Medicine
  Minneapolis, MN
- Clyde W. Yancy, M.D., M.Sc., FACC, FAHA, M.A.C.P.
  Division of Cardiology
  Northwestern University
  Chicago, IL