# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Kenneth S. Fink, M.D., M.G.A., M.P.H.
  Med-Quest Division, Hawaii State Medicaid
  Kapolei, HI
- Jalal Ghali, M.D.
  Division of Cardiology
  Mercer University School of Medicine
  Macon, GA
- Mariell Jessup, M.D.
  Professor of Medicine, University of Pennsylvania School of Medicine
  Medical Director,
  Penn Heart and Vascular Center
  Philadelphia, PA
- Carol Levine, M.A.
  Families and Health Care Project
  United Hospital Fund
  New York, NY
- JoAnn Lindenfeld, M.D.
  Cardiac Transplant Program
  University of Colorado
  Aurora, CO
- Timothy J. Wilt, M.D., M.P.H.
  Minneapolis VA Center for Chronic
  Disease Outcomes Research
  University of Minnesota School of Medicine
  Minneapolis, MN
- Clyde W. Yancy, M.D., M.Sc., FACC, FAHA, M.A.C.P.
  Division of Cardiology
  Northwestern University
  Chicago, IL
- Judy Zerzan, M.D., M.P.H.
  Colorado Department of Health
  Care Policy and Financing
  Denver, CO