# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Christine Chang, M.D., M.P.H., and our Associate Editor, Donna Dryden, Ph.D. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our research process. The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina at Chapel Hill. We express our gratitude to the following individuals for their contributions to this project: Carol Woodell, B.S.P.H., our Project Manager; Meera Viswanathan, Ph.D., Director of the RTI-UNC EPC; Timothy S. Carey, M.D., M.P.H., Director of the Cecil G. Sheps Center for Health Services Research at UNC; Rachael Posey, M.S.L.S., our EPC Librarian; Ellen Shanahan, M.A., our research associate; Claire Baker and Cassandra Rowe, B.A., our Research Assistants; Laura Small, editor; and Loraine Monroe, our EPC Publications Specialist.