# Discussion

For this report, we conducted a systematic review to evaluate the evidence for transitional care interventions for adults hospitalized for heart failure (HF). Below, we summarize the main findings and strength of evidence (SOE) for the bodies of evidence pertaining to those findings. We then discuss the findings in relation to what is already known, applicability of the findings, implications for decisionmaking, limitations of the review process or evidence base, research gaps, and conclusions.

We classified interventions into six main categories based primarily on the mode and environment of delivery, as defined in the introduction: home-visiting programs; structured telephone support (STS); telemonitoring; various types of outpatient clinic interventions, including multidisciplinary (MDS) HF clinic programs, nurse-led clinic interventions and primary care clinic interventions; primarily educational programs; and “other” efforts that did not fit neatly into any of these categories. Across all these types of interventions, we had 47 trials reported in 53 articles.

Because of the health policy and clinical issues involved in recent policies intended to help reduce excessive hospital readmissions, particularly for Medicare patients, our primary outcomes were focused on 30-day readmission and mortality rates. We also included trials that reported at least one of the following outcomes at any time point before 6 months following an index hospitalization for HF: all-cause readmission, HF-readmission, composite all-cause readmission or death, and mortality. We also examined outcomes relating to health-related quality of life and caregiver or self-care burden.

Our main findings and conclusions are based on randomized controlled trials comparing transitional care interventions with usual care that we rated as low or medium risk of bias. We identified only two trials comparing one type of intervention with another (i.e., making head-to-head comparisons); we rated both as high risk of bias. Thus, direct evidence was insufficient to draw conclusions about comparative effectiveness.

When we graded evidence as insufficient, the evidence was unavailable, did not permit estimation of an effect, or did not permit us to draw a conclusion with at least a low level of confidence. An insufficient grade does not indicate that an intervention has been proven to lack efficacy.

## Key Findings and Strength of Evidence

### Reducing Readmissions and Mortality

Table 20 summarizes our key findings by intervention category, main outcomes (readmission rates, mortality, or the composite of all-cause readmission or death), and timing of measurement of outcomes (30 days; 3-6 months). It documents our results when data met the following three criteria: (1) sufficient evidence to grade the SOE and to draw a conclusion that evidence either supports benefit [+] or does not [-]; (2) insufficient (I) evidence to make a determination (e.g. only one trial reporting an outcome of interest); or (3) no included trials that reported an outcome (NR).

Table 20 Summary of key findings and strength of evidence, by intervention category and outcome

Intervention Category | All-Cause Readmissions | | HF-specific Readmissions | | Composite Endpoint | | Mortality
Intervention Category | 30 days | 3 to 6 months | 30 days | 3 to 6 months | 30 days | 3 to 6 months | 30 days | 3 to 6 months
Home-visiting programs | + low^a^ | + high | NR | + Mod | + low | + mod | I | + mod
Structured telephone support | I | - mod | I | + High | NR | - low | NR | + mod
Telemonitoring | I | - mod | NR | - Mod | NR | NR | NR | - low
MDS-HF clinic Interventions | NR | + high | NR | I | NR | - mod | NR | + mod
Nurse-led clinic interventions | NR | - low | NR | I | NR | I | NR | - low
Primary care clinic interventions | NR | I | NR | NR | NR | NR | NR | I
Primarily educational interventions | NR | I | NR | I | NR | - low | NR | - low
Other interventions | I | NR | NR | NR | NR | NR | I | NR

Note: low, mod, high and I represent strength of evidence (SOE) grades: mod = moderate, I= insufficient. + indicates that we found benefit (i.e., statistically significant reduction in readmission rate, mortality, or composite compared with usual care), - indicates that we found no benefit (i.e., no statistically significant reduction in the outcome). HR = heart failure; MDS = multidisciplinary; NR = No trials in this category reported on an eligible outcome at this time point.

a Two home-visiting programs reported all-cause readmission at 30 days. The intervention studied by Naylor and colleagues was of higher intensity and showed efficacy. The lower-intensity intervention studied by Jaarsma et al. did not show efficacy at 30 days (low SOE). The “+” here refers to high-intensity home-visiting programs.

Table 21 then presents more detailed results, including relative risks (RRs) and 95% confidence intervals (CIs). We also present numbers needed to treat (NNTs, when applicable) for comparisons that included at least one trial reporting an outcome of interest.

Table 21 Summary of key findings and strength of evidence for transitional care interventions: Readmission, composite endpoint, and mortality

Intervention Category | Outcome | Outcome Timing | N Trials; N Subjects | Relative Risk (95% CI)^a^ | Numbers Needed To Treat | Strength of Evidence
Home-visiting programs | All-cause readmission | 30 days | 2; 418 | High intensity (1 study): 0.34 (0.19 to 0.62) Lower intensity (1 study): 0.89 (0.43 to 1.85) | 6 for high intensity NA^b^ for lower intensity programs | Low^c^ for benefit
Home-visiting programs | All-cause readmission | 3 to 6 months | 9;1,563 | 0.75 (0.68 to 0.86) | 9 | High for benefit
Home-visiting programs | HF-specific readmission | 3 to 6 months | 1; 282 | 0.51 (0.31 to 0.82) | 7 | Moderate^d^ for benefit
Home-visiting programs | Composite endpoint^e^ | 30 days | 1; 239 | Hazard ratio (SE): 0.869 (0.033) vs. 0.737 (0.041) | NA | Low^f^ for benefit
Home-visiting programs | Composite endpoint | 3 to 6 months | 4; 824 | Hazard ratio (SE): 0.071 (0.045) vs. 0.558 (0.047) 0.78 (0.65 to 0.94) | 10 | Moderate^g^ for benefit
Home-visiting programs | Mortality | 30 days | 1; 239 | 1.03 (0.15 to 7.16) | NA | Insufficient
Home-visiting programs | Mortality | 3 to 6 months | 8;1693 | 0.77 (0.60 to 0.997) | 33 | Moderate for benefit
Structured telephone support | All-cause readmission | 30 days | 1;134 | 0.80 (0.38 to 1.65) | NA | Insufficient
Structured telephone support | All-cause readmission | 3 to 6 months | 8; 2166 | 0.92 (0.77 to 1.10) | NA | Moderate for no benefit
Structured telephone support | HF-specific readmission | 30 days | 1;134 | 0.63 (0.24 to 1.87) | NA | Insufficient
Structured telephone support | HF-specific readmission | 3 to 6 months | 7; 1790 | 0.74 (0.61 to 0.90) | 14 | High for benefit
Structured telephone support | Composite endpoint | 3 to 6 months | 3; 977 | 0.81 (0.58 to 1.12) | NA | Low for no benefit
Structured telephone support | Mortality | 3 to 6 months | 7; 2011 | 0.74 (0.56 to 0.97) | 27 | Moderate for benefit
Telemonitoring | All-cause readmission | 30 days | 1; 168 | 1.02 (0.64 to 1.63) | NA | Insufficient
Telemonitoring | All-cause readmission | 3 to 6 months | 3;434 | 1.11 (0.87 to 1.42) | NA | Moderate^h^ for no benefit
Telemonitoring | HF-specific readmission | 3 to 6 months | 1; 182 | 1.70 (0.82 to 3.51) | NA | Moderate^h^ for no benefit
Telemonitoring | Mortality | 3 to 6 months | 3;564 | 0.93 (0.25 to 3.48) | NA | Low for no benefit
MDS-HF clinic | All-cause readmission | 3 to 6 months | 2; 336 | 0.70 (0.55 to 0.89) | 8 | High for benefit
MDS-HF clinic | HF- specific readmission | 3 to 6 months | 1;106 | 0.70 (0.29 to 1.70) | NA | Insufficient
MDS-HF clinic | Composite endpoint | 3 to 6 months | 2; 306 | 0.80 (0.43 to 1.01) | NA | Moderate for no benefit
MDS-HF clinic | Mortality | 3 to 6 months | 3; 536 | 0.56 (0.34 to 0.92) | 18 | Moderate for benefit
Nurse-led clinic | All-cause readmission | 3 to 6 months | 2; 264 | 0.88 (0.57 to 1.37) | NA | Low for no benefit
Nurse-led clinic | HF-specific readmission | 3 to 6 months | 1;158 | 0.95 (0.68 to 1.32) | NA | Insufficient
Nurse-led clinic | Composite endpoint | 3 to 6 months | 1;106 | 0.66 (0.43 to 1.01) | NA | Insufficient
Nurse-led clinic | Mortality | 3 to 6 months | 2; 264 | 0.59 (0.12 to 3.03) | | Low for no benefit
Primary-care clinic Intervention | All-cause readmission | 3 to 6 months | 1; 443 | 1.27 (1.05 to 1.54) | NA | Insufficient
Primary-care clinic Intervention | Mortality | 3 to 6 months | 1; 443 | 1.52 (0.88 to 2.63) | | Insufficient
Primarily educational interventions | All-cause readmission | 3 to 6 months | 1;200 | 1.14 (0.84 to 1.54) | NA | Insufficient
Primarily educational interventions | HF-specific readmission | 3 to 6 months | 1; 223 | 0.53 (0.31 to 0.90) | NA | Insufficient
Primarily educational interventions | Composite endpoint | 3 to 6 months | 2; 423 | 0.92 (0.58 to 1.47) | NA | Low
Primarily educational interventions | Mortality | 3 to 6 months | 2; 423 | 1.20 (0.52 to 2.76) | NA | Low
Other (cognitive training) | All-cause readmission | 30 days | 1;125 | 1.15 (0.71 to 2.28) | NA | Insufficient
Other (cognitive training) | Mortality | 30 days | 1;125 | 0.07 (0.00 to 1.12) | NA | Insufficient

a Entries in this column are relative risks (RRs) from our meta-analyses or RR calculations unless otherwise specified. RRs less than 1 favor interventions over controls.

b NA entry for numbers needed to treat (NNT) indicates that the relative risk (95% CI) was not statistically significant, so we did not calculate an NNT. NA for hazard ratios indicates that we could not calculate an NNT with the data provided by the investigators.

c Two home-visiting programs reported all-cause readmission at 30 days; the higher intensity showed efficacy but the lower intensity intervention did not.

d Although only one trial reported total number of people readmitted per group, we considered the findings consistent because one other trial reported on the number of readmissions per group and found a similar effect.53

e The composite endpoint comprises all-cause readmission or death.

f Although only a single trial reported the number of people alive and not readmitted at 30 days and 3 months, we considered the consistency of similar programs reducing 3-month readmissions rates when grading the SOE for this intervention at 30 days.

g Although evidence was limited to one trial, consistency for the 30-day outcome was unknown, and evidence was imprecise, we upgraded the SOE because this intervention category has demonstrated no effect on mortality at 3 or 6 months—thus, increasing our confidence in the results of this single trial.

h Although only a single trial reported on the number of people readmitted, we considered this finding consistent given that four other telemonitoring trials reported the total number of readmissions per group (rather than the number of people readmitted); all-cause readmissions did not differ between people receiving telemonitoring and those receiving usual care at 30 days, 3 months, or 6 months.

CI = confidence level; MDS-HF, multidisciplinary heart failure clinic; N = number; NA = not applicable; NNT = number needed to treat; RR = relative risk; SE = standard error; SOE = strength of evidence; STS = structured telephone support.

#### Outcomes at 30 Days

We found very little evidence on whether interventions reduce 30-day readmission rates. Most trials reported rates over 3 to 6 months.

The high-intensity home-visiting trial showed efficacy in reducing 30-day all-cause readmission and the composite endpoint (both low SOE).55 Despite having only this trial, this intervention and other trials in the home-visiting category also consistently reduced readmission rates measured over 3 to 6 months. Because of those robust findings, we considered high-intensity home-visiting programs to be efficacious in reducing all-cause readmission and the composite outcome at 30 days.

Evidence was insufficient to determine whether several other intervention categories reduced 30-day all-cause readmission rates, because we found no trials or only a single trial (none of which showed efficacy).

#### Outcomes at 3 to 6 Months

For outcomes measured over 3 to 6 months, we found evidence of efficacy (high SOE) for improving at least one of our primary outcomes for home-visiting programs, STS, and MDS-HF clinic interventions. Specifically, home-visiting programs reduced all-cause readmission rates (high SOE), HF-specific readmission rates (moderate SOE) and the composite outcome (moderate SOE). STS interventions reduced HF-specific readmission rates (high SOE) and mortality (moderate SOE) but not all-cause readmission (moderate SOE for no benefit). MDS-HF clinic interventions reduced all-cause readmission rates (high SOE) and mortality (moderate SOE) but not HF-specific readmission (moderate SOE for no benefit).

For these outcomes, we calculated NNTs when data on a given intervention or outcome permitted (Table 21). For all-cause readmission, NNTs were 9 for home-visiting programs and 8 for MDS-HF clinic interventions. For mortality, NNTs were 33 for home-visiting programs, 27 for STS, and 18 for MDS-HF clinic interventions. An NNT of 9 means, for example, that 9 hospitalized patients with HF would need to receive a home-visiting program following discharge (rather than usual care) to prevent one additional person from being readmitted over 3 to 6 months.

Our meta-analyses did not find telemonitoring, nurse-led clinic interventions, or primarily educational interventions to be efficacious for any primary outcomes. Evidence was insufficient to determine the efficacy of the following interventions in reducing readmission rates or mortality: primary care clinic interventions, peer support interventions, and cognitive training interventions (for people with HF and coexisting mild cognitive impairment).

Some experts have cautioned that inappropriate focus on reduction of readmission rates could negatively affect patient care and perhaps mortality. However, we found no evidence of such an effect. Specifically, no interventions reduced readmission rates but increased mortality.

### Utilization Outcomes

Few trials reported on emergency room (ER) visits or hospital days of subsequent readmissions. When these outcomes were reported, few trials reported measures in the same manner or at similar time points. No trial reported the number of acute outpatient (non-ER) visits.

For ER visits, evidence was generally insufficient to determine whether transitional care interventions increased or decreased such visits. The one exception was STS; these interventions had no effect on the rate of ER visits over 6 months (low SOE for no benefit).

Two intervention types significantly reduced the total number of all-cause hospital days (of subsequent readmissions) over 3 to 6 months: STS (moderate SOE) and home-visiting programs (low SOE). Otherwise, evidence was generally insufficient to determine whether other transitional care interventions increased or decreased hospital days of subsequent readmissions.

### Quality of Life

Few trials measured quality of life or functional status using the same measures at similar time points. HF-specific quality of life, as measured by the Minnesota Living With Health Failure Questionnaire (MLWHFQ), showed more improvement for home-visiting programs than usual care over 3 months (low SOE). Intervention and control groups did not differ on quality of life (MLWHFQ) for patients receiving STS over 3 and 6 months (low SOE for no benefit). Evidence was insufficient to determine whether other transitional care interventions improved quality of life.

### Components of Effective Interventions

No single-component intervention reduced all-cause readmissions. The two categories of interventions that reduced all-cause readmissions and the composite outcome—namely, home-visiting programs and MDS-HF clinic interventions—are multicomponent, complex interventions. As a whole, these two categories of interventions shared the following components:

- HF education emphasizing self-care, recognition of symptoms, and weight monitoring.
- HF pharmacotherapy emphasizing patient education about medications, promotion of adherence to medication regimens, and promotion of evidence-based HF pharmacotherapy before discharge or during followup (or both).
- Face-to-face contact following discharge via home-visiting personnel, MDS-HF clinic personnel (or both). In most cases, this contact occurred within 7 days of discharge.
- Streamlined mechanisms to contact care delivery personal (clinic personnel or visiting nurses or pharmacists) outside of scheduled visits (e.g., patient hotline).
- Mechanisms for postdischarge medication adjustment. In most cases, home-visiting personnel either directly recommended medication adjustment or assisted with coordination of care (e.g., with primary care provider or cardiologist) to facilitate timely medication adjustment based on a patient's needs (rather than advising patients to call for help themselves).

Three categories of interventions reduced mortality rates: home-visiting programs, STS, and MDS-HF clinic interventions. All are multicomponent interventions that include frequent patient contact following an inpatient admission for HF. As a whole, these categories shared the following components:

- HF education emphasizing self-care, recognition of symptoms, and weight monitoring.
- A series of scheduled, structured visits (via telephone or clinic followup) that focused on reinforcing education and monitoring for HF symptoms.
- A mechanism to contact providers easily outside of scheduled visits (e.g., patient hotline).

Separating out individual components from the overall categories (or “bundles”) of interventions that showed efficacy was not possible.

### Intensity, Delivery Personnel, and Mode of Delivery

In general, intervention categories that included higher-intensity interventions (i.e., home-visiting programs, STS, MDS-HF clinic interventions) reduced all-cause readmission or mortality. By contrast, categories with lower-intensity interventions (i.e., primarily educational interventions, nurse-led HF clinic interventions) did not.

Within most categories, evidence was generally insufficient to draw definitive conclusions about whether higher- or lower-intensity interventions are more or less efficacious in lowering all-cause readmission rates or mortality. The one exception was home-visiting programs; higher-intensity programs reduced all-cause readmission at 30 days but lower-intensity programs did not. Subgroup analyses yielded no significant difference in efficacy based on intensity for STS programs. Subgroup analyses were not possible for other categories of interventions because of either lack of variation or too few trials reporting outcomes at similar time points.

The two categories of interventions that reduced all-cause readmission and mortality (home-visiting programs and MDS-HF clinic interventions) were more likely to include teams of providers delivering the intervention (e.g., home visits that a nurse and pharmacist conducted together) than interventions that did not show efficacy (e.g., telemonitoring, primarily educational interventions). STS interventions, which were done primarily by nurses and pharmacists, did lower mortality but not all-cause readmission. Within categories, evidence was insufficient to draw definitive conclusions about whether specific delivery personnel are more or less efficacious for reducing all-cause readmission or mortality.

Across intervention categories, interventions were done mainly face-to-face or via technology (telephone, telemonitoring, video visits). The two categories of interventions delivered primarily face-to-face reduced all-cause readmission—i.e., home-visiting and MDS-HF clinic interventions. For these two categories, method of delivery did not vary within each category. STS reduced mortality; some of these interventions did include a face-to-face component (e.g., educational intervention before discharge). In general, interventions primarily delivered remotely (i.e., telemonitoring, STS) did not reduce all-cause readmission rates. Only STS interventions varied in the method of communication; our subgroup analyses for reduction in all-cause readmission and mortality found no statistically significant difference by method of communication at any time point.

## Findings in Relation to What Is Already Known

The 2009 update of the American Heart Association/American College of Cardiology (AHA/ACC) guidelines addressed postdischarge HF interventions. 25 25 These guidelines focused on the importance of discharge planning, emphasizing written discharge instructions or educational material targeted to the patient or caregiver at discharge. The AHA/ACC guidelines also recommended that “postdischarge systems of care, if available, should be used to facilitate the transition to effective outpatient care for patients hospitalized with heart failure.”

The 2010 Heart Failure Society of America guidelines are similar; their guidance emphasizes specific components of discharge planning. The Society does not give any specific guidance on optimal transitional care interventions aimed at preventing early readmissions for patients with HF.

As our results make clear, certain intervention categories (or combinations of components) have better efficacy than others for HF patients. For instance, categories of interventions that were delivered face-to-face (i.e., home-visiting and MDS-HF clinic interventions) reduced all-cause readmission rates, whereas other intervention categories did not. In general, intervention categories that included higher-intensity interventions, with education on self-care delivered over repeated visits through the transition from hospital to home (i.e., home-visiting programs, STS, MDS-HF clinic interventions) reduced all-cause readmission or mortality, whereas categories with lower-intensity intervention (i.e., primarily educational interventions, nurse-led HF clinic interventions) did not. Guidelines that focus on written discharge instructions and early outpatient followup may not provide sufficient guidance on optimal strategies to reduce readmission and mortality.

The interventions in the included trials were heterogeneous and could probably be categorized using a variety of approaches. We classified them in a manner that we believe is both descriptive and informative; other approaches to categorization could lead to different conclusions about the efficacy (or lack of it) for primary or other outcomes.

Other reviews have highlighted the difficulty in classifying trials into distinct categories. For example, we classified one trial by Rainville et al.71 as STS as did a 2011 Cochrane review,32 but a 2012 Cochrane review classified the same trial as case management, grouping it with trials that assessed home-visiting programs.31

The results of our current review are, in general, consistent with those in previous reviews of this literature. Unlike earlier reviews, however, we focused on shorter-term outcomes (6 months or less), with enrollment during or shortly following an admission for HF). By contrast, some other reviews included outcomes up to 12 months (or longer) following an index hospitalization or did not exclude studies in which patients had had no recent index hospitalization.31,102,103 For these reasons, our conclusions may differ. For example, a recent meta-analysis and network meta-analysis found no statistically significant effect of remote monitoring interventions on mortality or all-cause readmission up to 1 year, but it combined STS and telemonitoring interventions.102 At outcome timings over 3 to 6 months, we found that STS was associated with a mortality benefit while telemonitoring interventions were not.

Other reviews have used different categorization strategies (as mentioned above); a 2009 Cochrane review found that “case-management” interventions (home-visiting programs and telephone support) were associated with a reduction in all-cause mortality at 12 months (but not at 6 months) and a reduction in readmissions related to HF at 6 months and 1 year.31 One recent review of interventions to reduce 30-day readmissions excluded interventions that were disease specific; that is, those authors did not include interventions tailored to HF patients or other chronic diseases.33 They found that most studies tested multicomponent discharge bundles. Common components of effective interventions included postdischarge telephone calls and patient-centered discharge instructions—e.g., facilitation of patient engagement in the transition of care individually tailored for the patient's health and social circumstances.33

## Applicability

Most trials included adults with moderate to severe HF. The mean age of subjects was generally in the 70s; very few trials enrolled patients who were, on average, either younger or older. We did not find evidence to confirm or refute whether treatments are more or less efficacious for many other subgroups, including groups defined by sex, racial or ethnic minorities, people with higher severity of HF, type of HF (e.g., diastolic vs. systolic), and patients with certain coexisting conditions. Included trials commonly excluded patients who had end-stage renal disease or severe or unstable cardiovascular disease (e.g., recent myocardial infarction [MI]). Usual-care groups of included trials experienced rates of readmission that are comparable to those found in a Medicare population: the median all-cause readmission rate at 30 days among patients receiving usual care was 19 percent (intraquartile range [IQR] 14 percent to 22 percent); over 3 to 6 months, the rate was 43 percent (IQR 35 percent to 41 percent).

Although all included studies enrolled patients with HF, some degree of population heterogeneity across intervention categories may impact our findings (e.g., variation in HF severity, etiology, or number of comorbidities). The majority of trials included patients with moderate to severe HF based on the NYHA classification; most trials did not report whether patients had a preserved versus reduced ejection fraction. The interventions included are applicable only to patients who are discharged to home. Whether interventions would benefit patients who are discharged to another institution (e.g., assisted living facility) remains unclear.

Few trials used a risk stratification scheme to determine inclusion eligibility. Two trials assessing a home-visiting program (by the same author) specified inclusion or exclusion criteria based on risk of readmission. One of these trials included only patients with one “risk factor” for early readmission57 (prior history of HF, four or more hospitalizations for any reason in the preceding 5 years, or HF precipitated by either an acute MI or uncontrolled hypertension); the other trial excluded patients deemed “low risk.”58 Neither trial used a validated tool to assess risk.

Two other trials, one assessing a MDS-HF clinic intervention and one assessing an STS intervention, included patients deemed “high risk for readmission” but did not define how they assessed risk.65,87 One trial testing a primarily educational intervention excluded patients who were judged to have a “noncardiac illness likely to increase 6-month mortality or hospitalization risk.”95 How such inclusion criteria based on risk affect the applicability of results remains unclear. A systematic review of validated readmission risk prediction models found that most perform poorly.104

Approximately one-half of the home-visiting programs were conducted in the United States; the others were conducted in Australia, the United Kingdom, and various European countries. One of three trials assessing MDS-HF clinic was conducted in the United States; the other two were conducted in Taiwan and Canada; despite the potential differences in settings and health care systems, results were similar across the three trials.

Across most included trials, the majority of patients were prescribed an angiotensin-converting enzyme inhibitor (ACEI) or angiotensin receptor blocker (ARB) (when information was reported). By contrast, the percentages of patients across trials who were prescribed beta-blockers at discharge varied widely across trials.

Whether “usual care” in trials published during the early 1990s is comparable to current practice is questionable. In general, trials did not report details of usual care; for example, they typically did not specify whether followup was scheduled soon after discharge or whether patients were receiving additional services such as home health care.

The trials we examined were conducted in a mix of inpatient settings. These settings included academic medical centers, Department of Veterans Affairs hospital settings, and community hospitals. Our findings are, therefore, generally applicable to many hospital settings in the United States.

## Implications for Clinical and Policy Decisionmaking

Few trials reported readmission rates within 30 days following a HF hospitalization. Data based on Medicare claims suggest that 35.2 percent of 30-day readmissions are for HF; the remainder are for diverse indications (e.g., renal disorders, pneumonia, arrhythmias, and septicemia or shock).5 Whether certain interventions that reduce readmissions at 3 and 6 months would also be effective in reducing earlier readmissions remains uncertain.

We found moderately strong evidence for interventions that provided relatively frequent in-person monitoring following discharge—specifically, home-visiting programs and MDS-HF clinic interventions. The one trial that showed efficacy for reducing 30-day all-cause readmission provided frequent, in-home monitoring that began within 24 hours of discharge.55 These findings suggest, in general, the utility of such face-to-face monitoring, whether delivered at home or at an appropriate clinic.

Interventions that did not show efficacy for all-cause readmissions tended to focus more narrowly on HF self-care alone; this finding was true, for instance, for both STS and primarily educational interventions. For reducing all-cause readmissions, focusing on HF self-care training or weight monitoring alone does not appear sufficient.

Current clinical practice in the care of adults with HF after hospitalization varies greatly across the country, by hospital settings, and for other factors. A recent telephone survey of 100 U.S. hospitals found wide variation in education, discharge processes, care transition, and quality-improvement methods for patients hospitalized with HF.17 As mentioned in the introduction to this review, readmission rates vary by both geographic location and insurance coverage.6

Nevertheless, our findings provide some guidance to quality-improvement efforts that try to reduce readmissions for people with HF. Specifically, systems or providers aiming to implement programs to improve transitional care for patients with HF may wish to start with the multicomponent interventions that had meaningful effects on both all-cause readmission and mortality. In this regard, we found moderately strong evidence for home-visiting programs and MDS-HF clinic interventions for reducing all-cause readmission rates; in designing quality-improvement efforts, administrators may do well to give these approaches the greatest consideration.

We did not prespecify a magnitude of effect (i.e., a specific reduction in relative risk) that clinicians or policymakers should consider a meaningful change in readmission rates. The percentage of readmissions that are preventable may differ across settings and patient populations that are not comparable with patients enrolled in the trials we examined. However, as mentioned above, the 30-day readmission rates of included trials are similar to those seen in Medicare populations.

Finally, we did not find direct evidence on whether certain types of interventions increase or decrease caregiver or self-care burden, but these issues are meaningful for patients and their families. Thus, clinicians should consider the inherent demands or expectations that some transitional care interventions may place on caregivers and patients (e.g., burden of transportation). In recommending or selecting a transitional care intervention, administrators may want to weigh the goal of minimizing additional burden that a candidate intervention might pose.

## Limitations of the Comparative Effectiveness Review Process

The interventions in the included trials were quite diverse; they probably could be categorized using a variety of classification schemes or conceptual models. As explained previously, we classified them in a manner that we believe is both descriptive and informative; it accords with how numerous experts conceptualize these highly varied programs. Nonetheless, we acknowledge that other approaches to categorization could lead analysts to different conclusions.

Other reviews have highlighted the difficulty in classifying transitional care programs, particularly those aiming at specific kinds of outcomes or targeting specific types of patients, into distinct (mutually exclusive) categories. Using different categorizations for systematic reviews can place similar (or exactly the same) trials into different groupings (as noted above concerning the Rainville et al. trial). The effects of such classification decisions on findings, especially those relying on pooled data from eligible trials, are unpredictable.

We used the term “transitional care” broadly; generally, we were guided by Coleman's definition as “a set of actions designed to ensure the coordination and continuity of health care as patients transfer between different locations or different levels of care within the same location” (p. 30).24 The included interventions are diverse in terms of whether they aimed to coordinate care at the provider level or focused more on strategies to transfer care back to the patient (e.g., through self-care training for managing HF). We did not include or exclude trials based on any specific set of components; for that reason, included trials assessed diverse interventions. We chose to cast a broad net to be able to examine a comprehensive set of strategies to reduce readmission rates, lower mortality, improve quality of life, or influence other patient-centered outcomes, on the grounds that doing so would be useful to stakeholders in different settings (hospitals, outpatient clinics, or others).

Our inclusion and exclusion criteria specified that included trials had to enroll patients during (or soon after) a hospitalization for HF and also had to measure a readmission rate over 6 months or less. We did not include readmission rates or mortality rates measured beyond 6 months; interventions that we did not find efficacious may or may not be beneficial in long-term disease management in patients with HF. Finally, publication bias and selective reporting are potential limitations. Although we searched for unpublished trials and unpublished outcomes, we did not find direct evidence of either of these biases. Many of the included trials were published before trial registries (e.g., clinicaltrials.gov) became available; had we been able to consult such registries, we would have had greater certainty about the potential for either type of bias.

## Limitations of the Evidence Base

The evidence base was inadequate to draw conclusions for some of our questions or subquestions of interest. In particular, as described above, direct evidence was insufficient to permit us to draw any conclusions on comparative effectiveness of transitional care interventions.

In addition, evidence was quite limited for some outcomes (particularly readmissions within 30 days, utilization outcomes, and quality of life). Evidence was similarly insufficient to draw any definitive conclusions about whether any transitional care interventions are more or less efficacious in reducing readmissions or mortality based on patient subgroups defined by age, sex, race, ethnicity, socioeconomic status, disease severity, or coexisting conditions. We found just two eligible trials reporting information on different subgroups.

We identified little evidence on the potential harms of transitional care interventions, such as whether they increase caregiver burden or increase the rate of ER visits. None of the included trials measured caregiver burden, which is relevant given that health care interventions affect not only the health of the individual receiving the intervention but also the health of those close to the patient.

Many trials had methodological limitations introducing some risk of bias. Some trials did not clearly describe methods used for assessing utilization outcomes (e.g., readmissions, ER visits). Methods of handling missing data varied. Some trials did nothing to address missing data (i.e., analyzed only completers), but others conducted true intention-to-treat analyses and used appropriate methods of handling missing data. Some trials were limited in their ability to ascertain readmissions that were beyond a single institution.

Limitations also included inadequate sample sizes and heterogeneity of outcome measures across trials (specifically types of readmission rates). Reporting use of health services other than for the primary outcomes, such as ER visits, was variable across the included trials. This limited our ability to determine the effect of interventions on other measures of health services use (aside from readmission rates), such as an increase in ER visits or observational hospital stays.

Sometimes usual care and certain aspects of treatment interventions were not adequately described. Specifically, descriptions of whether (and how) interventions addressed medication management were often unsatisfactory. Categories of interventions that showed efficacy (e.g., the home-visiting and MDS-HF interventions) often included frequent visits with clinicians. Separating out individual components that are necessary from the overall type of interventions that showed efficacy was not possible. Moreover, some confounding components that were not described may be associated with efficacy as well, such as addressing social needs or optimizing HF pharmacotherapy.

## Research Gaps

We identified important gaps in the evidence that future research could address; many are highlighted above. Of note, the gaps we highlight relate only to the key questions that we addressed in this systematic review; our suggestions to address them should not eliminate a wide range of potentially important research that falls outside the specified scope of this review. Table 22 summarizes the gaps and offers examples of potential future research that could help to close them.

Table 22 Evidence gaps for future research, by Key Question

KQ | Evidence Gap | Potential Future Research and Improved Methods
1 | Few trials measured 30-day all-cause readmission outcomes (including those rated as high or unclear risk of bias); we found low SOE for home-visiting programs in reducing all-cause readmissions and the composite outcome (all-cause readmission or death). Evidence was insufficient to determine the efficacy of other intervention categories in reducing 30-day readmission rates. | If 30-day readmission rates remain an important metric for policy, reimbursement, and quality, then future studies should evaluate whether interventions that show efficacy in reducing 3- and 6-month readmission rates (e.g., care in an MDS-HF clinic following discharge) are also effective in reducing 30-day readmission rates. Future trials should ensure that the sample sizes and methods of ascertaining readmission outcomes are adequate to determine the effect of transitional care interventions on 30-day readmission rates. Future research could also include methods such as meta-analysis of individual patient data to ascertain whether other intervention categories reduce 30-day readmission rates.
1,2 | Only one trial evaluated one intervention that was based in a primary care clinic; this intervention primarily aimed to increase access. Evidence was insufficient to determine the efficacy of this intervention in reducing readmissions or mortality. | Given that many patients do not have access to specialty care (e.g., in rural settings) or may prefer to receive care following an HF admission in primary care clinics, future studies should evaluate the efficacy of transitional care interventions based in primary care clinics. Such experimental programs could include features such as home visits or a series of clinic-based visits following discharge. In addition, future research could examine the features of patients receiving services in primary care clinics versus those of patients in cardiology-run HF clinics; these variables might include severity of HF or coexisting conditions.
1, 3-4 | Key intervention components (content and process) were inconsistently described across trials. Some trials provided great detail, others very little. Researchers who aim to assess whether interventions reduce readmissions for the included time points (30 days to 6 months) do not use a common conceptual framework. | Future research of transitional care interventions could rely on guidance from the AHA statement offering a taxonomy for disease management for investigators to categorize and compare such programs.105 Alternatively, the AHA or others might amend this taxonomy to include more specific guidance on categorizing transitional-care-type interventions; for instance, incorporating subdomains in the “environment” domain that are more specific to the transition period might be helpful.
1 | Evidence was insufficient to determine the comparative effectiveness of transitional care interventions. Nearly all trials examined a particular program against “usual care” of various sorts. No trial tested a single complex intervention with and without a particular component thought to be critical to the intervention. | Future RCTs should address whether certain types of interventions are more efficacious than others. Examples of head-to-head trials include: (1) home-visiting programs that are higher vs. lower intensity or that differ in specific components; and (2) MDS- HF clinic followup compared with home visits that provide similar periodicity of followup and content (e.g., education on self-care and medication reconciliation).
1 | Telemonitoring interventions did not reduce readmissions over 6 months; whether this can be attributed to lack of care coordination or other factors remains unclear. | Future RCTs of telemonitoring interventions should include additional components that appear to be necessary for efficacy (based on our results for KQs 1-3). For example, conventional telemonitoring might be combined with one (or more) of three key components: (1) starts immediately after discharge, (2) is combined with initial in-person visits (in the clinic or in the home), and (3) is integrated with the patient's established outpatient care.
2 | Evidence was insufficient to determine whether transitional care interventions can reduce 30-day mortality. | Future trials and observational studies should evaluate whether interventions that reduce 30-day readmission rates increase or decrease mortality rates over the same period. There remains a concern about the relationship between reductions in 30-day readmission rates and mortality, especially for vulnerable populations.
2 | The literature did not adequately address the effect of interventions on burdens placed on either patients themselves or their caregivers. It also did not adequately examine the effect of interventions on health-related quality of life or physical functioning, beyond measuring changes in disease-specific outcomes (with the MLWHFQ). | Future research should include validated measures of caregiver burden, patient-reported measures of the self-care burden, or both.
2 | The literature did not adequately examine the effect of interventions on health-related quality of life or physical functioning, beyond measuring changes in disease-specific outcomes (with the MLWHFQ). | Health-related quality of life (in the form of PROs) is a crucial variable for many patients, families, professional societies, and research groups. Investigators could continue to use an HF-specific--specific instrument (such as the MLWHFQ, the Kansas City Cardiomyopathy Questionnaire or the Chronic Heart Failure Assessment tool). For broader quality-of-life outcomes, researchers should also consider use of reliable and valid PRO instruments; widely administered ones include the Medical Outcomes Study Short Forms and the EURO-QOL.
5 | Evidence was insufficient to determine whether certain subgroups of patients benefit from transitional care interventions. | Future research should assess whether readmission rates or other key outcomes differ by sex, racial or ethnic minority status, disease severity, literacy level, income, or socioeconomic status.

AHA = American Heart Association; HF = heart failure; KQ = Key Question; MDS-HF = multidisciplinary heart failure; MLWHFQ = Minnesota Living With Heart Failure Questionnaire; PRO = patient-reported outcome; RCT = randomized controlled trial; SOE = strength of evidence.

Also, we identified several methodological issues that increased the risk of bias for trials, and investigators could improve them in future research. Often trials only inadequately described methods of ascertaining outcomes relating to use of health care (e.g., readmissions, ER visits). Specifically, they did not say whether measurements were based on patient report, chart review, or some combination of measurements. Masking outcome assessments raised other concerns; for example, in some trials personnel delivering the intervention also appeared to be the primary staff for measuring health care utilization. Future trials should consider methods (such as blinded outcome assessments) that guard against measurement bias.

## Conclusions

Few trials evaluating transitional care interventions for adults with HF reported 30-day readmission rates; one high-intensity home-visiting trial did reduce all-cause readmission and the composite endpoint over 30 days (low SOE). Strong evidence supported findings that three approaches improved at least one of our primary outcomes over 3 to 6 months: home-visiting programs, STS, and MDS-HF clinic interventions. Home-visiting programs reduced all-cause readmission, HF-specific readmission, the composite outcome, and mortality; STS interventions reduced HF-specific readmission and mortality; and MDS-HF clinic interventions reduced all-cause readmission and mortality. Based on current evidence, telemonitoring interventions and primarily educational interventions did not reduce readmission or mortality. Direct evidence was insufficient to conclude whether one type of intervention was better than any other type of intervention. Evidence was generally insufficient to determine whether the efficacy of interventions differed for subgroups of patients. The potential harms of transitional care interventions (e.g., higher caregiver burden) were generally not reported.