# Strength of Evidence Tables

Table G1 All-cause readmission (number of people readmitted): Strength of evidence

Intervention Category; Time-point | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Findings and Direction^a^ [Magnitude] of Effect RR (95% CI) | Strength of Evidence
Home-visiting; 30 days | 2; 418 | Low | Consistent^b^ | Direct | Imprecise | High intensity (1 trial): 0.34 (0.19 to 0.62) Lower intensity (1 trial): 0.89 (0.43 to 1.85) | Low^b^
Home-visiting; 3 to 6 months | 9; 1,563 | Low | Consistent | Direct | Precise | 0.75 (0.68 to 0.86) | High^c^
Structured telephone support; 30 days | 1; 134 | Low | Unknown | Direct | Imprecise | 0.80 (0.38 to 1.65) | Insufficient
Structured telephone support; 3 to 6 months | 8;2,166 | Low | Consistent | Direct | Imprecise | 0.92 (0.77 to 1.10) | Moderate
Tele-monitoring; 30 days | 1; 168 | Low | Unknown | Direct | Imprecise | 1.02 (0.64 to 1.63) | Insufficient
Tele-monitoring; 3 to 6 months | 3; 434 | Low | Consistent^d^ | Direct | Imprecise | 1.11 (0.87 to 1.42) | Moderate
Clinic-based (nurse-led); 3 to 6 months | 2; 264 | Low | Inconsistent | Direct | Imprecise | 0.88 (0.57 to 1.37) | Low
Clinic-based (MDS-HF); 3 to 6 months | 2; 336 | Low | Consistent | Direct | Precise | 0.70 (0.55 to 0.89) | High
Clinic-based (Primary Care); 3 to 6 months | 1; 443 | Low | Unknown | Direct | Precise | 1.27 (1.05 to 1.54) | Insufficient
Primarily Educational; 3 to 6 months | 1; 200 | Low | Unknown | Direct | Imprecise | 1.14 (0.84 to 1.54) | Insufficient
Cognitive Training; 30 days | 1; 125 | Low | Unknown | Direct | Imprecise | 1.15 (0.71 to 2.28) | Insufficient

a For RR, values less than one favor the intervention group.

b For home-visiting programs, reduction in 30-day all-cause readmission differed by intervention intensity. The one trial assessing a higher intensity intervention showed efficacy1 while the one trial assessing a lower intensity intervention did not show efficacy.2 In grading the SOE, we considered results of similar interventions at other time-points. The low SOE refers to the overall assessment that the higher ntensity home-visiting program reduced all-cause readmission while the lower intensity intervention did not.

c Two additional trials reported on the total number of readmissions per group (rather than people readmitted): In one trial (N=200), patients receiving home visits had fewer unplanned readmissions (68) than those receiving usual care (118) (p = 0.031).3 In another trial (N=200), all-cause readmission did not differ between patients receiving home visits and those receiving usual care (measured as mean readmissions per patient-year alive: RR, 0.89; p=0.61).4

d Four telemonitoring studies reported the total number of readmissions per group (rather than the number of people readmitted); all-cause readmission did not differ between patients receiving telemonitoring and those receiving usual care at 30 days,5 3 months,6 or 6 months.5,7,8

Abbreviations: CI = confidence interval; MDS-HF = multidisciplinary heart failure; N = trial sample size; RCT = randomized controlled trial; RR = relative risk

Table G2 HF-specific readmission (number of people readmitted): Strength of evidence

Intervention Category; Time-point | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Findings and Direction^a^ [Magnitude] of Effect RR (95% CI) | Strength of Evidence
Home-visiting; 3 to 6 months | 1; 282 | Low | Consistent^b^ | Direct | Imprecise | 0.51 (0.31 to 0.82) | Moderate^b^
Structured telephone support; 30 days | 1; 134 | Low | Unknown | Direct | Imprecise | 0.63 (0.24 to 1.87) | Insufficient
Structured telephone support; 3 to 6 months | 7; 1790 | Low | Consistent | Direct | Precise | 0.74 (0.61 to 0.90) | High
Tele-monitoring; 3 to 6 months | 1; 182 | Low | Consistent^c^ | Direct | Imprecise | 1.70 (0.82 to 3.51) | Moderate^c^
Clinic-based (Nurse-led) 3 to 6 months | 1; 158 | Low | Unknown | Direct | Imprecise | 0.95 (0.68 to 1.32) | Insufficient
Clinic-based (MDS-HF) 3 to 6 months | 1; 106 | Low | Unknown | Direct | Imprecise | 0.70 (0.29 to 1.70) | Insufficient
Primarily Educational 3 months | 1; 223 | Low | Unknown | Direct | Precise | 0.53 (0.31 to 0.90) | Insufficient

a For RR, values less than one favor the intervention group

b Although one trial reported total number of people readmitted per group, we considered the findings consistent due to the fact that one other trial reported on the number of readmissions per group and found a similar effect: patients receiving home visits had fewer total HF readmissions than did patients receiving usual care (measured as readmissions per patient year alive, RR, 0.54; p<0.001; N=200).4

c Although one trial reported total number of people readmitted per group, we considered the findings consistent due to the fact that two other trial reported on the number of readmissions per group neither study found a difference between the intervention and control group two groups.7,8

Abbreviations: CI = confidence interval; HF = heart failure; MDS-HF = multidisciplinary heart failure; N = trial sample size; RR = relative risk.

Table G3 Composite all-cause readmission or death: Strength of evidence

Intervention Category; Time-point | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Findings and Direction [Magnitude] of Effect^a^ | Strength of Evidence
Home-visiting; 30 days | 1; 239 | Low | Unknown | Direct | Imprecise | HR (SE): 0.869 (0.033) vs. 0.737 (0.041) | Low^b^
Home-visiting; 3 to 6 months | 4; 824 | Low | Consistent | Direct | Imprecise | 3 trials (N=585): RR (95% CI): -0.78 (0.65 to 0.94) 1 trial (N=239): HR (SE): 0.600 (0.047) vs. 0.444 (0.047) | Moderate
Structured telephone support; 3 to 6 months | 3; 977 | Low | Inconsistent | Direct | Imprecise | RR (95% CI): 0.81 (0.58 to 1.12) | Low
Clinic-based (Nurse-led); 3 to 6 months | 1; 106 | Low | Unknown | Direct | Imprecise | RR (95% CI): 0.66 (0.43 to 1.01) | Insufficient
Clinic-based (MDS-HF); 3 to 6 months | 2; 306 | Low | Consistent | Direct | Imprecise | RR (95% CI): 0.80 (0.43 to 1.01) | Moderate
Primarily Educational; 3 to 6 months | 2; 423 | Low | Inconsistent | Direct | Imprecise | RR (95% CI): 0.92 (0.58 to 1.47) | Low

a For RRs, values less than one favor the intervention group.

b Although evidence was limited to 1 trial, consistency for the 30-day outcome was unknown, and evidence was imprecise, we upgraded the SOE because this intervention category has demonstrated efficacy for this outcome at different time points—thus, increasing our confidence in the results of this single trial.

Abbreviations: CI = confidence interval; HR = hazard ratio; MDS-HF = multidisciplinary heart failure; N = trial sample size; SE = standard error; SOE = strength of evidence.

Table G4 Emergency room or acute care visits

Intervention Category; Time-point | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Findings and Direction [Magnitude] of Effect^a^ | Strength of Evidence
Home-visiting; 30 days | 1; 179 | Medium | Unknown | Direct | Imprecise | % of subjects with ER visits, (intervention vs. control): 5% vs. 4%, p-value NR | Insufficient
Home-visiting; 3 to 6 months | 1; 179 | Medium | Unknown | Direct | Imprecise | % of subjects with ER visits (intervention vs. control): 17% vs. 22%, p-value NR | Insufficient
Home-visiting; 3 to 6 months | 1; 97 | Medium | Unknown | Direct | Imprecise | Total ER visits per group (intervention vs. control): 48 vs. 87 visits, p=0.05 | Insufficient
Structured telephone support; 3 to 6 months | 1; 111 | Medium | Unknown | Direct | Imprecise | Total ER visits per group: RR (95% CI): 0.66 (0.21 to 2.05) | Insufficient
Structured telephone support; 3 to 6 months | 2; 634 | Medium | Consistent | Direct | Imprecise | % of patients with at least one ER visit (intervention vs. control): 22.1 vs. 27.9, p=0.266 Mean ER visits per person (intervention vs. control): 0.14 vs. 0.11, p=0.58 | Low
Telemonitoring 3 to 6 months | 2; 284 | Medium | Unknown | Direct | Imprecise | Average ER visits per patient (intervention vs. control): 0.34 vs. 0.38, p=0.73 Total ER visits per group (intervention vs. control): 20 vs. 32, p-value NR | Insufficient
Clinic-based (MDS-HF); 3 to 6 months | 1; 230 | Medium | Unknown | Direct | Imprecise | Number of patients per group with ER visits: HR (95% CI): 0.97 (0.70 to 1.36) | Insufficient
Primarily Educational; 3 to 6 months | 1; 76 | Medium | Unknown | Direct | Imprecise | % of patients per group seen in ER (intervention vs. control): 38 vs. 33, p=0.68 | Insufficient

a For RRs and HRs, values less than 1.0 favor the intervention group.

Abbreviations: CI = confidence interval; ER = emergency room; HR = hazard ratio; MDS-HF = multidisciplinary heart failure; NR = not reported; RR = relative risk.

Table G5 Hospital days (of subsequent readmissions)

Intervention Category; Time-point | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Findings and Direction [Magnitude] of Effect^a^ | Strength of Evidence
Home-visiting; 30 days | 1; 179 | Medium | Unknown | Direct | Imprecise | Mean number of readmission days per person readmitted (SD) (intervention vs. control): 2.2 (7) vs. 2.3 (7) | Insufficient
Home-visiting; 3 months | 4; 765 | Medium | Consistent | Direct | Imprecise | Difference in total hospital days per group: WMD (95% CI): -1.17 (-2.44 to 0.09) | Low
Home-visiting; 6 months | 3; 403 | Medium | Consistent | Direct | Imprecise | Total hospital days (intervention vs. control, p=value): 261 vs. 452, p=0.05 875 vs. 1476, p=0.04 108 vs. 459, p≤0.01 | Low
Structured telephone support; 30 days | 1; 134 | Medium | Unknown | Direct | Imprecise | WMD (95% CI): -0.95 (-2.43 to 0.53) | Insufficient
Structured telephone support; 3 to 6 months | 5; 1,068 | Medium | Consistent | Direct | Precise | WMD (95% CI): -2.49 (-3.93 to -1.04) | Moderate
Telemonitoring 30 days | 1; 168 | Medium | Unknown | Direct | Imprecise | Mean length of hospital stay per patient readmitted (SD) (intervention vs. control): 1.9 (4.4) vs. 1.8 (12.2) | Insufficient
Telemonitoring 3 to 6 months | 2; 350 | Medium | Unknown | Direct | Imprecise | Mean length of hospital stay per patient readmitted (SD) (intervention vs. control): 4.9 (8.2) vs. 4.8 (10.2) Median duration of readmission hospital stay (intervention vs. control): 17 vs. 13 days, p=0.99 | Insufficient
Clinic-based (Nurse-led); 3 to 6 months | 2; 260 | Medium | Inconsistent | Direct | Imprecise | Total hospital days per group (intervention vs. control): 350 vs. 592, p=0.045 Mean hospital days per patient readmitted (SD) (intervention vs. control): 26 (19) vs. 18 (19); p-value NS per investigators | Insufficient
Clinic-based (MDS-HF); 3 to 6 months | 1; 230 | Medium | Unknown | Direct | Imprecise | Total hospital days per patient (intervention vs. control): Hazard ratio (95% CI): 0.61 (0.39 to 0.95) | Insufficient
Clinic-based (primary-care); 3 to 6 months | 1; 443 | Medium | Unknown | Direct | Precise | Mean hospital days per patient readmitted (intervention vs. control): 9.1 vs. 7.3, p=0.04 | Insufficient
Primarily Educational; 3 to 3 months | 1; 200 | Medium | Unknown | Direct | Imprecise | Mean length of hospital stay per person readmitted: 20 vs. 15 days, p-value NS per authors | Insufficient

a Negative values favor the intervention group (for WMD).

Abbreviations: CI = confidence interval; HR = hazard ratio; MDS-HF = multidisciplinary heart failure; NS = not significant; SD = standard deviation; WMD = weighted mean difference.

Table G6 Quality of life (MLWHFQ) by outcome timing – home-visiting programs versus usual care: Strength of evidence

Intervention Category; Time-point | Number of Studies; Subjects Analyzed | Study Limitations | Consistency | Directness | Precision | Findings and Direction [Magnitude] of Effect^a^ | Strength of Evidence
Home-visiting; 14 days | 1; 226 | Medium | Unknown | Direct | Imprecise | No difference in mean MLWHFQ score at 14 days | Insufficient
Home-visiting; 3 months | 3; 345 | Medium | Consistent | Direct | Imprecise | 2 trials: SMD (95% CI): -0.26 (-0.47 to -0.05).1,9 One trial (N=200): mean MLWHFQ (change from baseline, intervention vs. control): -19 vs. -1, p=0.04.^3^ | Low
Home-visiting; 6 months | 2; 384 | Medium | Inconsistent | Direct | Imprecise | Difference in mean score at 6 months: SMD (95% CI): -0.04 (-0.35 to 0.26) | Insufficient
Structured telephone support; 3 months | 3; 331 | Medium | Consistent | Direct | Imprecise | Difference in mean scores at 3 months: WMD (95% CI): -0.26 (-0.47 to -0.05) | Low
Structured telephone support; 6 months | 3; 331 | Medium | Consistent | Direct | Imprecise | Difference in mean scores at 6 months: WMD (95% CI): -0.19 (-0.49 to 0.10) | Low
Telemonitoring 3 months | 1; 102 | Medium | Unknown | Direct | Imprecise | Difference in mean scores at 3 months: 27.4 vs. 27.3, p=0.99 | Insufficient
Clinic-based Interventions 6 months | 1; 200 | Medium | Unknown | Direct | Imprecise | MLWHFQ change from baseline: -28.3 vs. -15.7, p=0.01 | Insufficient
Primarily Educational 6 months | 2; 372 | Medium | Inconsistent | Direct | Imprecise | One trial (N=223): mean MLWHFQ (SD) (intervention vs. control): 14 (20) vs. 10 (16), p<0.0001]. Another trial (N=149): mean MLWHFQ (SD) (intervention vs. control): 41 (22) vs. 42 (25), p-value NR. | Insufficient

a For SMDs and WMDs, negative values favor the intervention group.

Abbreviations: CI = confidence interval; MLWHFQ = Minnesota Living With Heart Failure Questionnaire; N = trial sample size; NR = not reported; SD = standard deviation; SMD = standardized mean difference; vs. = versus; WMD = weighted mean difference.

Table G7 Mortality: Strength of evidence

Intervention Category; Time-point | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Findings and Direction [Magnitude] of Effect RR (95% CI)^a^ | Strength of Evidence
Home-visiting; 30 days | 1; 239 | Low | Unknown | Direct | Imprecise | 1.03 (0.15 to 7.16) | Insufficient
Home-visiting; 3 to 6 months | 8; 1693 | Low | Consistent | Direct | Imprecise^b^ | 0.77 (0.60 to 0.996) | Moderate
Structured telephone support; 3 to 6 months | 7; 2011 | Low | Consistent | Direct | Imprecise | 0.74 (0.56 to 0.97) | Moderate
Telemonitoring 3 to 6 months | 3; 564 | Low | Inconsistent | Direct | Imprecise | 0.93 (0.25 to 3.48) | Low
Clinic-based (Nurse-led); 3 to 6 months | 2; 264 | Low | Unknown | Direct | Imprecise | 0.59 (0.12 to 3.03) | Low
Clinic-based (MDS-HF); 6 months | 3; 536 | Low | Consistent | Direct | Imprecise^b^ | 0.56 (0.34 to 0.92) | Moderate
Clinic-based (primary care); 6 months | 1; 443 | Low | Unknown | Direct | Imprecise | 1.52 (0.88 to 2.63) | Insufficient
Primarily Educational; 3 to 6 months | 2; 423 | Low | Inconsistent | Direct | Imprecise | 1.20 (0.52 to 2.76) | Low
Cognitive Training 30 days | 1; 125 | Low | Unknown | Direct | Imprecise | 0.07 (0.00 to 1.12) | Insufficient

a RR less than one favor the intervention.

b Although the findings are statistically significant, the confidence intervals around these estimates are wide, making it difficult to determine the true magnitude of effect for these mortality outcomes (compared to usual care). For this reason, we have called these estimates “imprecise.”

Abbreviations: CI = confidence interval; MDS-HF = multidisciplinary heart failure; RR = relative risk

## Appendix G References

1 Naylor MD, Brooten DA, Campbell RL, et al. Transitional care of older adults hospitalized with heart failure: a randomized, controlled trial. J Am Geriatr Soc. May. 2004;52(5):675-84. [pmid: 15086645].
2 Jaarsma T, Halfens R, Huijer Abu-Saad H, et al. Effects of education and support on self-care and resource utilization in patients with heart failure. Eur Heart J. May. 1999;20(9):673-82. [pmid: 10208788].
3 Stewart S, Marley JE, Horowitz JD. Effects of a multidisciplinary, home-based intervention on unplanned readmissions and survival among patients with chronic congestive heart failure: a randomised controlled study. Lancet. Sep. 25. 1999;354(9184):1077-83. [pmid: 10509499].
4 Kimmelstiel C, Levine D, Perry K, et al. Randomized, controlled evaluation of short- and long-term benefits of heart failure disease management within a diverse provider network: the SPAN-CHF trial. Circulation. Sep. 14. 2004;110(11):1450-5. [pmid: 15313938].
5 Jerant AF, Azari R, Martinez C, et al. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Serv Q. 2003;22(1):1-20. [pmid: 12749524].
6 Woodend AK, Sherrard H, Fraser M, et al. Telehome monitoring in patients with cardiac disease who are at high risk of readmission. Heart Lung. Jan-Feb. 2008;37(1):36-45. [pmid: 18206525].
7 Goldberg LR, Piette JD, Walsh MN, et al. Randomized trial of a daily electronic home monitoring system in patients with advanced heart failure: the Weight Monitoring in Heart Failure (WHARF) trial. Am Heart J. Oct. 2003;146(4):705-12. [pmid: 14564327].
8 Dendale P, De Keulenaer G, Troisfontaines P, et al. Effect of a telemonitoring-facilitated collaboration between general practitioner and heart failure clinic on mortality and rehospitalization rates in severe heart failure: the TEMA-HF 1 (TElemonitoring in the MAnagement of Heart Failure) study. Eur J Heart Fail. Mar. 2012;14(3):333-40. [pmid: 22045925].
9 Holland R, Brooksby I, Lenaghan E, et al. Effectiveness of visits from community pharmacists for patients with heart failure: HeartMed randomised controlled trial. BMJ. May. 26. 2007;334(7603):1098. [pmid: 17452390].