# Meta-Analysis and Forest Plots of Individual Trials: Sensitivity Analyses

Figure F1 All-cause readmission for transitional care interventions compared with usual care, by intervention category and outcome timing: Sensitivity analysis of including trials rated as having high or unclear ROB

Figure F-1 is titled “All-cause readmission for transitional care interventions compared with usual care, by intervention category and outcome timing: sensitivity analysis including trials rated as having high or unclear ROB”. The figure displays forest plots of sensitivity analyses of trials reporting all-cause readmissions for patients receiving transitional care interventions compared with usual care, by intervention and outcome timing. The main analyses and related figure are described in appendix E and in the “Detailed Synthesis: All-cause readmission: Transitional interventions compared with usual care” section of the main report. The following results are shown in Figure F-1. At 30 days, no differences were found in the risk of all-cause readmission between patients receiving usual care and home-visiting programs (2 trials, 0 high/unclear risk of bias, RR, 0.54, CI, 0.21 to 1.37); structured telephone support (single trial, 0 high/unclear risk of bias, 0.80, 95% CI, 0.38, 1.65); telemonitoring (single trial, 0 high/unclear risk of bias, RR, 1.02, 95% CI 0.64 to 1.63); cognitive training (other) (single trial, 0 high/unclear risk of bias, RR, 1.15, 95% CI 0.58 to 2.28); and peer support (single trial, 1 high/unclear risk of bias, RR, 1.53, 95% CI, 0.54 to 4.31). Over 3 to 6 months, patients who received home-visiting programs were at a reduced risk of all-cause readmission than patients receiving usual care (11 trials, 2 high/unclear risk of bias, RR, 0.78 (95% CI 0.70 to 0.88). No significant differences were found in the risk of all-cause readmissions for patients who received usual care and clinic-based (MDS-HF) (2 trials, 0 high/unclear risk of bias, RR, 0.70, 95% CI 0.55 to 0.89) clinic-based (nurse-led) (2 trials, 0 high/unclear risk of bias, RR, 0.88, 95% CI 0.57 to 1.37); primarily educational (2 trials, 1 high/unclear risk of bias, RR, 1.00, 95% CI, 0.78 to 1.27). No significant differences were found in the risk of all-cause readmission between patients receiving usual care and those receiving clinic-based (primary care) care at 6 months (single trial, 0 high/unclear risk of bias, RR, 1.27, 95% CI, 1.05 to 1.54) and peer support (other) at 3 months (single trial, 1 high/unclear risk of bias, RR, 0.88, 95% CI, 0.45 to 1.71).

Figure F2 HF readmissions for transitional care interventions compared with usual care, by intervention category and outcome timing: Sensitivity analysis including trials rated as having high or unclear ROB

Figure F-2 is titled “HF readmissions for transitional care interventions compared with usual care, by intervention category and outcome timing: sensitivity analysis including trials rated as having high or unclear ROB.” The figure displays forest plots of sensitivity analyses of trials reporting heart failure readmissions for patients receiving transitional care interventions compared with usual care, by intervention and outcome timing. The main analyses and related figure are described in appendix E and in the “Heart Failure Readmissions: Transitional Care Interventions Compared with Usual Care” section of the main report. The following results are shown in Figure F-2. Over 3 to 6 months, patients who received home visits were at a reduced risk of heart failure readmissions than those who received usual care (3 trials, 2 high/unclear risk of bias, RR, 0.66, 95% CI, 0.46 to 0.93). One trial (N=134) (1 high/unclear risk of bias) found no difference in the risk of heart failure readmissions between patients receiving structured telephone support and those receiving usual care at 30 days (RR, 0.63; 95% CI, 0.24 to 1.67). Over 3 to 6 months, our meta-analysis (eight trials, 1 high/unclear risk of bias) found that people receiving STS had a lower risk of heart failure readmissions than controls (RR, 0.74, 95% CI, 0.61 to 0.90). At 6 months, one trial (N=182) found no difference in the risk of heart failure readmission between patients receiving telemonitoring and controls (0 high/unclear risk of bias, RR, 1.70; 95% CI, 0.82 to 3.51). Two clinic based MDS-HF trials (1 high/unclear risk of bias) found no difference in the risk of HF readmission between patients receiving the intervention and those receiving usual care (RR, 0.29; 95% CI, 0.03 to 2.57). One nurse-led clinic intervention (N=158) also found no difference in the risk of HF readmission between the intervention and control groups (0 high/unclear risk of bias, RR, 0.95; 95% CI, 0.68 to 1.32). Two trials (1 high/unclear risk of bias) found no difference in the risk of HF readmission among patients receiving HF education to those receiving usual care at 3 to 6 months (RR, 0.76; 95% CI, 0.36 to 1.63). Two peer support trials found no difference in the risk of HF readmission between the intervention and control groups at 30 days (1 high/unclear risk of bias, RR, 1.91; 95% CI, 0.37 to 9.90) and at 3 months (1 high/unclear risk of bias, RR, 1.91; 95% CI, 0.62 to 5.89). The overall risk difference from 1 study (0 high/unclear risk of bias) for Structured Telephone Support at 30 days is 0.63 (95% CI 0.24, 1.67). The overall risk difference from 8 trials (1 high/unclear risk of bias) for Structured Telephone Support over 3 to 6 months is 0.74 (95% CI 0.61, 0.90). T The overall risk difference from 1 study (1 high/unclear risk of bias) for Clinic-based (MDS-HF) at 30 days is 0.00 (95% CI -0.06, 0.06). The overall risk difference from 2 trials (1 high/unclear risk of bias) for Clinic-based (MDS-HF) over 3 months to 6 months is 0.29 (95% CI 0.03, 2.57). The overall risk difference from 1 study (0 high/unclear risk of bias) for Clinic-based (nurse-led) at 6 months is 0.95(95% CI 0.68, 1.32). The overall risk difference from 2 studies (1 high/unclear risk of bias) for Primarily Educational over 3 to 6 months 0.76 (95% CI 0.36, 1.63). The overall risk difference from 1 study (1 high/unclear risk of bias) for Peer Support (other) at 30 days is 1.91 (95% CI 0.37, 9.90). The overall risk difference from 1 study (1 high/unclear risk of bias) for peer Support (other) at 3 months is 1.91 (95% CI 0.62, 5.89).

Figure F3 Composite all-cause readmission or death for transitional care interventions compared with usual care, by intervention category and outcome timing: Sensitivity analysis including trials rated as having high or unclear ROB

Figure F-3 is titled, “Composite all-cause readmission or death for transitional care interventions compared with usual care, by intervention category and outcome timing: Sensitivity analysis including studies trials rated as having high or unclear ROB.” The figure displays forest plots of trials reporting combined all-cause readmission or death for transitional care interventions versus usual care, by intervention category and outcome timing. The main analyses and related figure are described in appendix E and in the “Combined All-cause Readmission or Death: Transitional Care Interventions Compared with Usual Care” section of the main report. The following results are shown in Figure F-3. Our meta-analysis found a reduced risk of the composite outcome in patients receiving home visits compared to controls (4 studies, 1 high/unclear risk of bias, RR, 0.85 (95% CI, 0.72 to 0.99). Over 3 to 6 months, our meta-analysis (3 trials, 0 high/unclear risk of bias) found no difference in the risk of the composite outcome between patients receiving structured telephone support and controls (RR, 0.81; 95% CI, 0.58 to 1.12). Our meta-analysis (two trials, 0 high/unclear risk of bias) showed that over 3 to 6 months patients receiving clinic-based MDS outpatient care experienced a trend towards reduced risk of the composite outcome compared to controls that was not statistically significant (RR, 0.80; 95% CI, 0.63 to 1.02). One trial (N=106)(0 high/unclear risk of bias) assessing a nurse-led HF clinic found that patients receiving the intervention experienced a trend towards reduced risk of the composite outcome (that was not statistically significant) compared to controls (RR, 0.66; 95% CI, 0.43 to 1.01) at 3 months. Our meta-analysis (3 trials, 1 high/unclear risk of bias) found no difference in the risk of the composite outcome between patients receiving an educational intervention and patients receiving usual care (RR, 0.92; 95% CI, 0.71 to 1.21) over 3 to 6 months.

Figure F4 Mortality for transitional care interventions compared with usual care, by intervention category and outcome timing: Sensitivity analysis including trials rated as having high or unclear ROB

Note: For the trial by Wakefield et al., we include the telephone care arm here (not the videophone arm).1

Figure F-4 is titled, “Mortality for transitional care interventions compared with usual care, by intervention category and outcome timing: sensitivity analysis including trials rated as having high or unclear risk of bias.” The figure displays forest plots of trials reporting mortality for transitional care interventions versus usual care, by intervention category and outcome timing. The main analyses and related figure are described in appendix E and in the “Mortality: Transitional Care Interventions Compared with Usual Care” section of the main report. The following results are shown in Figure F-4. One home-vesting trial (N=239) reported mortality rates at 30 days; there was no difference in mortality between the intervention and control groups (0 high/unclear risk of bias, RR, 1.03; 95% CI, 0.15 to 7.16). Over 3 to 6 months, our meta-analysis (11 trials, 3 high/unclear risk of bias) did not find a difference in risk of mortality among patients receiving home visits compared to those receiving usual care (RR, 0.85; 95% CI, 0.68 to 1.05). Our meta-analysis (9 trials, 1 high/unclear risk of bias) found reduced risk of mortality among patients receiving structured telephone support compared to controls (RR, 0.73; 95% CI, 0.56 to 0.94). Our meta-analysis (5 trials, 2 high/unclear risk of bias) found no difference in mortality over 3 to 6 months, between patients receiving telemonitoring and those receiving usual care (RR, 0.70; 95% CI, 0.24 to 2.03; I2 80.4 percent). Our meta-analysis (4 trials, 1 high/unclear risk of bias) found that the MDS-HF clinic patients had reduced risk of mortality compared to control patients (RR, 0.59; 95% CI, 0.37 to 0.94). Our meta-analysis (two trials) assessing nurse-led HF clinic interventions found no difference in mortality over 3 to 6 months between patients receiving the intervention and patients receiving usual care (RR, 0.59; 95% CI, 0.12 to 3.03, I2 83.8%). The trial assessing increased access to primary care (N= 443) found a trend towards increased mortality in the intervention group compared with controls that was not statistically significant (RR, 1.52; 95% CI, 0.88 to 2.63). Our meta-analysis (4 trials, 2 high/unclear risk of bias) found no difference in mortality between patients receiving an educational intervention and those receiving usual care (RR, 1.51; 95% CI, 0.91 to 2.49). One trial assessing cognitive training among patients with HF and co-existing mild cognitive dysfunction at 30 days found that the group receiving the intervention experienced a trend towards reduced mortality that was not statistically significant (RR, 0.07; 95% CI, 0.00 to 1.12). The overall risk difference from one trial (0 high/unclear risk of bias) for Home-visiting at 30 days is 1.03 (95% CI 0.15, 7.16). The overall risk difference from 11 trials (3 high/unclear risk of bias) for Home-visiting Program over 3 to 6 months is 0.85 (95% CI 0.68, 1.05). The overall risk difference from 10 trials (1 high/unclear risk of bias) for Structured Telephone Support over 3 to 6 months is 0.77 (95% CI 0.60, 0.98). The overall risk difference from 5 trials (2 high/unclear risk of bias) for Telemonitoring over 3 months to 6 months is 0.70 (95% CI 0.24, 2.03). The overall risk difference from 4 trials (1 high/unclear risk of bias) for Clinic-based (MDS-HF) over 3 to 6 months is 0.59 (95% CI 0.37, 0.94). The overall risk difference from 2 trials (0 high/unclear risk of bias) for Clinic-based (nurse-led) over 3 to 6 months) is 1.52 (95% CI 0.88, 2.63). The overall risk difference from 4 trials (2 high/unclear risk of bias) for Primarily Educational over 3 to 6 months is 1.51 (95% CI 0.91, 2.49). The overall risk difference from 1 study (0 high/unclear risk of bias) for Cognitive Training at 30 days is 0.07 (95% CI 0.00, 1.12).

## Appendix F Reference

1 Wakefield BJ, Holman JE, Ray A, et al. Outcomes of a home telehealth intervention for patients with heart failure. J Telemed Telecare. 2009;15(1):46-50. [pmid: 19139220].