# Meta-Analysis and Forest Plots of Individual Trials

Figure E1 All-cause readmission for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-1 is titled “All-cause readmission for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and Forest Plot of Individual Trials.” The figure displays forest plots of trials reporting all-cause readmissions for transitional care interventions versus usual care, by intervention category and outcome timing. The results shown in this figure are described further in “Detailed Synthesis: All-cause readmission: Transitional interventions compared with usual care”of the main report. Home-Visiting Programs: “At 30 days, our meta-analysis (two trials) found no difference in the risk of all-cause readmissions between the patients receiving home visits and those receiving usual care (RR, 0.54; 95% CI, 0.21 to 1.37). However, there was considerable statistical heterogeneity between these two trials (I2 =74.4%) and also important clinical differences in the intervention delivered.” “Over 3 to 6 months, our meta-analysis (nine trials) found that patients receiving home visits had a reduced risk of all-cause readmission (RR, 0.75; 95% CI, 0.66 to 0.86). Structured Telephone Support: “One trial (N= 134) reported all-cause readmission at 30 days; the readmission rate did not differ between patients receiving structured telephone support and those receiving usual care (RR, 0.80; 95% CI, 0.38 to 1.65). Over 3 to 6 months, our meta-analysis (eight trials) found no difference in the relative risk of all-cause readmission between patients receiving structured telephone support and those receiving usual care (RR, 0.92; 95% CI, 0.77 to 1.10). “ Telemonitoring: “One trial (N=168) reported all-cause readmission at 30 days; the risk of all-cause readmission among patients receiving telemonitoring and those receiving usual care did not differ (RR, 1.02; 95% CI, 0.64 to 1.63). Over 3 to 6 months, our meta-analysis (three trials) found no difference in the risk of readmission between patients receiving telemonitoring and those receiving usual care (RR, 1.11; 95% CI, 0.87 to 1.42).” Clinic-based Interventions: “Given heterogeneity in the interventions among the clinic-based interventions, we pooled data separately by clinic setting: multidisciplinary HF (MDS-HF) clinic, nurse-led HF clinic, and primary care clinic. Among the MDS-HF interventions, our meta-analysis (two trials) found that patients receiving the intervention had a lower risk of all-cause readmission compared with patients receiving usual care (RR 0.70; 95% CI, 0.55 to 0.89). Over three to six month, our meta-analysis (two trials) found that patients receiving a nurse-led clinic-based intervention and those receiving usual care had a similar risk of all-cause readmission (RR, 0.88; 95% CI, 0.57 to 1.37). One trial (N=443) found that patients with HF who had increased (or enhanced) access to primary care (through a Department of Veterans Affairs [VA] health care setting) following discharge had a higher risk of all-cause readmission than the control group (RR, 1.27; 95% CI, 1.05 to 1.54).” Primarily Educational Interventions: “One trial found no difference in the risk of all-cause readmission at 6 months between patients receiving intensive pre-discharge education and controls (RR, 1.14; 95% CI, 0.84 to 1.54).” Other Interventions: “One trial (N=125) of cognitive training among patients with HF and coexisting cognitive dysfunction found no difference in the risk of 30-day readmission between patients receiving the intervention and controls (RR 1.15; 95% CI, 0.84 to 1.54).”

Figure E2 HF-specific readmission for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-2 is titled “Heart failure readmissions for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and Forest Plot of Individual Trials”. The figure displays a forest plots of trials reporting HF readmissions (number of people readmitted). The figure is described further in the “Detailed Synthesis: Heart Failure Readmission: Transitional Care Interventions Compared with Usual Care” of the main report. Home-visiting program: “At 3 months, one trial (N=282) found that patients receiving home visits had a reduced risk of HF readmissions compared with controls (RR, 0.51; 95% CI, 0.31 to 0.82). One other trial (N=200) reported the total number of readmissions per group (rather than the number of patients readmitted) at 3 months; patients receiving home visits had fewer total HF readmissions than did patients receiving usual care (measured as readmissions per patient year alive, RR, 0.54; p<0.001).” Structured Telephone Support: “One trial (N=134) found no difference in the risk of HF readmissions between patients receiving STS and those receiving usual care at 30 days (RR, 0.63; 95% CI, 0.84 to 1.54). Over 3 to 6 months, our meta-analysis (nine trials) found that people receiving STS had a lower risk of HF readmissions than controls (RR 0.74, 95% CI, -0.61 to 0.90).” Telemonitoring: “At 6 months, one trial (N=182) found no difference in the risk of HF readmission between patients receiving telemonitoring and controls (RR, 1.70; 95% CI, 0.82 to 3.51). Two additional trials reported the total number of readmissions per group (rather than patients readmitted); neither study found a difference between these two groups.” Clinic-based Interventions: “Two clinic based interventions reported HF readmissions at 6 months, one MDS-HF clinic intervention and one nurse-led clinic intervention. The MDS-HF trial (N=106) found no difference in the risk of HF readmission between patients receiving the intervention and those receiving usual care (RR, 0.70; 95% CI, 0.29 to 1.70). The trial of nurse-led clinic intervention (N=158) also found no difference in the risk of HF readmission between the intervention and control groups (RR, 0.95; 95% CI, 0.68 to 1.32).” Primarily Educational Interventions: “One trial (N=123) found a lower risk of HF readmission among patients receiving face-to-face intensive HF education before discharge compared to those receiving usual care at 3 months (RR, 0.53; 95% CI, 0.31 to 0.90).”

Figure E3 Composite all-cause readmission or death for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-3 is titled, “Composite all-cause readmission or death for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and Forest Plot of Individual Trials.” The figure displays forest plots of trials reporting combined all-cause readmission or death for transitional care interventions versus usual care, by intervention category and outcome timing. This figure is described further in the “Combined All-cause Readmission or Death: Transitional Care Interventions Compared with Usual Care” of the main report. Home-visiting Programs: “Our meta-analyses (three RCTs) found a reduced risk of the composite outcome in patients receiving home visits compared to controls (RR, 0.78; 95% CI, 0.65 to 0.94).” Structured Telephone Support: “Over 3 to 6 months, our meta-analysis (3 trials) found no difference in the risk of the composite outcome between patients receiving STS and controls (RR, 0.81; 95% CI, 0.58 to 1.12).” Clinic-based Interventions: “Our meta-analysis (two trials) showed that patients receiving MDS outpatient care experienced a trend toward reduced risk of the composite outcome compared to controls that was not statistically significant (RR, 0.80; 95% CI, 0.63 to 1.02). One trial (N=106) assessing a nurse-led HF clinic found that patients receiving the intervention experienced a trend towards reduced risk of the composite outcome (that was not statistically significant) compared to controls (RR, 0.66; 95% CI, 0.43 to 1.01).” Primarily Educational Interventions: “Our meta-analysis (two trials) found no difference in the risk of the composite outcome between patients receiving an educational intervention and patients receiving usual care (RR, 0.92; 95% CI, 0.58 to 1.47).”

Figure E4 Mean hospital days per person (of subsequent readmissions) for home-visiting programs compared with usual care over 3 months

Figure E-4 displays a forest plot showing mean hospital days per person (of subsequent readmissions) for home-visiting programs versus usual care over 3 months. The figure is described further in ‘Hospital Days (of Subsequent Readmissions): Transitional Care Interventions Compared with Usual Care: Home-Visiting Programs’ of the main report: “Our meta-analysis (four trials) found no difference in the mean number of hospital days per person accumulated over 3 months between people receiving home visits and those receiving usual care (WMD, -1.17; 95% CI, -2.44 to 0.09).”

Figure E5 Total hospital days per group (of subsequent readmissions) for structured telephone support interventions compared with usual care, by outcome timing: Meta-analysis and forest plot of individual trials

Figure E-5 displays a forest plot showing total hospital days per group (of subsequent readmissions) for structured telephone support interventions versus usual care, by outcome timing. This figure is described in ‘Hospital Days (of Subsequent Readmissions): Transitional Care Interventions Compared with Usual Care: Structured Telephone Support’ of the main report: “At 30 days, one trial (N=134) found no difference in the mean hospital days accumulated between patients receiving STS and controls (WMD, -0.95; 95% CI, -2.43 to 0.53). Our meta-analysis (five trials) found that patients receiving STS accumulated fewer total hospital days over 3 to 6 months than did patients receiving usual care (WMD, -2.49; 95% CI, 3.39 to -11.04). ”

Figure E6 Mortality among patients receiving transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and forest plot of individual trials

Note: For the trial by Wakefield et al., we include the telephone care arm here (not the videophone arm).1

Figure E-6 is titled “Mortality among patients receiving transitional care interventions compared with usual care, by intervention category and outcome timing.” The figure displays forest plots of trials reporting mortality for patients receiving transitional care interventions versus usual care, by intervention and outcome timing. This figure is described further in the “Mortality: Transitional Care Interventions versus Usual Care” of main report. Home-visiting Programs: “One trial (N=239) reported mortality rates at 30 days; there was no difference in mortality between the intervention and control groups (RR, 1.03; 95% CI, 0.15 to 7.16). Over 3 to 6 months, our meta-analysis (eight trials) found a reduced risk of mortality among patients receiving home visits compared to those receiving usual care (RR, 0.77; 95% CI, 0.60 to 0.996). “ Structured Telephone Support: “Our meta-analysis (six trials) found reduced risk of mortality among patients receiving STS compared to controls (RR, 0.69; 95% CI, 0.51 to 0.92).” Telemonitoring: “Our meta-analysis (three trials) found no difference in mortality over 3 to 6 months, between patients receiving telemonitoring and those receiving usual care (RR, 0.93; 95% CI, 0.25 to 3.48; I2 84 percent).” Clinic-based Interventions: “ Our meta-analysis (three trials) found that the MDS-HF clinic patients had reduced risk of mortality compared to control patients (RR, 0.56; 95% CI, 0.34 to 0.92).Our meta-analysis (two trials) assessing nurse-led HF clinic interventions found no difference in mortality over 3 to 6 months between patients receiving the intervention and patients receiving usual care (RR, 0.59; 95% CI, 0.12 to 3.03, I2 83.8%). The trial assessing increased access to primary care (N= 443) found a trend towards increased mortality in the intervention group compared with controls that was not statistically significant (RR, 1.52; 95% CI, 0.88 to 2.63).” Primarily Educational Interventions: “Our meta-analysis (two trials) found no difference in mortality between patients receiving an educational intervention and those receiving usual care (RR, 1.20; 95% CI, 0.52 to 2.76).” Other Interventions: “One trial assessing cognitive training among patients with HF and co-existing mild cognitive dysfunction found that the group receiving the intervention experienced a trend towards reduced mortality that was not statistically significant (RR, 0.07; 95% CI, 0.00 to 1.12).”

Figure E7 Difference in mean MLWHFQ scores for home-visiting programs compared with usual care, by outcome timing

Note: Naylor and colleagues transformed MLWHFQ scores to ordinal scales (assigning a score of 0 to patients who died to account for missing data and grouping other scores into quartiles ranging from 1 to 5); thus, although they measured quality of life with the same instrument, the scale differed from that used in other trials.2

Figure E-7 displays a forest plot showing difference in mean MLWHFQ scores for home-visiting programs versus usual care, by outcome timing. This figure is described in ‘Quality of Life: Home-Visiting Program’ of the main report: “Our meta-analysis (two trials) found that patients receiving home visits had better HF-specific quality of life than controls as measured by the MLWHFQ at 3 months (standardized mean difference [SMD], -0.26; 95% CI, -0.47 to -0.05) but not at 6 months (SMD, -0.04; 95% CI, -0.35 to 0.26). One additional trial (N=200) found significant improvement in MLWHFQ scores at 3 months in patients receiving home visits compared with those receiving usual care (change from baseline: -19 versus -1; p=0.04).”

Figure E8 Difference in mean MLWHFQ scores for structured telephone support interventions compared with usual care, by outcome timing

Note: For the trial by Wakefield et al., we include the telephone care arm here (not the videophone arm).1

Figure E-8 displays a forest plot showing difference in mean MLWHFQ scores for structured telephone support interventions versus usual care, by outcome timing. This figure is described in ‘Quality of Life or Function: Structured Telephone Support’ of the main report: “Our meta-analysis (two trials) found no difference in MLWHFQ scores at 3 months among patients receiving STS and those receiving usual care (WMD, -3.78; 95% CI, -10.39 to 2.83) or at 6 months (WMD, -7.14; 95% CI, -21.07 to 6.78). The trial by Wakefield and colleagues includes STS delivered by standard telephone and also by videophone (without telemonitoring); both STS modes were compared with usual care.”

Figure E9 All-cause readmissions for home-visiting programs compared with usual care, by intensity and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-9 displays a forest plot showing all-cause readmissions for home-visiting programs versus usual care, by intensity and outcome timing. This figure is described in ‘KQ4a Intensity: Home-visiting Program: All-Cause Readmissions’ of the main report: “Eight trials of either low or medium risk of bias reported all-cause readmissions; among these, we rated five as high intensity and three as medium intensity. Our subgroup analyses for reduction in all-cause readmissions found that higher intensity home home-visiting programs reduced all-cause readmissions at 30-days while lower intensity interventions did not. This is also discussed in KQ1. At outcome timings over 3 to 6 months, our analysis stratified by intensity found no significant difference between in high-intensity and medium-intensity. Our ability to make a definitive conclusion at outcome timings over 3 to 6 months is limited by lack of precision (wide and overlapping CIs); too few trials reported outcomes at the same timepoint to permit us to assess adequately whether efficacy of home-visiting programs differed by intensity.” Specifically, one medium-intensity trial found no difference in all-cause readmissions at 30 days (RR, 0.89; 95% CI, 0.43 to 1.85). Over 3 to 6 months our meta-analysis found no differences in medium-intensity (2 trials; RR, 0.79; 95% CI, 0.62 to 1.02) or high-intensity trials (5 trials, RR, 0.75; 95% CI, 0.63, 0.88). A difference was found, however, in a high-intensity trial at 30 days (RR, 0.34; 95% CI, 0.19, 0.62).

Figure E10 Mortality for home-visiting programs compared with usual care, by intensity and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-10 displays a forest plot showing mortality for home-visiting programs versus usual care, by intensity and outcome timing. This figure is described in ‘KQ4a Intensity: Home-visiting programs: Mortality’ of the main report: “Eight medium or low risk-of-bias trials reported mortality, among these, we rated four as high intensity and four as medium intensity. Our subgroup analyses for reduction in mortality found no significant difference in intensity at any outcome timepoint. As with all-cause readmissions, however, lack of precision (wide and overlapping CIs) limited our ability to make any definitive conclusions.” Specifically, there were no differences in the risk of mortality between patients receiving home-visiting programs and those receiving usual care found: in one high-intensity trial at 30 days (RR, 1.03; 95% CI, 0.15, 7.16) and four high intensity trials over 3 to 6 months (RR, 0.67; 95% CI, 0.44 to 1.03); and four medium-intensity trials over 3 to 6 months (RR, 0.80; 95% CI, 0.52 to 1.23).

Figure E11 All-cause readmissions for structured telephone support interventions compared with usual care, by intensity and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-11 displays a forest plot showing all-cause readmissions for structured telephone support interventions versus usual care, by intensity and outcome timing. This figure is described in ‘KQ4a Intensity: Structured Telephone Support: All-Cause Readmissions’ of the main report: “In KQ 1 we found that STS interventions had no efficacy in decreasing all-cause readmissions at any timepoint. Our analysis stratified by intensity found no significant difference between in high-intensity and medium-intensity trials at any point. Confidence intervals were wide and overlapped in all cases. One high-intensity trial reported a significant reduction in all-cause readmissions at 6 months (RR, 0.56; 95% CI, 0.40 to 0.79).”

Figure E12 Mortality for structured telephone support interventions compared with usual care, by intensity and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-12 displays a forest plot showing mortality for structured telephone support interventions versus usual care, by intensity and outcome timing. This figure is described in ‘KQ4a Intensity: Structured Telephone Support: Mortality’ of the main report: “We found no significant difference in reducing mortality rates between high-intensity and medium-intensity trials at any timepoint). Confidence intervals were wide and overlapped in all cases.” Specifically, there were no differences in the risk of mortality between patients receiving structured telephone support and those receiving usual care found: in three high-intensity trials over 3 to 6 months (RR, 0.73; 95% CI, 0.52 to 1.02) and 6 medium-intensity trials over 3 to 6 months (RR, 0.79; 95% CI, 0.55 to 1.13).

Figure E13 All-cause readmissions for home-visiting programs compared with usual care, by delivery personnel and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-13 displays a forest plot showing all-cause readmissions for home-visiting programs versus usual care, by delivery personnel and outcome timing. This figure is described further in ‘KQ4b Delivery Personnel: Home-visiting Programs: All-cause Readmissions’ of the main report: “Seven trials reported all-cause readmissions rates. Variation at 30 days was insufficient to determine whether delivery personnel influenced reductions in all-cause readmissions; over 3 to 6 months, our subgroup analyses found no significant difference by delivery personnel. However, our ability to make definitive conclusions was limited by lack of precision and disparity in when outcomes were measured.” No differences in the risk of all-cause readmissions were found over 3 to 6 months with multidisciplinary teams (4 trials; RR, 0.76, 95% CI, 0.63 to 0.90); nurse care (2 trials: RR, 0.84; 95% CI, 0.61 to 1.16); or pharmacist care (single trial: RR, 0.83; 95% CI, 0.59 to 1.17).

Figure E14 Mortality for home-visiting programs compared with usual care, by delivery personnel and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-14 displays a forest plot showing mortality for home-visiting programs versus usual care, by delivery personnel and outcome timing. This figure is described in ‘KQ4b Delivery Personnel: Home-visiting Programs: Mortality’ of the main report: “Seven home-visiting trials reported mortality. Variation at 30 days was insufficient to determine whether delivery personnel influenced reductions in mortality. At outcome timings over 3 to 6 months, our subgroup analysis found no significant differences by delivery personnel.” Specifically, our subgroup analysis found no differences in the risk of mortality when home-visiting programs were delivered by a nurse at 30 days (single trial: RR, 1.03; 95% CI 1.03 to 7.16) or over 3 to 6 months when delivered by a multidisciplinary team (3 trials: RR, 0.63; 95% CI, 0.40 to 0.99); a nurse (4 trials: RR, 0.66; 95% CI, 0.44 to 0.99); or a pharmacist (single trial: RR, 1.21; 95% CI, 0.74 to 1.96).

Figure E15 All-cause readmission for structured telephone support interventions compared with usual care, by delivery personnel and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-15 displays a forest plot showing all-cause readmission for structured telephone support interventions versus usual care, by delivery personnel and outcome timing. This figure is described in ‘KQ4b Delivery Personnel: Structured Telephone Support: All-cause Readmissions’ of the main report: “Our subgroup analyses for all-cause readmissions found no significant differences by delivery personnel. Delivery personnel did not vary much at each timepoint; confidence intervals were wide and overlapped. Overall, of 10 trials, two trials found a statistically significant reduction in all-cause readmissions; one intervention was delivered by a nurse and one was delivered by a pharmacist.” Specifically, there were no differences in risk of all-cause readmissions when structured telephone support was delivered by a nurse at 30 days (single trial: RR, 0.80; 95% CI, 0.38 to 1.65) or over 3 to 6 months when delivered by a case manager (single trial: RR, 1.10; 95% CI, 0.79 to 1.53); a nurse (6 trials: RR, 0.94; 95% CI, 0.77 to 1.15); or pharmacist (single trial: RR, 0.58; 95% CI, 0.35 to 0.95).

Figure E16 Mortality for structured telephone support interventions compared with usual care, by delivery personnel and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-16 displays a forest plot showing mortality for structured telephone support interventions compared with usual care, by delivery personnel and outcome timing. This figure is described in ‘KQ4b Delivery Personnel: Structured Telephone Support: Mortality’ in the main report: “Our subgroup analysis for mortality found no significant differences by delivery personnel. Delivery personnel varied little at each time-point.” Specifically, there were no differences in risk of mortality when structured telephone support was delivered by a case manager (single trial: RR, 0.90; 95% CI, 0.44 to 1.82); nurse (6 trials: RR, 0.78; 95% CI, 0.59 to 1.03); or pharmacist (2 trials: RR, 0.45; 95% CI, 0.19 to 1.05) over 3 to 6 months.

Figure E17 All-cause readmission for structured telephone support interventions compared with usual care, by method of communication and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-17 displays a forest plot showing all-cause readmission for structured telephone support interventions versus usual care, by method of communication and outcome timing. This figure is described in ‘KQ4c Method of Communication: Structured Telephone Support’ of the main report: “Our subgroup analysis found no difference in efficacy for either all-cause readmissions or mortality among trials with a face-to-face component compared with those with primarily the telephone contact; confidence intervals were wide and overlapped. Our ability to make definitive conclusions was limited by lack of precision (wide, overlapping CIs) and dissimilar points for measuring outcomes. One STS intervention directly compared two modes of delivery: standard telephone support and videophone (without telemonitoring technology), along with usual care. There was no difference in all-cause readmissions in the three groups at outcome timings over 3 to 6 months.” Specifically, there were no risk differences found with: telephone only at 30 days (single trial: RR, 0.80; 95% CI, 0.38 to 1.65); telephone plus face-to-face at 3 to 6 months (3 trials: RR, 0.95; 95% CI, 0.95 to 1.31); and telephone only at 3 to 6 months (5 trials: RR, 0.91; 95% CI, 0.72 to 1.15).

Figure E18 Mortality for structured telephone support interventions, by method of communication and outcome timing: Meta-analysis and forest plot of individual trials

Figure E-18 displays a forest plot showing mortality for structured telephone support interventions, by method of communication and outcome timing. This figure is described in ‘KQ4c Method of Communication: Structured Telephone Support of the main report: Our subgroup analysis found no difference in efficacy for either all-cause readmissions or mortality among trials with a face-to-face component compared with those with primarily the telephone contact; confidence intervals were wide and overlapped. Our ability to make definitive conclusions was limited by lack of precision (wide, overlapping CIs) and dissimilar points for measuring outcomes. One STS intervention directly compared two modes of delivery: standard telephone support and videophone (without telemonitoring technology), along with usual care. There was no difference in all-cause readmissions in the three groups at outcome timings over 3 to 6 months.” Specifically, there were no risk differences found with: telephone plus face-to-face at 3 to 6 months (6 trials: RR, 0.66; 95% CI, 0.48 to .90); telephone only at 3 to 6 months (3 trials: RR, 0.80; 95% CI, 0.51 to 1.24); and videophone at 6 months (single trial; RR, 1.30; 95% CI, 0.57 to 2.95).

## Appendix E References

1 Wakefield BJ, Holman JE, Ray A, et al. Outcomes of a home telehealth intervention for patients with heart failure. J Telemed Telecare. 2009;15(1):46-50. [pmid: 19139220].
2 Naylor MD, Brooten DA, Campbell RL, et al. Transitional care of older adults hospitalized with heart failure: a randomized, controlled trial. J Am Geriatr Soc. May. 2004;52(5):675-84. [pmid: 15086645].