# Risk of Bias Assessments for Included Studies

Table D1 Risk of bias evaluations and rationale

## Appendix D References

1 Albert NM, Buchsbaum R, Li J. Randomized study of the effect of video education on heart failure healthcare utilization, symptoms, and self-care behaviors. Patient Educ Couns. Dec. 2007;69(1-3):129-39. [pmid: 17913440].
2 Aldamiz-Echevarría Iraúrgui B, Muñiz J, Rodríguez-Fernández JA, et al. Randomized controlled clinical trial of a home care unit intervention to reduce readmission and death rates in patients discharged from hospital following admission for heart failure. Rev Esp Cardiol. 2007;(9):914-22. CN-00612373. [pmid: 17915147].
3 Angermann CE, Stork S, Gelbrich G, et al. Mode of action and effects of standardized collaborative disease management on mortality and morbidity in patients with systolic heart failure: the Interdisciplinary Network for Heart Failure (INH) study. Circ Heart Fail. Jan. 2012;5(1):25-35. [pmid: 21956192].
4 Barth V. A nurse-managed discharge program for congestive heart failure patients: outcomes and costs. Home Health Care Manag Pract. 2001;(6):436-43. CN-00773514.
5 Benatar D, Bondmass M, Ghitelman J, et al. Outcomes of chronic heart failure. Arch Intern Med. Feb. 10. 2003;163(3):347-52. [pmid: 12578516].
6 Lopez Cabezas C, Falces Salvador C, Cubi Quadrada D, et al. Randomized clinical trial of a postdischarge pharmaceutical care program vs regular follow-up in patients with heart failure. Farm Hosp. Nov-Dec. 2006;30(6):328-42. [pmid: 17298190].
7 Dar O, Riley J, Chapman C, et al. A randomized trial of home telemonitoring in a typical elderly heart failure population in North West London: results of the Home-HF study. Eur J Heart Fail. 2009;(3):319-25. CN-00681894. [pmid: 19174529].
8 Davis KK, Mintzer M, Dennison Himmelfarb CR, et al. Targeted intervention improves knowledge but not self-care or readmissions in heart failure patients with mild cognitive impairment. Eur J Heart Fail. Sep. 2012;14(9):1041-9. [pmid: 22736737].
9 Dendale P, De Keulenaer G, Troisfontaines P, et al. Effect of a telemonitoring-facilitated collaboration between general practitioner and heart failure clinic on mortality and rehospitalization rates in severe heart failure: the TEMA-HF 1 (TElemonitoring in the MAnagement of Heart Failure) study. Eur J Heart Fail. Mar. 2012;14(3):333-40. [pmid: 22045925].
10 Domingues FB, Clausell N, Aliti GB, et al. Education and telephone monitoring by nurses of patients with heart failure: randomized clinical trial. Arq Bras Cardiol. Mar. 2011;96(3):233-9. [pmid: 21308343].
11 Ducharme A, Doyon O, White M, et al. Impact of care at a multidisciplinary congestive heart failure clinic: a randomized trial. CMAJ. Jul. 5. 2005;173(1):40-5. [pmid: 15997043].
12 Duffy JR, Hoskins LM, Dudley-Brown S. Improving outcomes for older adults with heart failure: a randomized trial using a theory-guided nursing intervention. J Nurs Care Qual. Jan-Mar. 2010;25(1):56-64. [pmid: 19512945].
13 Dunagan WC, Littenberg B, Ewald GA, et al. Randomized trial of a nurse-administered, telephone-based disease management program for patients with heart failure. J Card Fail. Jun. 2005;11(5):358-65. [pmid: 15948086].
14 Ekman I, Andersson B, Ehnfors M, et al. Feasibility of a nurse-monitored, outpatient-care programme for elderly patients with moderate-to-severe, chronic heart failure. Eur Heart J. Aug. 1998;19(8):1254-60. [pmid: 9740348].
15 Goldberg LR, Piette JD, Walsh MN, et al. Randomized trial of a daily electronic home monitoring system in patients with advanced heart failure: the Weight Monitoring in Heart Failure (WHARF) trial. Am Heart J. Oct. 2003;146(4):705-12. [pmid: 14564327].
16 Holland R, Brooksby I, Lenaghan E, et al. Effectiveness of visits from community pharmacists for patients with heart failure: HeartMed randomised controlled trial. BMJ. May. 26. 2007;334(7603):1098. [pmid: 17452390].
17 Jaarsma T, Halfens R, Huijer Abu-Saad H, et al. Effects of education and support on self-care and resource utilization in patients with heart failure. Eur Heart J. May. 1999;20(9):673-82. [pmid: 10208788].
18 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. Nov. 2001;39(11):1234-45. [pmid: 11606877].
19 Jerant AF, Azari R, Martinez C, et al. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Serv Q. 2003;22(1):1-20. [pmid: 12749524].
20 Kasper EK, Gerstenblith G, Hefter G, et al. A randomized trial of the efficacy of multidisciplinary care in heart failure outpatients at high risk of hospital readmission. J Am Coll Cardiol. Feb. 6. 2002;39(3):471-80. [pmid: 11823086].
21 Kimmelstiel C, Levine D, Perry K, et al. Randomized, controlled evaluation of short- and long-term benefits of heart failure disease management within a diverse provider network: the SPAN-CHF trial. Circulation. Sep. 14. 2004;110(11):1450-5. [pmid: 15313938].
22 Koelling TM, Johnson ML, Cody RJ, et al. Discharge education improves clinical outcomes in patients with chronic heart failure. Circulation. Jan. 18. 2005;111(2):179-85. [pmid: 15642765].
23 Kwok T, Lee J, Woo J, et al. A randomized controlled trial of a community nurse-supported hospital discharge programme in older patients with chronic heart failure. J Clin Nurs. Jan. 2008;17(1):109-17. [pmid: 18088263].
24 Laramee AS, Levinsky SK, Sargent J, et al. Case management in a heterogeneous congestive heart failure population: a randomized controlled trial. Arch Intern Med. Apr. 14. 2003;163(7):809-17. [pmid: 12695272].
25 Linne AB, Liedholm H. Effects of an interactive CD-program on 6 months readmission rate in patients with heart failure - a randomised, controlled trial [NCT00311194]. BMC Cardiovasc Disord. 2006;6:30. [pmid: 16796760].
26 Liu MH, Wang CH, Huang YY, et al. Edema index-guided disease management improves 6-month outcomes of patients with acute heart failure. Int Heart J. 2012;53(1):11-7. [pmid: 22398670].
27 McDonald K, Ledwidge M, Cahill J, et al. Elimination of early rehospitalization in a randomized, controlled trial of multidisciplinary care in a high-risk, elderly heart failure population: the potential contributions of specialist care, clinical stability and optimal angiotensin-converting enzyme inhibitor dose at discharge. Eur J Heart Fail. Mar. 2001;3(2):209-15. [pmid: 11246059].
28 McDonald K, Ledwidge M, Cahill J, et al. Heart failure management: multidisciplinary care has intrinsic benefit above the optimization of medical care. J Card Fail. Jun. 2002;8(3):142-8. [pmid: 12140806].
29 Ledwidge M, Barry M, Cahill J, et al. Is multidisciplinary care of heart failure cost-beneficial when combined with optimal medical care?. Eur J Heart Fail. 2003;(3):381-9. CN-00456908. [pmid: 12798838].
30 Naylor MD, Brooten DA, Campbell RL, et al. Transitional care of older adults hospitalized with heart failure: a randomized, controlled trial. J Am Geriatr Soc. May. 2004;52(5):675-84. [pmid: 15086645].
31 Nucifora G, Albanese MC, De Biaggio P, et al. Lack of improvement of clinical outcomes by a low-cost, hospital-based heart failure management programme. J Cardiovasc Med (Hagerstown). Aug. 2006;7(8):614-22. [pmid: 16858241].
32 Oddone EZ, Weinberger M, Giobbie-Hurder A, et al. Enhanced access to primary care for patients with congestive heart failure. Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. Eff Clin Pract. Sep-Oct. 1999;2(5):201-9. [pmid: 10623052].
33 Pekmezaris R, Mitzner I, Pecinka KR, et al. The impact of remote patient monitoring (telehealth) upon Medicare beneficiaries with heart failure. Telemed J E Health. Mar. 2012;18(2):101-8. [pmid: 22283360].
34 Pugh LC, Havens DS, Xie S, et al. Case management for elderly persons with heart failure: the quality of life and cost outcomes. Medsurg Nurs. 2001;10(2):71-8.
35 Rainville EC. Impact of pharmacist interventions on hospital readmissions for heart failure. Am J Health Syst Pharm. Jul. 1. 1999;56(13):1339-42. [pmid: 10683133].
36 Rich MW, Vinson JM, Sperry JC, et al. Prevention of readmission in elderly patients with congestive heart failure: results of a prospective, randomized pilot study. J Gen Intern Med. Nov. 1993;8(11):585-90. [pmid: 8289096].
37 Rich MW, Beckham V, Wittenberg C, et al. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med. Nov. 2. 1995;333(18):1190-5. [pmid: 7565975].
38 Riegel B, Carlson B, Kopp Z, et al. Effect of a standardized nurse case-management telephone intervention on resource use in patients with chronic heart failure. Arch Intern Med. Mar. 25. 2002;162(6):705-12. [pmid: 11911726].
39 Riegel B, Carlson B. Is individual peer support a promising intervention for persons with heart failure?. J Cardiovasc Nurs. May-Jun. 2004;19(3):174-83. [pmid: 15191260].
40 Riegel B, Carlson B, Glaser D, et al. Randomized controlled trial of telephone case management in Hispanics of Mexican origin with heart failure. J Card Fail. Apr. 2006;12(3):211-9. [pmid: 16624687].
41 Schwarz KA, Mion LC, Hudock D, et al. Telemonitoring of heart failure patients and their caregivers: a pilot randomized controlled trial. Prog Cardiovasc Nurs. Winter. 2008;23(1):18-26. [pmid: 18326990].
42 Sethares KA, Elliott K. The effect of a tailored message intervention on heart failure readmission rates, quality of life, and benefit and barrier beliefs in persons with heart failure. Heart Lung. Jul-Aug. 2004;33(4):249-60. [pmid: 15252415].
43 Stewart S, Pearson S, Horowitz JD. Effects of a home-based intervention among patients with congestive heart failure discharged from acute hospital care. Arch Intern Med. May. 25. 1998;158(10):1067-72. [pmid: 9605777].
44 Stewart S, Marley JE, Horowitz JD. Effects of a multidisciplinary, home-based intervention on unplanned readmissions and survival among patients with chronic congestive heart failure: a randomised controlled study. Lancet. Sep. 25. 1999;354(9184):1077-83. [pmid: 10509499].
45 Stromberg A, Martensson J, Fridlund B, et al. Nurse-led heart failure clinics improve survival and self-care behaviour in patients with heart failure: results from a prospective, randomised trial. Eur Heart J. Jun. 2003;24(11):1014-23. [pmid: 12788301].
46 Thompson DR, Roebuck A, Stewart S. Effects of a nurse-led, clinic and home-based intervention on recurrent hospital use in chronic heart failure. Eur J Heart Fail. Mar. 16. 2005;7(3):377-84. [pmid: 15718178].
47 Triller DM, Hamilton RA. Effect of pharmaceutical care services on outcomes for home care patients with heart failure. Am J Health Syst Pharm. Nov. 1. 2007;64(21):2244-9. [pmid: 17959576].
48 Tsuyuki RT, Fradette M, Johnson JA, et al. A multicenter disease management program for hospitalized patients with heart failure. J Card Fail. Dec. 2004;10(6):473-80. [pmid: 15599837].
49 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemed J E Health. Oct. 2008;14(8):753-61. [pmid: 18954244].
50 Wakefield BJ, Holman JE, Ray A, et al. Outcomes of a home telehealth intervention for patients with heart failure. J Telemed Telecare. 2009;15(1):46-50. [pmid: 19139220].
51 Woodend AK, Sherrard H, Fraser M, et al. Telehome monitoring in patients with cardiac disease who are at high risk of readmission. Heart Lung. Jan-Feb. 2008;37(1):36-45. [pmid: 18206525].