# Characteristics of Interventions

Table C1 Intervention components for primarily educational interventions

Author, Year | Risk of Bias | Intensity | Primary Mode of Delivery | Delivery Personnel | Self-Care Management Education/Promotion | Weight-Monitoring Education or Promotion | Diet/Sodium Restriction Education or Promotion | Promotion of Medication Adherence | Exercise Education or Promotion | Other or Unspecified HF Education | Medication Reconciliation | Setting/Timing of Education a | Planned Telephone Follow-up Post d/c | Timing of First Phone or TM Follow-up (Days) | Phone Follow-up Conducted by Same Personnel Delivering Inpatient Intervention Component | Patient Phone Hotline | Timing of First Clinic Visit Post d/c
Albert et al., 2007^1^ | High | Low | Video | NA | x | x | x | x | x | - | - | Post-d/c | - | - | - | - | -
Koelling et al., 2005^2^ | Low | Low | Face-to-Face | Nurse | x | x | x | x | - | x | - | Pre-d/c | - | - | - | - | -
Linne et al., 2006^3^ | Unclear | Low | Interactive CD-ROM | NA | x | x | - | x | x | - | - | Both | - | - | - | - | -
Nucifora et al., 2006^4^ | Med | Med. | Face-to-Face | Nurse | x | x | x | x | - | - | - | Both | x | > 7 days | x | x | > 14 days

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention

a Both = both pre- and post-d/c.

Abbreviations: CD-ROM = compact disk read-only memory; d/c = discharge; HF = heart failure; MDS = multidisciplinary; Med = Medium; NA = not applicable.

Table C2 Intervention components for home visiting interventions (Part 1)

Author, Year | Risk of Bias | Intensity | Primary Mode of Delivery | Delivery Personnel | Self-Care Management Education/Promotion | Weight-Monitoring Education or Promotion | Diet/Sodium Restriction Education or Promotion | Promotion of Medication Adherence | Exercise Education or Promotion | Other or Unspecified HF Education | Medication Reconciliation | Setting/Timing of Education^a^
Aldamiz-Echevarría Iraúrgui et al., 2007^5^ | Med | High | Face-to-Face | MDS | x | x | x | X | - | x | x | Post-d/c
Holland et al., 2007^6^ | Med | Med | Face-to-Face | Pharm. | x | x | x | X | x | x | x | Post-d/c
Jaarsma et al., 1999^7^ | Med | Med | Face-to-Face | Nurse | x | - | x | X | - | x | - | Both
Kimmelstiel et al., 2004^8^ | Med | Med | Face-to-Face | Nurse | x | x | x | X | - | x | - | Post-d/c
Kwok et al., 2007^9^ | Med | High | Face-to-Face | Nurse | x | - | x | X | x | - | x | Both
Naylor et al., 2004^10^ | Low | High | Face-to-Face | Nurse | x | x | x | X | - | - | x | Both
Pugh et al., 2001^11^ | High | Med | Face-to-Face | Nurse | x | - | - | - | - | x | - | Other
Rich et al., 1993^12^ | Med | High | Face-to-Face | MDS | x | x | x | X | - | x | x | Both
Rich et al., 1995^13^ | Med | High | Face-to-Face | MDS | x | x | x | X | - | x | x | Both
Sethares et al., 2004^14^ | High | Med | Face-to-Face | Nurse | x | x | x | X | - | - | - | Both
Stewart et al., 1998^15^ | Med | Med | Face-to-Face | Nurse | x | - | - | X | - | - | - | Both
Stewart et al., 1999^16^ | Med | Med | Face-to-Face | Nurse | x | x | - | X | x | - | - | Post-d/c (based on assessment)
Thompson et al., 2005^17^ | High | High | Face-to-Face | Nurse | x | x | x | X | x | x | x | Both
Triller et al., 2008^18^ | Unclear | Med | Face-to-Face | Pharm. | x | x | x | X | - | - | x | Post-d/c

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

a Both = both pre- and post-d/c.

Abbreviations: d/c= discharge; HF = heart failure; MDS = multidisciplinary; Med = Medium; Pharm. = Pharmacist

Table C3 Intervention components for home visiting interventions (Part 2)

Author, Year | Risk of Bias | Transition Coach or Coordination Between Inpatient/Outpatient Providers | Individualized D/C Plan | Provider Continuity | Planned Telephone Follow-up Post D/C | Timing of First Phone or TM Follow-up (Days) | Phone Follow-up Conducted by Same Personnel Delivering Inpatient Intervention Component | Series of Structured Calls | Patient Phone Hotline | Timing of First Home Visit (Days)
Aldamiz-Echevarría Iraúrgui et al., 2007^5^ | Med | - | - | - | - | - | - | - | x | 1-2
Holland et al., 2007^6^ | Med | - | - | - | - | - | - | - | - | < 14
Jaarsma et al., 1999^7^ | Med | - | x | - | x | ≤7 | x | - | x | < 7
Kimmelstiel et al., 2004^8^ | Med | - | - | - | - | - | - | x (as needed) | x | < 7
Kwok et al., 2007^9^ | Med | x | - | x | - | - | - | - | x | < 7
Naylor et al., 2004^10^ | Low | x | x | - | - | - | - | - | x | < 1
Pugh et al., 2001^11^ | High | - | x | - | x | - | - | x | - | unclear
Rich et al., 1993^12^ | Med | x | x | - | x (as needed) | - | x | - | x | 1-2
Rich et al., 1995^13^ | Med | x | x | - | x (as needed) | - | x | - | x | 1-2
Sethares et al., 2004^14^ | High | x | - | - | - | - | - | - | - | > 7
Stewart et al., 1998^15^ | Med | x | - | - | - | - | - | - | - | < 7
Stewart et al., 1999^16^ | Med | - | - | - | - | - | - | - | - | > 7
Thompson et al., 2005^17^ | High | x | - | - | - | - | - | - | x | > 7
Triller et al., 2008^18^ | Unclear | - | - | - | - | - | - | - | - | < 7

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

Abbreviations: d/c = discharge; HF = heart failure; hrs = hours; Med = Medium; TM = telemonitoring.

Table C4 Intervention components for home visiting interventions (Part 3)

Author, Year | Risk of Bias | Number of Scheduled Home Visits | Medication Reconciliation During Home Visit | Unspecified HF Education/Promotion During Home Visit | Symptom Checklist or Clinical Assessment During Home Visit (e.g. History, Symptoms) | Physical Exam During Home Visit | Home Visiting Personnel Coordinates Care or Collaborates With Outpatient Provider | Clinic Personnel On-Call/Available for Acute Symptom Management (Outside of Scheduled Appt) | Medication Optimization; Pre-D/C or During Intervention
Aldamiz-Echevarría Iraúrgui et al., 2007^5^ | Med | 2 to 3 | x | x | x | x | - | - | x
Holland et al., 2007^6^ | Med | 2 | x | x | x | - | x | - | x
Jaarsma et al., 1999^7^ | Med | 1 | - | x | - | - | - | - | -
Kimmelstiel et al., 2004^8^ | Med | 1 | x | x | x | - | x | - | -
Kwok et al., 2007^9^ | Med | 6^a^ | x | - | x | x | x | - | x
Naylor et al., 2004^10^ | Low | 8 | x | x | x | - | x | - | -
Pugh et al., 2001^11^ | High | 1^b^ | x | x | - | - | - | - | -
Rich et al., 1993^12^ | Med | >3 | x | x | - | x | - | - | x
Rich et al., 1995^13^ | Med | >3 | x | x | - | x | - | - | x
Sethares et al., 2004^14^ | High | 2 to 3 | x | - | - | - | - | - | -
Stewart et al., 1998^15^ | Med | 1 | x | x | - | - | x | - | -
Stewart et al., 1999^16^ | Med | 1 | - | x | x | x | x | - | -
Thompson et al., 2005^17^ | High | 1 | - | x | x | x | - | x | x
Triller et al., 2008^18^ | Unclear | other | x | x | - | - | x | - | x

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

a In Kwok et al., an average of 6 visits took place, including the initial inpatient visit, but more visits were scheduled for individual patients if needed.9

b Additional visits were scheduled at home or in a clinic based on individual need.19

Abbreviations: appt = appointment; d/c = discharge; HF = heart failure; Med = Medium.

Table C5 Intervention components for clinic-based interventions (Part 1)

Author, Year | Risk of Bias | Intensity | Primary Mode of Delivery | Delivery Personnel | Self-Care Management Education/Promotion | Weight-Monitoring Education or Promotion | Diet/Sodium Restriction Education or Promotion | Promotion of Medication Adherence | Other or Unspecified HF Education | Medication Reconciliation | Setting/Timing of Education^a^ | Transition Coach or Coordination Between Inpatient/Outpatient Providers
Ekman et al., 1998^20^ | Med | Med | Face-to-Face | Nurse | - | x | - | x | - | - | Post-d/c | -
Stromberg et al., 2003^21^ | Low | Med | Face-to-Face | Nurse | x | x | x | x | - | - | Post-d/c | -
Ducharme et al., 2005^22^ | Low | High | Face-to-Face | MDS | x | x | x | x | x | x | Post-d/c | -
Kasper et al., 2002^23^ | Low | High | Face-to-Face | MDS | x | - | - | - | x | - | Post-d/c | -
Liu et al., 2012^24^ | Low | High | Face-to-Face | MDS | x | - | - | x | - | x | Both | x
McDonald et al., 2001^25^; McDonald et al., 2002^26^; Ledwidge et al., 2003^27^ | Unclear | High | Face-to-Face | MDS | - | x | x | x | - | - | Both | -
Oddone et al., 1999^28^ | Med | Med | Face-to-Face | PCP | - | - | - | - | - | - | Pre-d/c | -

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

a Both = both pre- and post-d/c.

Abbreviations: d/c= discharge; HF = heart failure; MDS = multidisciplinary; Med = Medium; PCP = primary care (physician, nurse in clinic).

Table C6 Intervention components for clinic-based interventions (Part 2)

Author, Year | Risk of Bias | Individualized D/C Plan | Provider Continuity | Medications Adjusted During Inpatient Stay | Planned Telephone Follow-Up Post D/C | Timing of First Phone or TM Follow-Up (Days) | Phone Follow-up Conducted by Same Personnel Delivering Inpatient Intervention Component | Series of Structured Calls | Patient Phone Hotline | Timing of First Clinic Visit Post D/C (Days) | Consultation With a Dietician | Clinic Personnel On-Call/Available for Acute Symptom Management (Outside of Scheduled Appt) | Cardiac Rehab Component | Clinical Pharmacist Visit/Consultation | Medication Optimization; Pre-D/C or During Intervention
Ekman et al., 1998^20^ | Med | - | - | - | x | <7 | - | - | x | NR | - | x | - | - | -
Stromberg et al., 2003^21^ | Low | - | - | - | - | - | - | - | - | > 14 | x | x | x | x | -
Ducharme et al., 2005^22^ | Low | - | - | - | x | ≤ 3 | - | x | - | ≤ 14 | x | x | - | x | x
Kasper et al., 2002^23^ | Low | - | - | - | x | ≤ 7 | - | x | x | Unclear | - | - | - | - | x
Liu et al., 2012^24^ | Low | x | - | - | x | ≤ 7 | unclear | x | x | ≤ 7 | x | x | - | - | x
McDonald et al., 2001^25^; McDonald et al., 2002^26^; Ledwidge et al., 2003^27^ | Unclear | - | - | - | x | <7 | x | x | x | <14 | x | x | - | - | -
Oddone et al., 1999^28^ | Med | x | - | - | x | 1-2 | - | - | - | <7 | - | - | - | - | -

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

Abbreviations: d/c= discharge; hrs = hours; Med = Medium; NR = not reported; TM= telemonitoring.

Table C7 Intervention components for other interventions

Author, Year | Specific Type of Intervention | Risk of Bias | Intensity | Primary Mode of Delivery | Delivery Personnel | Self-Care Management Education/Promotion | Weight-Monitoring Education or Promotion | Diet/sodium Restriction Education or Promotion | Promotion of Medication Adherence | Exercise Education or Promotion | Other or Unspecified HF Education | Medication Reconciliation | Setting/Timing of Education a | Planned Telephone Follow-up Post D/C | Timing of First Phone or TM Follow-up (Days) | Phone Follow-up Conducted by Same Personnel Delivering Inpatient Intervention Component
Davis et al., 2012^29^ | Other (Cognitive Training) | Med | Med | Face-to-Face | Nurse | x | x | x | x | - | - | - | Both | x | ≤ 7 | x
Riegel et al., 2004^30^ | Other (Peer Support) | High | Med | Face-to-Face; Telephone | Peer Support | x | x | x | x | - | - | - | Post-d/c | x | <7 | -

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

a Both = both pre- and post-d/c.

Abbreviations: d/c= discharge; HF = heart failure; hrs = hours; Med = Medium.

Table C8 Intervention components for STS interventions (Part 1)

Author, Year | Risk of Bias | Intensity | Primary Mode of Delivery | Delivery Personnel | Self-care Management Education/Promotion | Weight-Monitoring Education or Promotion | Diet/Sodium Restriction Education or Promotion | Promotion of Medication Adherence | Exercise Education or promotion | Other or Unspecified HF Education | Medication Reconciliation | Setting/Timing of Education a | Transition Coach or Coordination Between Inpatient/Outpatient Providers
Angermann et al., 2011^31^ | Med | High | Telephone; Face-to-Face | Nurse | x | x | x | X | x | x | - | Both | x
Barth et al., 2001^32^ | High | Low | Telephone | Nurse | x | x | x | X | x | - | x | Post-d/c | -
Cabezas et al., 2006^33^ | Med | Med | Telephone; Face-to-Face | Pharmacist | - | - | x | X | - | x | - | Both | -
Domingues et al., 2010^34^ | Med | Low | Telephone | Nurse | x | x | - | X | x | x | - | Post-d/c | -
Duffy et al., 2010^35^ | High | Med | Face-to-Face; Telephone | Nurse | x | x | - | X | - | x | - | Post-d/c | -
Dunagan et al., 2005^36^ | Med | High | Telephone | Nurse | x | x | x | X | x | - | x | Post-d/c | -
Jerant et al., 2001^37^; Jerant et al., 2003^38^ | High | Med | Videophone; Telephone | Nurse | x | x | x | X | - | - | - | Both | -
Laramee et al., 2003^39^ | Med | High | Telephone; Face-to-Face | Nurse-Case Manager | x | x | x | X | - | - | x | Both | x
Rainville et al., 1999^40^ | Med | Med | Telephone; Face-to-Face | Pharmacist | - | x | - | X | - | x | - | Both | x
Riegel et al., 2002^41^ | Med | Med | Telephone | Nurse | x | - | x | X | - | x | x | Post-d/c | -
Riegel et al., 2006^42^ | Med | Med | Telephone | Nurse | x | - | x | X | - | x | | Post-d/c | -
Tsuyuki et al., 2004^43^ | Med | High | Telephone | Nurse | x | x | x | X | x | x | x | Both | -
Wakefield et al., 2008^44^; Wakefield et al., 2009^45^ | Med | Med | Telephone | Nurse | x | x | x | x | - | - | - | Both | -
Wakefield et al., 2008^44^; Wakefield et al., 2009^45^ | Med | Med | Videophone | Nurse | x | x | x | X | - | - | - | Both | -

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

a Both = both pre- and post-d/c.

Abbreviations: d/c= discharge; HF = heart failure; Med = Medium; STS = Structured Telephone Support.

Table C9 Intervention components for STS interventions (Part 2)

Author, Year | Risk of Bias | Individualized D/C Plan | Medications Adjusted During Inpatient Stay | Planned Telephone Follow-up Post D/C | Timing of First Phone or TM Follow-up (Days) | Phone Follow-up Conducted by Same Personnel Delivering Inpatient Intervention Component | Series of Structured Calls | Patient Phone Hotline | Unspecified HF Education/Promotion During Home Visit | Symptom Checklist or Clinical Assessment During Home Visit (e.g. History, symptoms) | Timing of First Clinic Visit Post D/C (Days) | Clinical Pharmacist Visit/Consultation
Angermann et al., 2011^31^ | Med | - | - | x | ≤ 7 | x | x | x | - | - | - | -
Barth et al., 2001^32^ | High | - | - | x | ≤ 7 | - | x | x | - | - | - | -
Cabezas et al., 2006^33^ | Med | - | - | x | ≤ 7 | unclear | x | - | - | - | ≥ 14 | x
Domingues et al., 2010^34^ | Med | - | - | x | ≤ 7 | - | x | - | - | - | - | -
Duffy et al., 2010^35^ | High | - | - | x | NR | - | x | x | x | x | - | -
Dunagan et al., 2005^36^ | Med | - | - | x | ≤ 7 | - | x | x | - | - | - | -
Jerant et al., 2001^37^; Jerant et al., 2003^38^ | High | - | - | x | > 7 | x | x | x | - | - | - | -
Laramee et al., 2003^39^ | Med | x | - | x | ≤ 7 | x | x | x | - | - | - | -
Rainville et al., 1999^40^ | Med | - | x | x | ≤ 2 | x | x | x | - | - | - | -
Riegel et al., 2002^41^ | Med | - | - | x | ≤ 7 | - | x | - | - | - | - | -
Riegel et al., 2006^42^ | Med | - | - | x | ≤ 7 | - | x | - | - | - | - | -
Tsuyuki et al., 2004^43^ | Med | - | x | x | ≤14 | x | x | - | - | - | - | -
Wakefield et al., 2008^44^; Wakefield et al., 2009^45^ | Med | - | - | x | ≤ 7 | - | x | x | - | - | - | -
Wakefield et al., 2008^44^; Wakefield et al., 2009^45^ | Med | - | - | x | ≤ 7 | - | x | - | - | - | - | -

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

Abbreviations: CND = cannot determine; d/c= discharge; HF = heart failure; hrs = hours; Med = Medium; NR = not reported; STS = Structured Telephone Support; TM= telemonitoring.

Table C10 Intervention components for STS interventions (Part 3)

Author, Year | Risk of Bias | Medication Optimization; Pre-d/c or During Intervention | Timing of First Telehealth Contact After d/c | Intervention Involves Reinforcement of D/C Plan | Prescribed Protocol Used to Guide Assessment And/or Plan | Telehealth Service Coordinates Care With Outpatient Provider | TM Device has Automated Adherence Reminder | Device Can Transmit Vital Signs | Device Can Transmit Symptoms | Device Utilizes Technology That Allows Physical Exam
Angermann et al., 2011^31^ | Med | - | - | - | x | x | - | - | - | -
Barth et al., 2001^32^ | High | x | ≤ 7 | x | x | x | - | - | - | -
Cabezas et al., 2006^33^ | Med | - | - | x | - | - | - | - | - | -
Domingues et al., 2010^34^ | Med | - | - | - | - | - | - | - | - | -
Duffy et al., 2010^35^ | High | - | - | - | x | - | - | - | - | -
Dunagan et al., 2005^36^ | Med | - | - | - | | x | - | - | x | x
Jerant et al., 2001^37^; Jerant et al., 2003^38^ | High | - | > 7 | - | x | - | - | x | x | x
Laramee et al., 2003^39^ | Med | - | ≤ 7 | x | x | x | - | x | - | -
Rainville et al., 1999^40^ | Med | - | | - | - | - | - | - | - | -
Riegel et al., 2002^41^ | Med | - | ≤ 7 | x | x | x | - | - | - | -
Riegel et al., 2006^42^ | Med | - | ≤ 7 | x | x | x (as needed) | - | - | - | -
Tsuyuki et al., 2004^43^ | Med | - | - | - | - | - | - | - | - | -
Wakefield et al., 2008^44^; Wakefield et al., 2009^45^ | Med | - | - | - | - | - | - | - | - | -
Wakefield et al., 2008^44^; Wakefield et al., 2009^45^ | Med | - | ≤ 7 | x | x | x | - | - | x | x

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

Abbreviations: d/c= discharge; Med = Medium; STS = Structured Telephone Support; TM= telemonitoring.

Table C11 Intervention components for telemonitoring interventions (Part 1)

Author, Year | Risk of Bias | Intensity | Primary Mode of Delivery | Delivery Personnel | Self-Management Education/Promotion | Weight-Monitoring Education or Promotion | Diet/Sodium Restriction Education or Promotion | Promotion of Medication Adherence | Exercise Education or Promotion | Other or Unspecified HF Education | Medication Reconciliation | Setting/Timing of Education
Benatar et al., 2003^46^ | Unclear | Med | Telephone | Nurse | - | - | X | x | - | - | - | Post-d/c
Dar et al., 2008^47^ | Med | High | Remote monitoring | Nurse | x | - | - | - | - | - | - | Post-d/c
Dendale et al., 2012^48^ | Unclear | Med | Remote monitoring | Nurse | x | x | X | x | x | - | - | Pre-d/c
Goldberg et al., 2003^49^ | Med | High | Remote monitoring | Nurse | x | x | X | - | - | - | - | Pre-d/c
Jerant et al., 2001^37^; Jerant et al., 2003^38^ | High | Med | Videophone, telephone | Nurse | x | x | X | x | - | - | - | Post-d/c
Pekmezaris et al., 2012^50^ | Med | Med | Videophone | Nurse | x | - | X | x | - | - | - | Post-d/c
Schwarz et al., 2008^51^ | Med | Med | Remote monitoring | Nurse | - | x | - | - | - | - | - | Post-d/c
Woodend et al., 2008^52^ | High | High | Remote monitoring and videophone | Nurse | x | - | - | - | - | - | - | Post-d/c

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

Abbreviations: d/c= discharge; HF = heart failure; Med = Medium.

Table C12 Intervention components for telemonitoring interventions (Part 2)

Author, Year | Risk of Bias | Transition Coach or Coordination Between Inpatient/Outpatient Providers | Planned Telephone Follow-up Post d/c | Timing of First Phone or TM Follow-up (Days) | Phone Follow-up Conducted by Same Personnel Delivering Inpatient Intervention Component | Series of Structured Calls | Patient Phone Hotline | Timing of First Home Visit (Days) | Number of Scheduled Home Visits | Symptom Checklist or Clinical Assessment During Home Visit (e.g. History, Symptoms) | Physical Exam During Home Visit | Timing of First Clinic Visit Post D/C (Days)
Benatar et al., 2003^46^ | Unclear | x | - | - | - | - | - | - | - | - | - | -
Dar et al., 2008^47^ | Med | - | - | - | - | - | - | - | - | - | - | -
Dendale et al., 2012^48^ | Unclear | x | x | ≤ 7 | x | - | - | - | - | - | - | > 14
Goldberg et al., 2003^49^ | Med | - | - | - | - | - | - | - | - | - | - | -
Jerant et al., 2001^37^; Jerant et al., 2003^38^ | High | - | x | > 7 | - | x | x | > 7 | other | x | - | -
Pekmezaris et al., 2012^50^ | Med | - | - | - | - | - | - | - | - | - | - | -
Schwarz et al., 2008^51^ | Med | - | - | - | - | - | - | > 7 | 2 to 3 | - | x | -
Woodend et al., 2008^52^ | High | - | - | - | - | - | - | - | - | - | - | -

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

Abbreviations: d/c= discharge; Med = Medium; TM = telemonitoring.

Table C13 Intervention components for telemonitoring interventions (Part 3)

Author, Year | Risk of Bias | Clinic Personnel on-Call/Available for Acute Symptom Management (Outside of Scheduled Appt) | Timing of First Telehealth Contact After D/C (Days) | Intervention Involves Reinforcement of D/C Plan | Prescribed Protocol Used to Guide Assessment and/or Plan | Telehealth Service Coordinates Care With Outpatient Provider | TM Device has Automated Adherence Reminder | Device Can Transmit Vital Signs | Device Can Transmit Symptoms | Device Utilizes Technology that Allows Physical Exam
Benatar et al., 2003^46^ | Unclear | - | > 7 | - | x | - | - | x | - | -
Dar et al., 2008^47^ | Med | - | - | - | x | - | - | x | x | -
Dendale et al., 2012^48^ | Unclear | x | ≤1 | - | - | - | - | x | - | -
Goldberg et al., 2003^49^ | Med | - | > 7 | x | x | x | x | x | x | -
Jerant et al., 2001^37^; Jerant et al., 2003^38^ | High | - | > 7 | - | x | - | - | x | x | x
Pekmezaris et al., 2012^50^ | Med | - | > 7 | - | - | - | - | x | - | x
Schwarz et al., 2008^51^ | Med | - | - | - | x | x | - | x | x | -
Woodend et al., 2008^52^ | High | - | 1-2 | - | x | - | - | x | - | x

Note: x = this component was part of the study intervention and “-” = this component was not included in the intervention.

Abbreviations: appt = appointment; d/c= discharge; hrs = hours; Med = Medium; TM = telemonitoring.

## Appendix C. References

1 Albert NM, Buchsbaum R, Li J. Randomized study of the effect of video education on heart failure healthcare utilization, symptoms, and self-care behaviors. Patient Educ Couns. Dec. 2007;69(1-3):129-39. [pmid: 17913440].
2 Koelling TM, Johnson ML, Cody RJ, et al. Discharge education improves clinical outcomes in patients with chronic heart failure. Circulation. Jan. 18. 2005;111(2):179-85. [pmid: 15642765].
3 Linne AB, Liedholm H. Effects of an interactive CD-program on 6 months readmission rate in patients with heart failure - a randomised, controlled trial [NCT00311194]. BMC Cardiovasc Disord. 2006;6:30. [pmid: 16796760].
4 Nucifora G, Albanese MC, De Biaggio P, et al. Lack of improvement of clinical outcomes by a low-cost, hospital-based heart failure management programme. J Cardiovasc Med (Hagerstown). Aug. 2006;7(8):614-22. [pmid: 16858241].
5 Aldamiz-Echevarría Iraúrgui B, Muñiz J, Rodríguez-Fernández JA, et al. [Randomized controlled clinical trial of a home care unit intervention to reduce readmission and death rates in patients discharged from hospital following admission for heart failure]. Rev Esp Cardiol. 2007;(9):914-22. CN-00612373. [pmid: 17915147].
6 Holland R, Brooksby I, Lenaghan E, et al. Effectiveness of visits from community pharmacists for patients with heart failure: HeartMed randomised controlled trial. BMJ. May. 26. 2007;334(7603):1098. [pmid: 17452390].
7 Jaarsma T, Halfens R, Huijer Abu-Saad H, et al. Effects of education and support on self-care and resource utilization in patients with heart failure. Eur Heart J. May. 1999;20(9):673-82. [pmid: 10208788].
8 Phillips CO, Wright SM, Kern DE, et al. Comprehensive discharge planning with postdischarge support for older patients with congestive heart failure: a meta-analysis. JAMA. Mar. 17. 2004;291(11):1358-67. [pmid: 15026403].
9 Kwok T, Lee J, Woo J, et al. A randomized controlled trial of a community nurse-supported hospital discharge programme in older patients with chronic heart failure. J Clin Nurs. Jan. 2008;17(1):109-17. [pmid: 18088263].
10 Naylor MD, Brooten DA, Campbell RL, et al. Transitional care of older adults hospitalized with heart failure: a randomized, controlled trial. J Am Geriatr Soc. May. 2004;52(5):675-84. [pmid: 15086645].
11 Pugh LC, Havens DS, Xie S, et al. Case management for elderly persons with heart failure: the quality of life and cost outcomes. Medsurg Nurs. 2001;10(2):71-8.
12 Rich MW, Vinson JM, Sperry JC, et al. Prevention of readmission in elderly patients with congestive heart failure: results of a prospective, randomized pilot study. J Gen Intern Med. Nov. 1993;8(11):585-90. [pmid: 8289096].
13 Rich MW, Beckham V, Wittenberg C, et al. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med. Nov. 2. 1995;333(18):1190-5. [pmid: 7565975].
14 Sethares KA, Elliott K. The effect of a tailored message intervention on heart failure readmission rates, quality of life, and benefit and barrier beliefs in persons with heart failure. Heart Lung. Jul-Aug. 2004;33(4):249-60. [pmid: 15252415].
15 Stewart S, Pearson S, Horowitz JD. Effects of a home-based intervention among patients with congestive heart failure discharged from acute hospital care. Arch Intern Med. May. 25. 1998;158(10):1067-72. [pmid: 9605777].
16 Stewart S, Marley JE, Horowitz JD. Effects of a multidisciplinary, home-based intervention on unplanned readmissions and survival among patients with chronic congestive heart failure: a randomised controlled study. Lancet. Sep. 25. 1999;354(9184):1077-83. [pmid: 10509499].
17 Thompson DR, Roebuck A, Stewart S. Effects of a nurse-led, clinic and home-based intervention on recurrent hospital use in chronic heart failure. Eur J Heart Fail. Mar. 16. 2005;7(3):377-84. [pmid: 15718178].
18 Triller DM, Hamilton RA. Effect of pharmaceutical care services on outcomes for home care patients with heart failure. Am J Health Syst Pharm. Nov. 1. 2007;64(21):2244-9. [pmid: 17959576].
19 Blaha C, Robinson JM, Pugh LC, et al. Longitudinal nursing case management for elderly heart failure patients: notes from the field. Nurs Case Manag. Jan-Feb. 2000;5(1):32-6. [pmid: 10855156].
20 Kasper EK, Gerstenblith G, Hefter G, et al. A randomized trial of the efficacy of multidisciplinary care in heart failure outpatients at high risk of hospital readmission. J Am Coll Cardiol. Feb. 6. 2002;39(3):471-80. [pmid: 11823086].
21 Stromberg A, Martensson J, Fridlund B, et al. Nurse-led heart failure clinics improve survival and self-care behaviour in patients with heart failure: results from a prospective, randomised trial. Eur Heart J. Jun. 2003;24(11):1014-23. [pmid: 12788301].
22 Ducharme A, Doyon O, White M, et al. Impact of care at a multidisciplinary congestive heart failure clinic: a randomized trial. CMAJ. Jul. 5. 2005;173(1):40-5. [pmid: 15997043].
23 Ekman I, Andersson B, Ehnfors M, et al. Feasibility of a nurse-monitored, outpatient-care programme for elderly patients with moderate-to-severe, chronic heart failure. Eur Heart J. Aug. 1998;19(8):1254-60. [pmid: 9740348].
24 Liu MH, Wang CH, Huang YY, et al. Edema index-guided disease management improves 6-month outcomes of patients with acute heart failure. Int Heart J. 2012;53(1):11-7. [pmid: 22398670].
25 McDonald K, Ledwidge M, Cahill J, et al. Elimination of early rehospitalization in a randomized, controlled trial of multidisciplinary care in a high-risk, elderly heart failure population: the potential contributions of specialist care, clinical stability and optimal angiotensin-converting enzyme inhibitor dose at discharge. Eur J Heart Fail. Mar. 2001;3(2):209-15. [pmid: 11246059].
26 McDonald K, Ledwidge M, Cahill J, et al. Heart failure management: multidisciplinary care has intrinsic benefit above the optimization of medical care. J Card Fail. Jun. 2002;8(3):142-8. [pmid: 12140806].
27 Ledwidge M, Barry M, Cahill J, et al. Is multidisciplinary care of heart failure cost-beneficial when combined with optimal medical care?. Eur J Heart Fail. 2003;(3):381-9. CN-00456908. [pmid: 12798838].
28 Oddone EZ, Weinberger M, Giobbie-Hurder A, et al. Enhanced access to primary care for patients with congestive heart failure. Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. Eff Clin Pract. Sep-Oct. 1999;2(5):201-9. [pmid: 10623052].
29 Davis KK, Mintzer M, Dennison Himmelfarb CR, et al. Targeted intervention improves knowledge but not self-care or readmissions in heart failure patients with mild cognitive impairment. Eur J Heart Fail. Sep. 2012;14(9):1041-9. [pmid: 22736737].
30 Riegel B, Carlson B. Is individual peer support a promising intervention for persons with heart failure?. J Cardiovasc Nurs. May-Jun. 2004;19(3):174-83. [pmid: 15191260].
31 Angermann CE, Stork S, Gelbrich G, et al. Mode of action and effects of standardized collaborative disease management on mortality and morbidity in patients with systolic heart failure: the Interdisciplinary Network for Heart Failure (INH) study. Circ Heart Fail. Jan. 2012;5(1):25-35. [pmid: 21956192].
32 Barth V. A nurse-managed discharge program for congestive heart failure patients: outcomes and costs. Home Health Care Manag Pract. 2001;(6):436-43. CN-00773514.
33 Lopez Cabezas C, Falces Salvador C, Cubi Quadrada D, et al. Randomized clinical trial of a postdischarge pharmaceutical care program vs regular follow-up in patients with heart failure. Farm Hosp. Nov-Dec. 2006;30(6):328-42. [pmid: 17298190].
34 Domingues FB, Clausell N, Aliti GB, et al. Education and telephone monitoring by nurses of patients with heart failure: randomized clinical trial. Arq Bras Cardiol. Mar. 2011;96(3):233-9. [pmid: 21308343].
35 Duffy JR, Hoskins LM, Dudley-Brown S. Improving outcomes for older adults with heart failure: a randomized trial using a theory-guided nursing intervention. J Nurs Care Qual. Jan-Mar. 2010;25(1):56-64. [pmid: 19512945].
36 Dunagan WC, Littenberg B, Ewald GA, et al. Randomized trial of a nurse-administered, telephone-based disease management program for patients with heart failure. J Card Fail. Jun. 2005;11(5):358-65. [pmid: 15948086].
37 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. Nov. 2001;39(11):1234-45. [pmid: 11606877].
38 Jerant AF, Azari R, Martinez C, et al. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Serv Q. 2003;22(1):1-20. [pmid: 12749524].
39 Laramee AS, Levinsky SK, Sargent J, et al. Case management in a heterogeneous congestive heart failure population: a randomized controlled trial. Arch Intern Med. Apr. 14. 2003;163(7):809-17. [pmid: 12695272].
40 Rainville EC. Impact of pharmacist interventions on hospital readmissions for heart failure. Am J Health Syst Pharm. Jul. 1. 1999;56(13):1339-42. [pmid: 10683133].
41 Riegel B, Carlson B, Kopp Z, et al. Effect of a standardized nurse case-management telephone intervention on resource use in patients with chronic heart failure. Arch Intern Med. Mar. 25. 2002;162(6):705-12. [pmid: 11911726].
42 Riegel B, Carlson B, Glaser D, et al. Randomized controlled trial of telephone case management in Hispanics of Mexican origin with heart failure. J Card Fail. Apr. 2006;12(3):211-9. [pmid: 16624687].
43 Tsuyuki RT, Fradette M, Johnson JA, et al. A multicenter disease management program for hospitalized patients with heart failure. J Card Fail. Dec. 2004;10(6):473-80. [pmid: 15599837].
44 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemed J E Health. Oct. 2008;14(8):753-61. [pmid: 18954244].
45 Wakefield BJ, Holman JE, Ray A, et al. Outcomes of a home telehealth intervention for patients with heart failure. J Telemed Telecare. 2009;15(1):46-50. [pmid: 19139220].
46 Benatar D, Bondmass M, Ghitelman J, et al. Outcomes of chronic heart failure. Arch Intern Med. Feb. 10. 2003;163(3):347-52. [pmid: 12578516].
47 Dar O, Riley J, Chapman C, et al. A randomized trial of home telemonitoring in a typical elderly heart failure population in North West London: results of the Home-HF study. Eur J Heart Fail. 2009;(3):319-25. CN-00681894. [pmid: 19174529].
48 Dendale P, De Keulenaer G, Troisfontaines P, et al. Effect of a telemonitoring-facilitated collaboration between general practitioner and heart failure clinic on mortality and rehospitalization rates in severe heart failure: the TEMA-HF 1 (TElemonitoring in the MAnagement of Heart Failure) study. Eur J Heart Fail. Mar. 2012;14(3):333-40. [pmid: 22045925].
49 Goldberg LR, Piette JD, Walsh MN, et al. Randomized trial of a daily electronic home monitoring system in patients with advanced heart failure: the Weight Monitoring in Heart Failure (WHARF) trial. Am Heart J. Oct. 2003;146(4):705-12. [pmid: 14564327].
50 Pekmezaris R, Mitzner I, Pecinka KR, et al. The impact of remote patient monitoring (telehealth) upon Medicare beneficiaries with heart failure. Telemed J E Health. Mar. 2012;18(2):101-8. [pmid: 22283360].
51 Schwarz KA, Mion LC, Hudock D, et al. Telemonitoring of heart failure patients and their caregivers: a pilot randomized controlled trial. Prog Cardiovasc Nurs. Winter. 2008;23(1):18-26. [pmid: 18326990].
52 Woodend AK, Sherrard H, Fraser M, et al. Telehome monitoring in patients with cardiac disease who are at high risk of readmission. Heart Lung. Jan-Feb. 2008;37(1):36-45. [pmid: 18206525].