# Studies Excluded After Full-Text Level Review

Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles

Exclusion codes
X1 Ineligible publication type
X2 Ineligible population
X3 Ineligible or no intervention
X4 Ineligible comparator
X5 Ineligible outcomes
X6 Ineligible timing
X8 Ineligible study design

1 CHF education saved this hospital $173. RN. Nov. 1998;61(11):24C-F-24C-H. Exclusion Code: X1. [pmid: 10205572].
2 Solid outcomes show e-health and chronically ill senior populations are compatible. Dis Manag Advis. Jul. 2001;7(7):103-6. 97. Exclusion Code: X1. [pmid: 11496438].
3 Telehealth helps hospital cut readmissions by 75%. Healthcare Benchmarks Qual Improv. Aug. 2007;14(8):92-4. Exclusion Code: X1. [pmid: 17715882].
4 Development and implementation of a standard congestive heart failure education guide and evaluation of the impact on medical therapy, hospital readmission rates and patient outcomes. J Cardiovasc Nurs. 2012;27(5):376-7. Language: English. Entry Date: 20121102. Publication Type: journal article. Exclusion Code: X8.
5 Agren S, Evangelista LS, Hjelm C, et al. Dyads affected by chronic heart failure: a randomized study evaluating effects of education and psychosocial support to patients with heart failure and their partners. J Card Fail. May. 2012;18(5):359-66. Exclusion Code: X2. [pmid: 22555264].
6 Aguado O, Morcillo C, Delas J, et al. Long-term implications of a single home-based educational intervention in patients with heart failure. Heart Lung. Nov-Dec. 2010;39(6 Suppl). Exclusion Code: X6. [pmid: 20598745].
7 Agvall B, Alehagen U, Dahlstrom U. The benefits of using a heart failure management programme in Swedish primary healthcare. Eur J Heart Fail. Feb. 2013;15(2):228-36. Exclusion Code: X2. [pmid: 23109650].
8 Aimonino N, Tibaldi V, Barale S, et al. Depressive symptoms and quality of life in elderly patients with exacerbation of chronic obstructive pulmonary disease or cardiac heart failure: preliminary data of a randomized controlled trial. Arch Gerontol Geriatr. Suppl 1. 2007;44:7-12. Exclusion Code: X3. [pmid: 17317428].
9 Albanese MC, Bulfoni A, Rossi P, et al. The SCOOP II trial in heart failure. Italian heart journal. Supplement : official journal of the Italian Federation of Cardiology. 2001;(4):390-5. CN-00699305. Exclusion Code: X1. [pmid: 19397013].
10 Albert NM, Nutter B, Forney J, et al. A randomized controlled pilot study of outcomes of strict allowance of fluid therapy in hyponatremic heart failure (SALT-HF). J Card Fail. Jan. 2013;19(1):1-9. Exclusion Code: X3. [pmid: 23273588].
11 Aliti GB, Rabelo ER, Clausell N, et al. Aggressive fluid and sodium restriction in acute decompensated heart failure: a randomized clinical trial. JAMA Intern Med. Jun. 24. 2013;173(12):1058-64. Exclusion Code: X3. [pmid: 23689381].
12 Anderson C, Deepak BV, Amoateng-Adjepong Y, et al. Benefits of comprehensive inpatient education and discharge planning combined with outpatient support in elderly patients with congestive heart failure. Congest Heart Fail. 2005;11(6):315-21. Exclusion Code: X8. [pmid: 16330907].
13 Andryukhin A, Frolova E, Vaes B, et al. The impact of a nurse-led care programme on events and physical and psychosocial parameters in patients with heart failure with preserved ejection fraction: a randomized clinical trial in primary care in Russia. Eur J Gen Pract. Dec. 2010;16(4):205-14. Exclusion Code: X2. [pmid: 21073267].
14 Anguita M, Esteban F, Castillo JC, et al. Usefulness of brain natriuretic peptide levels, as compared with usual clinical control, for the treatment monitoring of patients with heart failure. Med Clin (Barc). 2010;(10):435-40. CN-00770147. Exclusion Code: X1. [pmid: 20673678].
15 Antonicelli R, Mazzanti I, Abbatecola AM, et al. Impact of home patient telemonitoring on use of beta-blockers in congestive heart failure. Drugs Aging. Oct. 1. 2010;27(10):801-5. Exclusion Code: X6. [pmid: 20883060].
16 Antonicelli R, Testarmata P, Spazzafumo L, et al. Impact of telemonitoring at home on the management of elderly patients with congestive heart failure. J Telemed Telecare. 2008;14(6):300-5. Exclusion Code: X6. [pmid: 18776075].
17 Artinian NT, Harden JK, Kronenberg MW, et al. Pilot study of a Web-based compliance monitoring device for patients with congestive heart failure. Heart Lung. Jul-Aug. 2003;32(4):226-33. Exclusion Code: X2. [pmid: 12891162].
18 Atienza F, Anguita M, Martinez-Alzamora N, et al. Multicenter randomized trial of a comprehensive hospital discharge and outpatient heart failure management program. Eur J Heart Fail. Aug. 2004;6(5):643-52. Exclusion Code: X6. [pmid: 15302014].
19 Austin J, Williams R, Ross L, et al. Randomised controlled trial of cardiac rehabilitation in elderly patients with heart failure. Eur J Heart Fail. Mar. 16. 2005;7(3):411-7. Exclusion Code: X2. [pmid: 15718182].
20 Azad N, Molnar F, Byszewski A. Lessons learned from a multidisciplinary heart failure clinic for older women: a randomised controlled trial. Age Ageing. May. 2008;37(3):282-7. Exclusion Code: X2. [pmid: 18285347].
21 Azad NA, Molnar FJ, Byszewski AM. Multidisciplinary congestive heart failure clinic for older women: a randomized, controlled trial. J Am Geriatr Soc. 2006;(5):874-5. CN-00556312. Exclusion Code: X2. [pmid: 16696774].
22 Azevedo A, Pimenta J, Dias P, et al. Effect of a heart failure clinic on survival and hospital readmission in patients discharged from acute hospital care. Eur J Heart Fail. Jun. 2002;4(3):353-9. Exclusion Code: X8. [pmid: 12034162].
23 Bakan G, Akyol AD. Theory-guided interventions for adaptation to heart failure. J Adv Nurs. Mar. 2008;61(6):596-608. Exclusion Code: X2. [pmid: 18302601].
24 Baker DW, Dewalt DA, Schillinger D, et al. The effect of progressive, reinforcing telephone education and counseling versus brief educational intervention on knowledge, self-care behaviors and heart failure symptoms. J Card Fail. Oct. 2011;17(10):789-96. Exclusion Code: X2. [pmid: 21962415].
25 Balk AH, Davidse W, Dommelen P, et al. Tele-guidance of chronic heart failure patients enhances knowledge about the disease. A multi-centre, randomised controlled study. Eur J Heart Fail. Nov. 2008;10(11):1136-42. Exclusion Code: X2. [pmid: 18790668].
26 Barnason S, Zimmerman L, Nieveen J, et al. Impact of a home communication intervention for coronary artery bypass graft patients with ischemic heart failure on self-efficacy, coronary disease risk factor modification, and functioning. Heart Lung. May-Jun. 2003;32(3):147-58. Exclusion Code: X5. [pmid: 12827099].
27 Barnason S, Zimmerman L, Young L. An integrative review of interventions promoting self-care of patients with heart failure (Structured abstract). J Clin Nurs. 2012;(3/4):448-75. DARE-12012005438. Exclusion Code: X5. [pmid: 22098479].
28 Basford JR, Oh JK, Allison TG, et al. Safety, acceptance, and physiologic effects of sauna bathing in people with chronic heart failure: a pilot report. Arch Phys Med Rehabil. Jan. 2009;90(1):173-7. Exclusion Code: X2. [pmid: 19154844].
29 Belardinelli R, Capestro F, Misiani A, et al. Moderate exercise training improves functional capacity, quality of life, and endothelium-dependent vasodilation in chronic heart failure patients with implantable cardioverter defibrillators and cardiac resynchronization therapy. Eur J Cardiovasc Prev Rehabil. Oct. 2006;13(5):818-25. Exclusion Code: X2. [pmid: 17001224].
30 Berger R, Moertl D, Peter S, et al. N-terminal pro-B-type natriuretic peptide-guided, intensive patient management in addition to multidisciplinary care in chronic heart failure a 3-arm, prospective, randomized pilot study. J Am Coll Cardiol. Feb. 16. 2010;55(7):645-53. Exclusion Code: X6. [pmid: 20170790].
31 Bernardi L. Modifying breathing patterns in chronic heart failure. Eur Heart J. 1999;(2):83-4. CN-00161282. Exclusion Code: X1. [pmid: 10099900].
32 Blue L, Lang E, McMurray JJ, et al. Randomised controlled trial of specialist nurse intervention in heart failure. BMJ. Sep. 29. 2001;323(7315):715-8. Exclusion Code: X6. [pmid: 11576977].
33 Blue L, Lang E, McMurray JJV, et al. Randomized controlled trial of specialist nurse intervention in heart failure. BMJ: British Medical Journal (International Edition). 2001;323(7315):715-8. Language: English. Entry Date: 20020201. Revision Date: 20121228. Publication Type: journal article. Exclusion Code: X6.
34 Bocalini DS, dos Santos L, Serra AJ. Physical exercise improves the functional capacity and quality of life in patients with heart failure. Clinics (Sao Paulo). Aug. 2008;63(4):437-42. Exclusion Code: X3. [pmid: 18719752].
35 Bocchi EA, Cruz F, Guimaraes G, et al. Long-term prospective, randomized, controlled study using repetitive education at six-month intervals and monitoring for adherence in heart failure outpatients: the REMADHE trial. Circ Heart Fail. Jul. 2008;1(2):115-24. Exclusion Code: X2. [pmid: 19808281].
36 Bondmass M, Bolger N, Castro G, et al. The effect of physiological home monitoring and telemanagement on chronic heart failure outcomes. Int J Asthm, Allerg, Immunolog [online]. 1999;3(2). Exclusion Code: X8.
37 Boren SA, Wakefield BJ, Gunlock TL, et al. Heart failure self-management education: a systematic review of the evidence (Structured abstract). International Journal of Evidence-Based Healthcare. 2009;(3):159-68. DARE-12009108816. Exclusion Code: X8 (SR). [pmid: 21631856].
38 Bouvy ML, Heerdink ER, Urquhart J, et al. Effect of a pharmacist-led intervention on diuretic compliance in heart failure patients: a randomized controlled study. J Card Fail. 2003;(5):404-11. CN-0041819. Exclusion Code: X2. [pmid: 14583903].
39 Bowles KH, Holland DE, Horowitz DA. A comparison of in-person home care, home care with telephone contact and home care with telemonitoring for disease management. J Telemed Telecare. 2009;15(7):344-50. Exclusion Code: X2. [pmid: 19815903].
40 Boyde M, Turner C, Thompson DR, et al. Educational interventions for patients with heart failure: a systematic review of randomized controlled trials. J Cardiovasc Nurs. Jul-Aug. 2011;26(4):E27-35. Exclusion Code: X8 (SR). [pmid: 21076308].
41 Boyne JJ, Vrijhoef HJ, Crijns HJ, et al. Tailored telemonitoring in patients with heart failure: results of a multicentre randomized controlled trial. Eur J Heart Fail. Jul. 2012;14(7):791-801. Exclusion Code: X2. [pmid: 22588319].
42 Brodie DA, Inoue A, Shaw DG. Motivational interviewing to change quality of life for people with chronic heart failure: a randomised controlled trial. Int J Nurs Stud. Apr. 2008;45(4):489-500. Exclusion Code: X5. [pmid: 17258218].
43 Brotons C, Falces C, Alegre J, et al. Randomized clinical trial of the effectiveness of a home-based intervention in patients with heart failure: the IC-DOM study. Rev Esp Cardiol. Apr. 2009;62(4):400-8. Exclusion Code: X6. [pmid: 19401125].
44 Brumley R, Enguidanos S. Findings from a multisite in-home palliative care study. J Palliat Care. 2006;22(3):199. Language: English. Entry Date: 20070119. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X3.
45 Byszewski A, Azad N, Molnar FJ, et al. Clinical pathways: adherence issues in complex older female patients with heart failure (HF). Arch Gerontol Geriatr. Mar-Apr. 2010;50(2):165-70. Exclusion Code: X5. [pmid: 19406488].
46 Caldwell MA, Peters KJ, Dracup KA. A simplified education program improves knowledge, self-care behavior, and disease severity in heart failure patients in rural settings. Am Heart J. Nov. 2005;150(5):983. Exclusion Code: X2. [pmid: 16290977].
47 Capomolla S, Febo O, Ceresa M, et al. Cost/utility ratio in chronic heart failure: comparison between heart failure management program delivered by day-hospital and usual care. J Am Coll Cardiol. Oct. 2. 2002;40(7):1259-66. Exclusion Code: X6. [pmid: 12383573].
48 Capomolla S, Pinna G, La Rovere MT, et al. Heart failure case disease management program: a pilot study of home telemonitoring versus usual care. European Heart Journal Supplements. November. 1. 2004. 2004;6(suppl F):F91-F8. Exclusion Code: X6.
49 Cartwright M, Hirani SP, Rixon L, et al. Effect of telehealth on quality of life and psychological outcomes over 12 months (Whole Systems Demonstrator telehealth questionnaire study): nested study of patient reported outcomes in a pragmatic, cluster randomised controlled trial. BMJ. 2013;346:f653. Exclusion Code: X2. [pmid: 23444424].
50 Chan C, Tang D, Jones A. Clinical outcomes of a cardiac rehabilitation and maintenance program for Chinese patients with congestive heart failure. Disabil Rehabil. 2008;30(17):1245-53. Language: English. Entry Date: 20090116. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X8. [pmid: 17926158].
51 Chang BH, Hendricks AM, Slawsky MT, et al. Patient recruitment to a randomized clinical trial of behavioral therapy for chronic heart failure. BMC Med Res Methodol. Apr. 17. 2004;4:8. Exclusion Code: X2. [pmid: 15090073].
52 Chang BH, Jones D, Hendricks A, et al. Relaxation response for Veterans Affairs patients with congestive heart failure: results from a qualitative study within a clinical trial. Preventive cardiology. 2004;(2):64-70. CN-00468815. Exclusion Code: X8. [pmid: 15133373].
53 Chaudhry SI, Barton B, Mattera J, et al. Randomized trial of Telemonitoring to Improve Heart Failure Outcomes (Tele-HF): study design. J Card Fail. Nov. 2007;13(9):709-14. Exclusion Code: X2. [pmid: 17996818].
54 Chaudhry SI, Mattera JA, Curtis JP, et al. Telemonitoring in patients with heart failure. N Engl J Med. Dec. 9. 2010;363(24):2301-9. Exclusion Code: X2. [pmid: 21080835].
55 Chaudhry SI, Phillips CO, Stewart SS, et al. Telemonitoring for patients with chronic heart failure: a systematic review (Provisional abstract). J Card Fail. 2007;(1):56-62. DARE-12007001099. Exclusion Code: X8 (SR). [pmid: 17339004].
56 Chen YH, Ho YL, Huang HC, et al. Assessment of the clinical outcomes and cost-effectiveness of the management of systolic heart failure in Chinese patients using a home-based intervention. J Int Med Res. Jan-Feb. 2010;38(1):242-52. Exclusion Code: X8. [pmid: 20233536].
57 Chetney R. The Cardiac Connection program: home care that doesn't miss a beat. Home Healthc Nurse. 2003;21(10):680-6. Exclusion Code: X2. [pmid: 14557707].
58 Chien CL, Lee CM, Wu YW, et al. Home-based exercise increases exercise capacity but not quality of life in people with chronic heart failure: a systematic review. Aust J Physiother. 2008;54(2):87-93. Exclusion Code: X2. [pmid: 18491999].
59 Clark RA, Inglis SC, McAlister FA, et al. Telemonitoring or structured telephone support programmes for patients with chronic heart failure: systematic review and meta-analysis. BMJ. May. 5. 2007;334(7600):942. Exclusion Code: X8 (SR). [pmid: 17426062].
60 Cleland JG, Louis AA, Rigby AS, et al. Noninvasive home telemonitoring for patients with heart failure at high risk of recurrent admission and death: the Trans-European Network-Home-Care Management System (TEN-HMS) study. J Am Coll Cardiol. May. 17. 2005;45(10):1654-64. Exclusion Code: X2. [pmid: 15893183].
61 Coleman EA, Boult C. Improving the quality of transitional care for persons with complex care needs. J Am Geriatr Soc. Apr. 2003;51(4):556-7. Exclusion Code: X1. [pmid: 12657079].
62 Copeland LA, Berg GD, Johnson DM, et al. An intervention for VA patients with congestive heart failure. Am J Manag Care. Mar. 2010;16(3):158-65. Exclusion Code: X2. [pmid: 20225911].
63 Cordisco ME, Benjaminovitz A, Hammond K, et al. Use of telemonitoring to decrease the rate of hospitalization in patients with severe congestive heart failure. Am J Cardiol. Oct. 1. 1999;84(7):860-2, A8. Exclusion Code: X2. [pmid: 10513789].
64 Cutrona SL, Choudhry NK, Fischer MA, et al. Modes of delivery for interventions to improve cardiovascular medication adherence (Structured abstract). Am J Manag Care. 2010;(12):929-42. DARE-12011000969. Exclusion Code: X2. [pmid: 21348564].
65 Dall'Ago P, Chiappa GR, Guths H, et al. Inspiratory muscle training in patients with heart failure and inspiratory muscle weakness: a randomized trial. J Am Coll Cardiol. 2006;(4):757-63. CN-00555241. Exclusion Code: X2. [pmid: 16487841].
66 Dansky K, Vasey J. Managing heart failure patients after formal homecare. Telemed J E Health. Dec. 2009;15(10):983-91. Exclusion Code: X2. [pmid: 19929234].
67 Dansky KH, Vasey J, Bowles K. Use of telehealth by older adults to manage heart failure. Res Gerontol Nurs. Jan. 2008;1(1):25-32. Exclusion Code: X2. [pmid: 20078015].
68 Dansky KH, Vasey J, Bowles K. Impact of telehealth on clinical outcomes in patients with heart failure. Clin Nurs Res. Aug. 2008;17(3):182-99. Exclusion Code: X2. [pmid: 18617707].
69 Davidson PM, Cockburn J, Newton PJ, et al. Can a heart failure-specific cardiac rehabilitation program decrease hospitalizations and improve outcomes in high-risk patients?. Eur J Cardiovasc Prev Rehabil. Aug. 2010;17(4):393-402. Exclusion Code: X5. [pmid: 20498608].
70 Davies P, Taylor F, Beswick A, et al. Promoting patient uptake and adherence in cardiac rehabilitation. Cochrane Database of Systematic Reviews. 2010;(7):CD007131. Exclusion Code: X3. [pmid: 20614453].
71 de la Porte PW, Lok DJ, van Veldhuisen DJ, et al. Added value of a physician-and-nurse-directed heart failure clinic: results from the Deventer-Alkmaar heart failure study. Heart. Jul. 2007;93(7):819-25. Exclusion Code: X2. [pmid: 17065182].
72 de Lusignan S, Wells S, Johnson P, et al. Compliance and effectiveness of 1 year's home telemonitoring. The report of a pilot study of patients with chronic heart failure. Eur J Heart Fail. Dec. 2001;3(6):723-30. Exclusion Code: X2. [pmid: 11738225].
73 DeBusk RF, Miller NH, Parker KM, et al. Care management for low-risk patients with heart failure: a randomized, controlled trial. Ann Intern Med. Oct. 19. 2004;141(8):606-13. Exclusion Code: X6. [pmid: 15492340].
74 Del Sindaco D, Pulignano G, Minardi G, et al. Two-year outcome of a prospective, controlled study of a disease management programme for elderly patients with heart failure. J Cardiovasc Med (Hagerstown). May. 2007;8(5):324-9. Exclusion Code: X6. [pmid: 17443097].
75 Delagardelle C, Feiereisen P, Vaillant M, et al. Reverse remodelling through exercise training is more pronounced in non-ischemic heart failure. Clin Res Cardiol. Dec. 2008;97(12):865-71. Exclusion Code: X2. [pmid: 18696023].
76 Delaney C, Apostolidis B. Pilot testing of a multicomponent home care intervention for older adults with heart failure: an academic clinical partnership. J Cardiovasc Nurs. Sep-Oct. 2010;25(5):E27-40. Exclusion Code: X8. [pmid: 20671564].
77 Delaney C, Apostolidis B, Bartos S, et al. A Randomized Trial of Telemonitoring and Self-Care Education in Heart Failure Patients Following Home Care Discharge. Home Health Care Management & Practice. 2013;25(5):187-95. Language: English. Entry Date: 20131004. Revision Date: 20131025. Publication Type: journal article. Exclusion Code: X6.
78 DeWalt DA, Malone RM, Bryant ME, et al. A heart failure self-management program for patients of all literacy levels: a randomized, controlled trial [ISRCTN11535170]. BMC Health Serv Res. 2006;6:30. Exclusion Code: X2. [pmid: 16533388].
79 DeWalt DA, Schillinger D, Ruo B, et al. Multisite randomized trial of a single-session versus multisession literacy-sensitive self-care intervention for patients with heart failure. Circulation. Jun. 12. 2012;125(23):2854-62. Exclusion Code: X2. [pmid: 22572916].
80 Ditewig JB, Blok H, Havers J, et al. Effectiveness of self-management interventions on mortality, hospital readmissions, chronic heart failure hospitalization rate and quality of life in patients with chronic heart failure: a systematic review (Structured abstract). Patient Educ Couns. 2010;(3):297-315. DARE-12010002763. Exclusion Code: X8 (SR). [pmid: 20202778].
81 Domingo M, Lupón J, González B, et al. Noninvasive remote telemonitoring for ambulatory patients with heart failure: effect on number of hospitalizations, days in hospital, and quality of life. CARME (CAtalan Remote Management Evaluation) study. Rev Esp Cardiol. 2011;(4):277-85. CN-00786543. Exclusion Code: X2.
82 Doughty RN, Wright SP, Pearl A, et al. Randomized, controlled trial of integrated heart failure management: The Auckland Heart Failure Management Study. Eur Heart J. Jan. 2002;23(2):139-46. Exclusion Code: X6. [pmid: 11785996].
83 Dracup K, Evangelista LS, Hamilton MA, et al. Effects of a home-based exercise program on clinical outcomes in heart failure. Am Heart J. Nov. 2007;154(5):877-83. Exclusion Code: X2. [pmid: 17967593].
84 Duffy JR, Hoskins LM, Chen MC. Nonpharmacological strategies for improving heart failure outcomes in the community: a systematic review. J Nurs Care Qual. Oct-Dec. 2004;19(4):349-60. Exclusion Code: X8 (SR). [pmid: 15535541].
85 Duffy JR, Hoskins LM, Dudley-Brown S. Development and testing of a caring-based intervention for older adults with heart failure. The Journal of cardiovascular nursing. 2005;(5):325-33. CN-00529955. Exclusion Code: X1. [pmid: 16141777].
86 Duncan K, Pozehl B. Effects of an exercise adherence intervention on outcomes in patients with heart failure. Rehabil Nurs. Jul-Aug. 2003;28(4):117-22. Exclusion Code: X2. [pmid: 12875144].
87 Engel Mark E, Matchaba Patrice T, Volmink J. Corticosteroids for tuberculous pleurisy. John Wiley & Sons, Ltd. 2007. Exclusion Code: Corticosteroids for tuberculous pleurisy.
88 Evengelista L, Doering L, Dracup K. Exercise training and weight control in patients with chronic heart failure. Commun Nurs Res. 2005;38:245. Language: English. Entry Date: 20080613. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X3.
89 Fabbri G, Gorini M, Maggioni AP, et al. Heart failure: the importance of a disease management program. Giornale italiano di cardiologia (2006). 2007;(6):353-8. CN-00704189. Exclusion Code: X1. [pmid: 17633908].
90 Falces C, López-Cabezas C, Andrea R, et al. An educative intervention to improve treatment compliance and to prevent readmissions of elderly patients with heart failure. Med Clin (Barc). 2008;(12):452-6. CN-00687356. Exclusion Code: X1. [pmid: 18928735].
91 Feaster SJ. Tips, tools, and techniques. Nursing, technology, and patient care: a home-based model. Nurs Case Manag. 1998. Jan-Feb. 1998;3(1):7-10. Language: English. Entry Date: 19980701. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X1. [pmid: 9526391].
92 Feldman PH, Murtaugh CM, Pezzin LE, et al. Just-in-time evidence-based e-mail “reminders” in home health care: impact on patient outcomes. Health Serv Res. Jun. 2005;40(3):865-85. Exclusion Code: X2. [pmid: 15960695].
93 Finkelstein SM, Speedie SM, Potthoff S. Home telehealth improves clinical outcomes at lower cost for home healthcare. Telemed J E Health. Apr. 2006;12(2):128-36. Exclusion Code: X2. [pmid: 16620167].
94 Flynn KE, Pina IL, Whellan DJ, et al. Effects of exercise training on health status in patients with chronic heart failure: HF-ACTION randomized controlled trial. JAMA. Apr. 8. 2009;301(14):1451-9. Exclusion Code: X2. [pmid: 19351942].
95 Fredericks S, Beanlands H, Spalding K, et al. Effects of the characteristics of teaching on the outcomes of heart failure patient education interventions: a systematic review. Eur J Cardiovasc Nurs. Mar. 2010;9(1):30-7. Exclusion Code: X8 (SR). [pmid: 19734100].
96 Fursse J, Clarke M, Jones R, et al. Early experience in using telemonitoring for the management of chronic disease in primary care. J Telemed Telecare. 2008;14(3):122-4. Exclusion Code: X8. [pmid: 18430275].
97 Gardner-Bonneau D. Remote patient monitoring: a human factors assessment. Biomed Instrum Technol. 2010:71-7. Language: English. Entry Date: 20110311. Revision Date: 20120622. Publication Type: journal article. Exclusion Code: X5.
98 Gary R. Exercise self-efficacy in older women with diastolic heart failure: results of a walking program and education intervention. J Gerontol Nurs. Jul. 2006;32(7):31-9. quiz 40-1. Exclusion Code: X2. [pmid: 16863044].
99 Gary RA, Sueta CA, Dougherty M, et al. Home-based exercise improves functional performance and quality of life in women with diastolic heart failure. Heart Lung. Jul-Aug. 2004;33(4):210-8. Exclusion Code: X2. [pmid: 15252410].
100 Gattis WA, Hasselblad V, Whellan DJ, et al. Reduction in heart failure events by the addition of a clinical pharmacist to the heart failure management team: results of the Pharmacist in Heart Failure Assessment Recommendation and Monitoring (PHARM) Study. Arch Intern Med. Sep. 13. 1999;159(16):1939-45. Exclusion Code: X2. [pmid: 10493325].
101 Gellis ZD, Kenaley B, McGinty J, et al. Outcomes of a telehealth intervention for homebound older adults with heart or chronic respiratory failure: a randomized controlled trial. Gerontologist. Aug. 2012;52(4):541-52. Exclusion Code: X2. [pmid: 22241810].
102 GESICA Investigators. Randomised trial of telephone intervention in chronic heart failure: DIAL trial. BMJ. Aug. 20. 2005;331(7514):425. Exclusion Code: X2. [pmid: 16061499].
103 Giannuzzi P, Temporelli PL, Corra U, et al. Antiremodeling effect of long-term exercise training in patients with stable chronic heart failure: results of the Exercise in Left Ventricular Dysfunction and Chronic Heart Failure (ELVD-CHF) Trial. Circulation. Aug. 5. 2003;108(5):554-9. Exclusion Code: X2. [pmid: 12860904].
104 Giliarevski SR, Orlov VA, Khamaganova LK. et al. [Effect of therapeutic education of patients with chronic heart failure on quality of life and requirement of rehospitalizations. Results of 12-months randomized study]. Kardiologiia. 2002;(5):56-61. CN-00434818. Exclusion Code: X1.
105 Giordano A, Scalvini S, Zanelli E, et al. Multicenter randomised trial on home-based telemanagement to prevent hospital readmission of patients with chronic heart failure. Int J Cardiol. Jan. 9. 2009;131(2):192-9. Exclusion Code: X6. [pmid: 18222552].
106 Godfrey CM, Harrison MB, Friedberg E, et al. The symptom of pain in individuals recently hospitalized for heart failure. J Cardiovasc Nurs. Sep-Oct. 2007;22(5):368-74. discussion 6-7. Exclusion Code: X4. [pmid: 17724418].
107 Gohler A, Januzzi JL, Worrell SS, et al. A systematic meta-analysis of the efficacy and heterogeneity of disease management programs in congestive heart failure. J Card Fail. Sep. 2006;12(7):554-67. Exclusion Code: X8 (SR). [pmid: 16952790].
108 Gomez-Soto FM, Puerto JL, Andrey JL, et al. Consultation between specialists in Internal Medicine and Family Medicine improves management and prognosis of heart failure. Eur J Intern Med. Nov. 2008;19(7):548-54. Exclusion Code: X8. [pmid: 19013386].
109 Gonseth J, Guallar-Castillon P, Banegas JR, et al. The effectiveness of disease management programmes in reducing hospital re-admission in older patients with heart failure: a systematic review and meta-analysis of published reports. Eur Heart J. Sep. 2004;25(18):1570-95. Exclusion Code: X8 (SR). [pmid: 15351157].
110 Grady KL. Self-care and quality of life outcomes in heart failure patients (Structured abstract). J Cardiovasc Nurs. 2008;(3):285-92. DARE-12008103868. Exclusion Code: X8 (SR). [pmid: 18437071].
111 Grancelli HO. Disease management programs in heart failure. Findings of the DIAL study. Rev Esp Cardiol. 2007:15-22. CN-00628926. Exclusion Code: X1. [pmid: 18093490].
112 Gregory D, Kimmelstiel C, Perry K, et al. Hospital cost effect of a heart failure disease management program: the Specialized Primary and Networked Care in Heart Failure (SPAN-CHF) trial. Am Heart J. May. 2006;151(5):1013-8. Exclusion Code: X8. [pmid: 16644325].
113 Guadagnoli E, Normand SL, DiSalvo TG, et al. Effects of treatment recommendations and specialist intervention on care provided by primary care physicians to patients with myocardial infarction or heart failure. Am J Med. Sep. 15. 2004;117(6):371-9. Exclusion Code: X5. [pmid: 15380493].
114 Guimaraes GV, Carvalho VO, Bocchi EA, et al. Pilates in heart failure patients: a randomized controlled pilot trial. Cardiovasc Ther. Dec. 2012;30(6):351-6. Exclusion Code: X2. [pmid: 21884019].
115 Gwadry-Sridhar F, Guyatt G, o'Brien B, et al. TEACH: Trial of Education And Compliance in Heart dysfunction chronic disease and heart failure (HF) as an increasing problem. Contemp Clin Trials. Nov. 2008;29(6):905-18. Exclusion Code: X5. [pmid: 18703166].
116 Gwadry-Sridhar FH, Arnold JM, Zhang Y, et al. Pilot study to determine the impact of a multidisciplinary educational intervention in patients hospitalized with heart failure. Am Heart J. Nov. 2005;150(5):982. Exclusion Code: X6. [pmid: 16290975].
117 Gwadry-Sridhar FH, Flintoft V, Lee DS, et al. A systematic review and meta-analysis of studies comparing readmission rates and mortality rates in patients with heart failure. Arch Intern Med. Nov. 22. 2004;164(21):2315-20. Exclusion Code: X8 (SR). [pmid: 15557409].
118 Hailey D, Ohinmaa A, Roine R. Published evidence on the success of telecardiology: a mixed record. J Telemed Telecare. Suppl 1. 2004;10:36-8. Exclusion Code: X2. [pmid: 15603604].
119 Hamner JB. State of the science: posthospitalization nursing interventions in congestive heart failure. ANS Adv Nurs Sci. Apr-Jun. 2005;28(2):175-90. Exclusion Code: X8. [pmid: 15920363].
120 Harrison MB. Providing supportive care during hospital to home transfer: implementing and evaluating clinical practice guidelines on supportive care for individuals with heart failure [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. 1998:52. CN-00598189. Exclusion Code: X1.
121 Harrison MB, Browne GB, Roberts J, et al. Quality of life of individuals with heart failure: a randomized trial of the effectiveness of two models of hospital-to-home transition. Med Care. Apr. 2002;40(4):271-82. Exclusion Code: X5. [pmid: 12021683].
122 Heisler M, Halasyamani L, Cowen ME, et al. Randomized controlled effectiveness trial of reciprocal peer support in heart failure. Circ Heart Fail. Mar. 2013;6(2):246-53. Exclusion Code: X2. [pmid: 23388114].
123 Hershberger RE, Ni H, Nauman DJ, et al. Prospective evaluation of an outpatient heart failure management program. J Card Fail. Mar. 2001;7(1):64-74. Exclusion Code: X2. [pmid: 11264552].
124 Holst DP, Kaye D, Richardson M, et al. Improved outcomes from a comprehensive management system for heart failure. Eur J Heart Fail. Oct. 2001;3(5):619-25. Exclusion Code: X2. [pmid: 11595611].
125 Hopp F, Woodbridge P, Subramanian U, et al. Outcomes associated with a home care telehealth intervention. Telemed J E Health. Jun. 2006;12(3):297-307. Exclusion Code: X2. [pmid: 16796497].
126 Hughes S, Weaver F, Manheim L, et al. Cost-effectiveness of team-managed home care in the VA: an update from a multi-site randomized trial [abstract]. Abstract Book/Association for Health Services Research. 1997:110-1. CN-00270902. Exclusion Code: X2.
127 Hughes SL, Weaver FM, Giobbie-Hurder A, et al. Effectiveness of team-managed home-based primary care: a randomized multicenter trial. JAMA. Dec. 13. 2000;284(22):2877-85. Exclusion Code: X2. [pmid: 11147984].
128 Hwang R, Marwick T. Efficacy of home-based exercise programmes for people with chronic heart failure: a meta-analysis. Eur J Cardiovasc Prev Rehabil. Oct. 2009;16(5):527-35. Exclusion Code: X5. [pmid: 20054288].
129 Inglis Sally C, Clark Robyn A, McAlister Finlay A, et al. Structured telephone support or telemonitoring programmes for patients with chronic heart failure. Cochrane Database of Systematic Reviews. 2010;(8):CD007228. Exclusion Code: X8 (SR). [pmid: 20687083].
130 Inglis SC, Clark RA, Cleland JG. Telemonitoring in patients with heart failure. N Engl J Med. March. 17. 2011;364(11):1078-9. Exclusion Code: X1. [pmid: 21410377].
131 Inglis SC, Clark RA, McAlister FA, et al. Which components of heart failure programmes are effective? A systematic review and meta-analysis of the outcomes of structured telephone support or telemonitoring as the primary component of chronic heart failure management in 8323 patients: Abridged Cochrane Review. Eur J Heart Fail. Sep. 2011;13(9):1028-40. Exclusion Code: X8 (SR). [pmid: 21733889].
132 Jaarsma T, Brons M, Kraai I, et al. Components of heart failure management in home care; a literature review. European Journal of Cardiovascular Nursing. 2013;12(3):230-41. Language: English. Entry Date: 20130531. Revision Date: 20130531. Publication Type: journal article. Exclusion Code: X8. [pmid: 22707520].
133 Jaarsma T, Halfens R, Tan F, et al. Self-care and quality of life in patients with advanced heart failure: the effect of a supportive educational intervention. Heart Lung. Sep-Oct. 2000;29(5):319-30. Exclusion Code: X5. [pmid: 10986526].
134 Jaarsma T, Lvan-Der-Wal M, Lesman LI. Value of basic or intensive management of patients with heart failure confirmed in a randomised controlled clinical trial. Ned Tijdschr Geneeskd. 2008;152:2016-21. Exclusion Code: X1. [pmid: 18825890].
135 Jaarsma T, Van Der Wal MH, Hogenhuis J, et al. Design and methodology of the COACH study: a multicenter randomised Coordinating study evaluating Outcomes of Advising and Counselling in Heart failure. Eur J Heart Fail. Mar. 1. 2004;6(2):227-33. Exclusion Code: X1. [pmid: 14984731].
136 Jaarsma T, van der Wal MH, Lesman-Leegte I, et al. Effect of moderate or intensive disease management program on outcome in patients with heart failure: Coordinating Study Evaluating Outcomes of Advising and Counseling in Heart Failure (COACH). Arch Intern Med. Feb. 11. 2008;168(3):316-24. Exclusion Code: X6. [pmid: 18268174].
137 Jaarsma T, van Veldhuisen DJ. When, how and where should we “coach” patients with heart failure: the COACH results in perspective. Eur J Heart Fail. 2008;10(4):331-3. Exclusion Code: X1. [pmid: 18353718].
138 Jaarsma T, van Veldhuisen DJ, van der Wal MH. NHF-COACH multicenter trial in The Netherlands: searching for underlying potentially beneficial mechanisms in nurse led heart failure management. Prog Cardiovasc Nurs. Spring. 2002;17(2):96-8. Exclusion Code: X1. [pmid: 11986543].
139 Jaarsma T, Veldhuisen DJ. Research set-up concerning the effectiveness of heart failure clinics in the Netherlands. Ned Tijdschr Geneeskd. 2003;(11):513-4. CN-00558540. Exclusion Code: X1. [pmid: 12677952].
140 Jackson RA. Internet and telephone-based congestive heart failure program as effective as and cheaper than traditional one, study says. Rep Med Guidel Outcomes Res. Feb. 22. 2001;12(4):9-10. 2. Exclusion Code: X1. [pmid: 11767797].
141 Jayadevappa R, Johnson JC, Bloom BS, et al. Effectiveness of transcendental meditation on functional capacity and quality of life of African Americans with congestive heart failure: a randomized control study. Ethn Dis. 2007;(1):72-7. CN-00575174. Exclusion Code: X3. [pmid: 17274213].
142 Jerant AF, Nesbitt TS. Heart failure disease management incorporating telemedicine: a critical review. Journal of Clinical Outcomes Management. 2005;12(4):207-17. Language: English. Entry Date: 20050624. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X8 (SR).
143 Johnson MJ, Oxberry SG, Cleland JG, et al. Measurement of breathlessness in clinical trials in patients with chronic heart failure: the need for a standardized approach: a systematic review. Eur J Heart Fail. Feb. 2010;12(2):137-47. Exclusion Code: X3. [pmid: 20083623].
144 Jolly K, Taylor RS, Lip GY, et al. A randomized trial of the addition of home-based exercise to specialist heart failure nurse care: the Birmingham Rehabilitation Uptake Maximisation study for patients with Congestive Heart Failure (BRUM-CHF) study. Eur J Heart Fail. Feb. 2009;11(2):205-13. Exclusion Code: X2. [pmid: 19168520].
145 Jonsdottir S, Andersen KK, Sigurosson AF, et al. The effect of physical training in chronic heart failure. Eur J Heart Fail. Jan. 2006;8(1):97-101. Exclusion Code: X2. [pmid: 16194620].
146 Jovicic A, Chignell M, Wu R, et al. Is Web-only self-care education sufficient for heart failure patients?. AMIA Annu Symp Proc. 2009;2009:296-300. Exclusion Code: X5. [pmid: 20351868].
147 Jovicic A, Holroyd-Leduc JM, Straus SE. Effects of self-management intervention on health outcomes of patients with heart failure: a systematic review of randomized controlled trials. BMC Cardiovasc Disord. 2006;6:43. Exclusion Code: X8 (SR). [pmid: 17081306].
148 Karapolat H, Demir E, Bozkaya YT, et al. Comparison of hospital-based versus home-based exercise training in patients with heart failure: effects on functional capacity, quality of life, psychological symptoms, and hemodynamic parameters. Clin Res Cardiol. Oct. 2009;98(10):635-42. Exclusion Code: X2. [pmid: 19641843].
149 Karlsson MR, Edner M, Henriksson P, et al. A nurse-based management program in heart failure patients affects females and persons with cognitive dysfunction most. Patient Educ Couns. Aug. 2005;58(2):146-53. Exclusion Code: X5. [pmid: 16009290].
150 Kashem A, Droogan MT, Santamore WP, et al. Managing heart failure care using an internet-based telemedicine system. J Card Fail. Mar. 2008;14(2):121-6. Exclusion Code: X2. [pmid: 18325458].
151 Kashem A, Droogan MT, Santamore WP, et al. Web-based Internet telemedicine management of patients with heart failure. Telemedicine journal and e-health : the official journal of the American Telemedicine Association. 2006;(4):439-47. CN-0051916. Exclusion Code: X2. [pmid: 16942416].
152 Kayanakis JG, Page E, Aros F, et al. Rehabilitation of patients with chronic cardiac insufficiency. Immediate and midterm effects. Presse médicale (Paris, France : 1983). 1994;(3):121-6. CN-00101144. Exclusion Code: X1.
153 Kessing D, Denollet J, Widdershoven J, et al. Investigating a TELEmedicine solution to improve MEDication adherence in chronic Heart Failure (TELEMED-HF): study protocol for a randomized controlled trial. Trials. 2011;12:227. Exclusion Code: X2. [pmid: 21999637].
154 Keteyian SJ, Isaac D, Thadani U, et al. Safety of symptom-limited cardiopulmonary exercise testing in patients with chronic heart failure due to severe left ventricular systolic dysfunction. Am Heart J. 2009;(4 Suppl):S72-7. CN-00722507. Exclusion Code: X2. [pmid: 19782792].
155 Khunti K, Stone M, Paul S, et al. Disease management programme for secondary prevention of coronary heart disease and heart failure in primary care: a cluster randomised controlled trial. Heart. Nov. 2007;93(11):1398-405. Exclusion Code: X2. [pmid: 17309907].
156 Kim YJ, Soeken KL. A meta-analysis of the effect of hospital-based case management on hospital length-of-stay and readmission. Nurs Res. Jul-Aug. 2005;54(4):255-64. Exclusion Code: X8 (SR). [pmid: 16027568].
157 Klersy C, De Silvestri A, Gabutti G, et al. Economic impact of remote patient monitoring: an integrated economic model derived from a meta-analysis of randomized controlled trials in heart failure. Eur J Heart Fail. Apr. 2011;13(4):450-9. Exclusion Code: X8. [pmid: 21193439].
158 Klersy C, De Silvestri A, Gabutti G, et al. A meta-analysis of remote monitoring of heart failure patients. J Am Coll Cardiol. Oct. 27. 2009;54(18):1683-94. Exclusion Code: X8 (SR). [pmid: 19850208].
159 Kline KS, Scott LD, Britton AS. The use of supportive-educative and mutual goal-setting strategies to improve self-management for patients with heart failure. Home Healthc Nurse. Sep. 2007;25(8):502-10. Exclusion Code: X2. [pmid: 17828004].
160 Köhler F, Nettlau H, Schweizer T, et al. The research project of the German Federal Ministry of Economics and Technology: ‘Partnership for the Heart’ -- a new approach in telemedicine. Disease Management & Health Outcomes. 2006;14:37-41. Language: English. Entry Date: 20080208. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X1.
161 Kommuri NV, Johnson ML, Koelling TM. Relationship between improvements in heart failure patient disease specific knowledge and clinical events as part of a randomized controlled trial. Patient Educ Couns. Feb. 2012;86(2):233-8. Exclusion Code: X5. [pmid: 21705170].
162 Konstam MA. Home monitoring should be the central element in an effective program of heart failure disease management. Circulation. Feb. 14. 2012;125(6):820-7. Exclusion Code: X1. [pmid: 22331919].
163 Konstam V, Gregory D, Chen J, et al. Health-related quality of life in a multicenter randomized controlled comparison of telephonic disease management and automated home monitoring in patients recently hospitalized with heart failure: SPAN-CHF II trial. J Card Fail. Feb. 2011;17(2):151-7. Exclusion Code: X5. [pmid: 21300305].
164 Kothe K, Ullmann K, Daiss W. Risk score modifications in congestive heart failure-focus on exercise therapy and women. Int J Sports Med. 1996;(Suppl 1):S13. CN-00506784. Exclusion Code: X3.
165 Koukouvou G, Kouidi E, Iacovides A, et al. Quality of life, psychological and physiological changes following exercise training in patients with chronic heart failure. J Rehabil Med. Jan. 2004;36(1):36-41. Exclusion Code: X2. [pmid: 15074436].
166 Kozak AT, Rucker-Whitaker C, Basu S, et al. Elements of nonpharmacologic interventions that prevent progression of heart failure: a meta-analysis. Congest Heart Fail. Sep-Oct. 2007;13(5):280-7. Exclusion Code: X8 (SR). [pmid: 17917495].
167 Kraai IH, Luttik ML, de Jong RM, et al. Heart failure patients monitored with telemedicine: patient satisfaction, a review of the literature. J Card Fail. 2011;17(8):684-90. Language: English. Entry Date: 20120615. Revision Date: 20120615. Publication Type: journal article. Exclusion Code: X5. [pmid: 21807331].
168 Krantz MJ, Havranek EP, Haynes DK, et al. Inpatient initiation of beta-blockade plus nurse management in vulnerable heart failure patients: a randomized study. J Card Fail. May. 2008;14(4):303-9. Exclusion Code: X3. [pmid: 18474343].
169 Krumholz HM, Amatruda J, Smith GL, et al. Randomized trial of an education and support intervention to prevent readmission of patients with heart failure. J Am Coll Cardiol. Jan. 2. 2002;39(1):83-9. Exclusion Code: X6. [pmid: 11755291].
170 Kulcu DG, Kurtais Y, Tur BS, et al. The effect of cardiac rehabilitation on quality of life, anxiety and depression in patients with congestive heart failure. A randomized controlled trial, short-term results. Europa Medicophysica. 2007;43(4):489-97. Language: English. Entry Date: 20080418. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X2. [pmid: 18084172].
171 Kutzleb J, Reiner D. The impact of nurse-directed patient education on quality of life and functional capacity in people with heart failure. J Am Acad Nurse Pract. Mar. 2006;18(3):116-23. Exclusion Code: X2. [pmid: 16499744].
172 LaFramboise LM, Todero CM, Zimmerman L, et al. Comparison of Health Buddy with traditional approaches to heart failure management. Fam Community Health. Oct-Dec. 2003;26(4):275-88. Exclusion Code: X2. [pmid: 14528134].
173 Lainchbury JG, Troughton RW, Strangman KM, et al. N-terminal pro-B-type natriuretic peptide-guided treatment for chronic heart failure: results from the BATTLESCARRED (NT-proBNP-Assisted Treatment To Lessen Serial Cardiac Readmissions and Death) trial. J Am Coll Cardiol. Dec. 29. 2009;55(1):53-60. Exclusion Code: X4. [pmid: 20117364].
174 Lambrinou E, Kalogirou F, Lamnisos D, et al. Effectiveness of heart failure management programmes with nurse-led discharge planning in reducing re-admissions: a systematic review and meta-analysis. Int J Nurs Stud. May. 2012;49(5):610-24. Exclusion Code: X8 (SR). [pmid: 22196054].
175 Landolina M, Perego GB, Lunati M, et al. Remote monitoring reduces healthcare use and improves quality of care in heart failure patients with implantable defibrillators: the evolution of management strategies of heart failure patients with implantable defibrillators (EVOLVO) study. Circulation. Jun. 19. 2012;125(24):2985-92. Exclusion Code: X2. [pmid: 22626743].
176 Laoutaris I, Dritsas A, Brown MD, et al. Inspiratory muscle training using an incremental endurance test alleviates dyspnea and improves functional status in patients with chronic heart failure. Eur J Cardiovasc Prev Rehabil. Dec. 2004;11(6):489-96. Exclusion Code: X2. [pmid: 15580060].
177 LaPointe NM, DeLong ER, Chen A, et al. Multifaceted intervention to promote beta-blocker use in heart failure. Am Heart J. May. 2006;151(5):992-8. Exclusion Code: X2. [pmid: 16644320].
178 Ledwidge M, Ryan E, o'Loughlin C, et al. Heart failure care in a hospital unit: a comparison of standard 3-month and extended 6-month programs. Eur J Heart Fail. Mar. 16. 2005;7(3):385-91. Exclusion Code: X2. [pmid: 15718179].
179 Ledwidge MT, o'Hanlon R, Lalor L, et al. Can individualized weight monitoring using the HeartPhone algorithm improve sensitivity for clinical deterioration of heart failure?. Eur J Heart Fail. Apr. 2013;15(4):447-55. Exclusion Code: X2. [pmid: 23204211].
180 Leff B, Burton L, Mader S, et al. Satisfaction with hospital at home care. J Am Geriatr Soc. Sep. 2006;54(9):1355-63. Exclusion Code: X2. [pmid: 16970642].
181 Leff B, Burton L, Mader SL, et al. Comparison of functional outcomes associated with hospital at home care and traditional acute hospital care. J Am Geriatr Soc. Feb. 2009;57(2):273-8. Exclusion Code: X3. [pmid: 19170781].
182 Leff B, Burton L, Mader SL, et al. Comparison of stress experienced by family members of patients treated in hospital at home with that of those receiving traditional acute hospital care. J Am Geriatr Soc. Jan. 2008;56(1):117-23. Exclusion Code: X3. [pmid: 17979955].
183 Leventhal ME, Denhaerynck K, Brunner-La Rocca HP, et al. Swiss Interdisciplinary Management Programme for Heart Failure (SWIM-HF): a randomised controlled trial study of an outpatient inter-professional management programme for heart failure patients in Switzerland. Swiss Med Wkly. 2011;141:w13171. Exclusion Code: X6. [pmid: 21384285].
184 Lin SJ, McElfresh J, Hall B, et al. Inspiratory muscle training in patients with heart failure: a systematic review (Provisional abstract). Database of Abstracts of Reviews of Effects. 2012;(3):29-36. DARE-12012057718. Exclusion.
185 Lloyd-Williams F, Mair FS, Leitner M. Exercise training and heart failure: a systematic review of current evidence. Br J Gen Pract. Jan. 2002;52(474):47-55. Exclusion Code: X3. [pmid: 11791816].
186 Louis AA, Turner T, Gretton M, et al. A systematic review of telemonitoring for the management of heart failure. Eur J Heart Fail. Oct. 2003;5(5):583-90. Exclusion Code: X8 (SR). [pmid: 14607195].
187 Lusignan S, Meredith K, Wells S, et al. A controlled pilot study in the use of telemedicine in the community on the management of heart failure--a report of the first three months. Stud Health Technol Inform. 1999:126-37. CN-0031805. Exclusion Code: X2. [pmid: 10747531].
188 Lynga P, Persson H, Hagg-Martinell A, et al. Weight monitoring in patients with severe heart failure (WISH). A randomized controlled trial. Eur J Heart Fail. Apr. 2012;14(4):438-44. Exclusion Code: X2. [pmid: 22371525].
189 Madigan EA, Schott D, Matthews CR. Rehospitalization among home healthcare patients: results of a prospective study. Home Healthc Nurse. May. 2001;19(5):298-305. Exclusion Code: X8. [pmid: 11985040].
190 Mainardi L, Iazzolino E, Asteggiano R, et al. Comparison between telephone and outpatient nursing management in patients with chronic heart failure in a large territorial area in Piedmont, Italy. Giornale italiano di cardiologia (2006). 2010;(1):35-42. CN-00743369. Exclusion Code: X1. [pmid: 20380340].
191 Maric B, Kaan A, Ignaszewski A, et al. A systematic review of telemonitoring technologies in heart failure. Eur J Heart Fail. May. 2009;11(5):506-17. Exclusion Code: X3. [pmid: 19332417].
192 Martinez A, Everss E, Rojo-Alvarez JL, et al. A systematic review of the literature on home monitoring for patients with heart failure. J Telemed Telecare. 2006;12(5):234-41. Exclusion Code: X8 (SR). [pmid: 16848935].
193 Mau J, Kolk M, Pelon J, et al. Nurse-directed home-based heart failure management program decreases death/readmission rates and increases dietary and medication compliance. Prog Cardiovasc Nurs. 2006;(2):112. CN-00614843. Exclusion Code: X8.
194 McAlister FA, Lawson FM, Teo KK, et al. A systematic review of randomized trials of disease management programs in heart failure. Am J Med. Apr. 1. 2001;110(5):378-84. Exclusion Code: X8 (SR). [pmid: 11286953].
195 McBride MG, Binder TJ, Paridon SM. Safety and feasibility of inpatient exercise training in pediatric heart failure: a preliminary report. Journal of Cardiopulmonary Rehabilitation & Prevention. 2007;27(4):219-22. Language: English. Entry Date: 20080215. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X2. [pmid: 17667017].
196 McCauley KM, Bixby MB, Naylor MD. Advanced practice nurse strategies to improve outcomes and reduce cost in elders with heart failure. Dis Manag. 2006;9(5):302-10. Exclusion Code: X5. [pmid: 17044764].
197 McKelvie RS, Teo KK, Roberts R, et al. Effects of exercise training in patients with heart failure: the Exercise Rehabilitation Trial (EXERT). Am Heart J. Jul. 2002;144(1):23-30. Exclusion Code: X2. [pmid: 12094184].
198 McManus SG. A Telehealth Program to Reduce Readmission Rates Among Heart Failure Patients: One Agency's Experience. Home Health Care Management & Practice. June. 1. 2004. 2004;16(4):250-4. Exclusion Code: X2.
199 Mehra MR, Uber PA, Chomsky DB, et al. Emergence of electronic home monitoring in chronic heart failure: rationale, feasibility, and early results with the HomMed Sentry-Observer system. Congest Heart Fail. 2000;6(3):137-9. Exclusion Code: X2. [pmid: 12029180].
200 Mejhert M, Kahan T, Persson H, et al. Limited long term effects of a management programme for heart failure. Heart. Sep. 2004;90(9):1010-5. Exclusion Code: X5. [pmid: 15310688].
201 Mello PR, Guerra GM, Borile S, et al. Inspiratory muscle training reduces sympathetic nervous activity and improves inspiratory muscle weakness and quality of life in patients with chronic heart failure: a clinical trial. J Cardiopulm Rehabil Prev. Sep-Oct. 2012;32(5):255-61. Exclusion Code: X2. [pmid: 22785143].
202 Mendoza H, Martin MJ, Garcia A, et al. ‘Hospital at home’ care model as an effective alternative in the management of decompensated chronic heart failure. Eur J Heart Fail. Dec. 2009;11(12):1208-13. Exclusion Code: X3. [pmid: 19875400].
203 Metten L, Zueca F, Haver Y, et al. 22 Effects of intensified care for heart failure patients by telemonitoring. European Journal of Cardiovascular Nursing. 2011;10(s):S26-S. Language: English. Entry Date: 20130322. Revision Date: 20130419. Publication Type: journal article. Exclusion Code: X2.
204 Moertl D, Berger R, Hammer A, et al. B-type natriuretic peptide predicts benefit from a home-based nurse care in chronic heart failure. J Card Fail. Apr. 2009;15(3):233-40. Exclusion Code: X2. [pmid: 19327625].
205 Molloy GJ, Johnston DW, Gao C, et al. Effects of an exercise intervention for older heart failure patients on caregiver burden and emotional distress. Eur J Cardiovasc Prev Rehabil. Jun. 2006;13(3):381-7. Exclusion Code: X2. [pmid: 16926668].
206 Morcillo C, Valderas JM, Aguado O, et al. Evaluation of a home-based intervention in heart failure patients. Results of a randomized study. Rev Esp Cardiol. 2005;(6):618-25. CN-00528602. Exclusion Code: X1 (May be excluded).
207 Morguet AJ, Kuhnelt P, Kallel A, et al. Impact of telemedical care and monitoring on morbidity in mild to moderate chronic heart failure. Cardiology. 2008;111(2):134-9. Exclusion Code: X2. [pmid: 18376125].
208 Mortara A, Pinna GD, Johnson P, et al. Home telemonitoring in heart failure patients: the HHH study (Home or Hospital in Heart Failure). Eur J Heart Fail. 2009;11(3):312-8. Exclusion Code: X2. [pmid: 19228800].
209 Mudge A, Denaro C, Scott I, et al. The paradox of readmission: effect of a quality improvement program in hospitalized patients with heart failure. J Hosp Med. Mar. 2010;5(3):148-53. Exclusion Code: X6. [pmid: 20235283].
210 Mueller TM, Vuckovic KM, Knox DA, et al. Telemanagement of heart failure: a diuretic treatment algorithm for advanced practice nurses. Heart Lung. Sep-Oct. 2002;31(5):340-7. Exclusion Code: X1. [pmid: 12487012].
211 Murphy SA. Initiation Management Predischarge: Process for Assessment of Carvedilol Therapy in Heart Failure (IMPACT-HF). ACC Current Journal Review. 2004;13(7):41-2. Language: English. Entry Date: 20050729. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X3.
212 Murray MD, Young J, Hoke S, et al. Pharmacist intervention to improve medication adherence in heart failure: a randomized trial. Ann Intern Med. May. 15. 2007;146(10):714-25. Exclusion Code: X2. [pmid: 17502632].
213 Murray MD, Young JM, Morrow DG, et al. Methodology of an ongoing, randomized, controlled trial to improve drug use for elderly patients with chronic heart failure. The American journal of geriatric pharmacotherapy. 2004;(1):53-65. CN-00492778. Exclusion Code: X2. [pmid: 15555479].
214 Nanevicz T, Piette J, Zipkin D, et al. The feasibility of a telecommunications service in support of outpatient congestive heart failure care in a diverse patient population. Congest Heart Fail. 2000;6(3):140-5. Exclusion Code: X2. [pmid: 12029181].
215 Naylor M, Brooten D, Jones R, et al. Comprehensive discharge planning for the hospitalized elderly. A randomized clinical trial. Ann Intern Med. Jun. 15. 1994;120(12):999-1006. Exclusion Code: X2. [pmid: 8185149].
216 Naylor MD, Aiken LH, Kurtzman ET, et al. The care span: the importance of transitional care in achieving health reform. Health Aff (Millwood). Apr. 2011;30(4):746-54. Exclusion Code: X2. [pmid: 21471497].
217 Nechwatal RM, Duck C, Gruber G. Physical training as interval or continuous training in chronic heart failure for improving functional capacity, hemodynamics and quality of life--a controlled study. Z Kardiol. 2002;(4):328-37. CN-00389580. Exclusion Code: X3. [pmid: 12063705].
218 Nguyen V, Ducharme A, White M, et al. Lack of long-term benefits of a 6-month heart failure disease management program. J Card Fail. 2007;(4):287-93. CN-00589076. Exclusion Code: X6. [pmid: 17517349].
219 Nieboer AP, Schulz R, Matthews KA, et al. Spousal caregivers' activity restriction and depression: a model for changes over time. Soc Sci Med. Nov. 1998;47(9):1361-71. Exclusion Code: X2. [pmid: 9783879].
220 Nobel JJ, Norman GK. Emerging information management technologies and the future of disease management. Dis Manag. Winter. 2003;6(4):219-31. Exclusion Code: X2. [pmid: 14736346].
221 Nundy S, Razi RR, Dick JJ, et al. A text messaging intervention to improve heart failure self-management after hospital discharge in a largely African-American population: before-after study. J Med Internet Res. 2013;15(3):e53. Exclusion Code: X5. [pmid: 23478028].
222 o'Connor CM, Whellan DJ, Lee KL, et al. Efficacy and safety of exercise training in patients with chronic heart failure: HF-ACTION randomized controlled trial. JAMA. Apr. 8. 2009;301(14):1439-50. Exclusion Code: X2. [pmid: 19351941].
223 Ojeda S, Anguita M, Delgado M, et al. Short- and long-term results of a programme for the prevention of readmissions and mortality in patients with heart failure: are effects maintained after stopping the programme?. Eur J Heart Fail. Aug. 2005;7(5):921-6. Exclusion Code: X6. [pmid: 16051519].
224 Pandor A, Gomersall T, Stevens JW, et al. Remote monitoring after recent hospital discharge in patients with heart failure: a systematic review and network meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2013;(3). epub. DARE-12013029243. Exclusion.
225 Panella M, Marchisio S, Demarchi ML, et al. Reduced in-hospital mortality for heart failure with clinical pathways: the results of a cluster randomised controlled trial. Qual Saf Health Care. Oct. 2009;18(5):369-73. Exclusion Code: X3. [pmid: 19812099].
226 Panella M, Marchisio S, Di Mario G, et al. The effectiveness of an integrated care pathway for inpatient heart failure treatment: results of a trial in a community hospital. Journal of Integrated Care Pathways. 2005;9(1):21-8. Language: English. Entry Date: 20051202. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X3.
227 Panella M, Marchisio S, Gardini A, et al. A cluster randomized controlled trial of a clinical pathway for hospital treatment of heart failure: study design and population. BMC Health Serv Res. 2007;7:179. Exclusion Code: X3. [pmid: 17986361].
228 Pantilat SZ, o'Riordan DL, Dibble SL, et al. Hospital-based palliative medicine consultation: a randomized controlled trial. Arch Intern Med. 2010;(22):2038-40. CN-00770681. Exclusion Code: X2. [pmid: 21149765].
229 Paradis V, Cossette S, Frasure-Smith N, et al. The efficacy of a motivational nursing intervention based on the stages of change on self-care in heart failure patients. J Cardiovasc Nurs. Mar-Apr. 2010;25(2):130-41. Exclusion Code: X2. [pmid: 20168193].
230 Pare G, Moqadem K, Pineau G, et al. Clinical effects of home telemonitoring in the context of diabetes, asthma, heart failure and hypertension: a systematic review. J Med Internet Res. 2010;12(2):e21. Exclusion Code: X2. [pmid: 20554500].
231 Parry C, Min SJ, Chugh A, et al. Further application of the care transitions intervention: results of a randomized controlled trial conducted in a fee-for-service setting. Home Health Care Serv Q. 2009;28(2-3):84-99. Exclusion Code: X2. [pmid: 20182958].
232 Pascual CR, Galán EP, Guerrero JL, et al. Rationale and methods of the multicenter randomised trial of a heart failure management programme among geriatric patients (HF-Geriatrics). BMC Public Health. 2011:627. CN-00806731. Exclusion Code: X1. [pmid: 21819564].
233 Patel H, Shafazand M, Ekman I, et al. Home care as an option in worsening chronic heart failure -- a pilot study to evaluate feasibility, quality adjusted life years and cost-effectiveness. Eur J Heart Fail. Jul. 2008;10(7):675-81. Exclusion Code: X3. [pmid: 18573692].
234 Paterna S, Gaspare P, Fasullo S, et al. Normal-sodium diet compared with low-sodium diet in compensated congestive heart failure: is sodium an old enemy or a new friend?. Clin Sci (Lond). Feb. 2008;114(3):221-30. Exclusion Code: X6. [pmid: 17688420].
235 Patja K, Absetz P, Auvinen A, et al. Health coaching by telephony to support self-care in chronic diseases: clinical outcomes from The TERVA randomized controlled trial. BMC Health Serv Res. 2012;12:147. Exclusion Code: X5. [pmid: 22682298].
236 Peacock WFt, Remer EE, Aponte J, et al. Effective observation unit treatment of decompensated heart failure. Congest Heart Fail. Mar-Apr. 2002;8(2):68-73. Exclusion Code: X8. [pmid: 11927779].
237 Pearl A, Wright SP, Gamble GD, et al. The effect of an integrated care approach for heart failure on general practice. Fam Pract. Dec. 2003;20(6):642-5. Exclusion Code: X6. [pmid: 14701886].
238 Pearson S, Inglis SC, McLennan SN, et al. Prolonged effects of a home-based intervention in patients with chronic illness. Arch Intern Med. Mar. 27. 2006;166(6):645-50. Exclusion Code: X6. [pmid: 16567604].
239 Pecchia L, Schiraldi F, Verde S, et al. Evaluation of short-term effectiveness of the disease management program “Di.Pro.Di.” on continuity of care of patients with congestive heart failure. J Am Geriatr Soc. 2010;(8):1603-4. CN-00760374. Exclusion Code: X8. [pmid: 20942881].
240 Peters-Klimm F, Campbell S, Hermann K, et al. Case management for patients with chronic systolic heart failure in primary care: the HICMan exploratory randomised controlled trial. Trials. 2010;11:56. Exclusion Code: X2. [pmid: 20478035].
241 Peters-Klimm F, Muller-Tasch T, Schellberg D, et al. Rationale, design and conduct of a randomised controlled trial evaluating a primary care-based complex intervention to improve the quality of life of heart failure patients: HICMan (Heidelberg Integrated Case Management). BMC Cardiovasc Disord. 2007;7:25. Exclusion Code: X2. [pmid: 17716364].
242 Philbin EF, Rocco TA, Lindenmuth NW, et al. The results of a randomized trial of a quality improvement intervention in the care of patients with heart failure. The MISCHF Study Investigators. Am J Med. Oct. 15. 2000;109(6):443-9. Exclusion Code: X3. [pmid: 11042232].
243 Philbin EF, Weil HF, Erb TA, et al. Cardiology or primary care for heart failure in the community setting: process of care and clinical outcomes. Chest. Aug. 1999;116(2):346-54. Exclusion Code: X8. [pmid: 10453861].
244 Phillips CO, Singa RM, Rubin HR, et al. Complexity of program and clinical outcomes of heart failure disease management incorporating specialist nurse-led heart failure clinics. A meta-regression analysis. Eur J Heart Fail. Mar. 16. 2005;7(3):333-41. Exclusion Code: X8 (SR). [pmid: 15718173].
245 Phillips CO, Wright SM, Kern DE, et al. Comprehensive discharge planning with postdischarge support for older patients with congestive heart failure: a meta-analysis. JAMA. Mar. 17. 2004;291(11):1358-67. Exclusion Code: X8 (SR). [pmid: 15026403].
246 Pihl E, Cider Å, Strömberg A, et al. Exercise in elderly patients with chronic heart failure in primary care: Effects on physical capacity and health-related quality of life. European Journal of Cardiovascular Nursing. 2011;10(3):150-8. Language: English. Entry Date: 20110916. Revision Date: 20120727. Publication Type: journal article. Exclusion Code: X2. [pmid: 21470913].
247 Pinna GD, Maestri R, Andrews D, et al. Home telemonitoring of vital signs and cardiorespiratory signals in heart failure patients: system architecture and feasibility of the HHH model. Int J Cardiol. Sep. 3. 2007;120(3):371-9. Exclusion Code: X2. [pmid: 17189654].
248 Piotrowicz E, Baranowski R, Bilinska M, et al. A new model of home-based telemonitored cardiac rehabilitation in patients with heart failure: effectiveness, quality of life, and adherence. Eur J Heart Fail. Feb. 2010;12(2):164-71. Exclusion Code: X2. [pmid: 20042423].
249 Polisena J, Tran K, Cimon K, et al. Home telemonitoring for congestive heart failure: a systematic review and meta-analysis. J Telemed Telecare. 2010;16(2):68-76. Exclusion Code: X8 (SR). [pmid: 20008054].
250 Powell LH, Calvin JE Jr, Richardson D, et al. Self-management counseling in patients with heart failure: the heart failure adherence and retention randomized behavioral trial. JAMA. Sep. 22. 2010;304(12):1331-8. Exclusion Code: X6. [pmid: 20858878].
251 Prescott E, Hjardem-Hansen R, Dela F, et al. Effects of a 14-month low-cost maintenance training program in patients with chronic systolic heart failure: a randomized study. Eur J Cardiovasc Prev Rehabil. Aug. 2009;16(4):430-7. Exclusion Code: X5. [pmid: 19491687].
252 Proctor EK, Morrow-Howell N, Kaplan SJ. Implementation of discharge plans for chronically ill elders discharged home. Health Soc Work. Feb. 1996;21(1):30-40. Exclusion Code: X5. [pmid: 8626156].
253 Proctor EK, Morrow-Howell N, Li H, et al. Adequacy of home care and hospital readmission for elderly congestive heart failure patients. Health Soc Work. May. 2000;25(2):87-96. Exclusion Code: X3. [pmid: 10845143].
254 Pugh LC, Tringali RA, Boehmer J, et al. Partners in care: a model of collaboration. Holist Nurs Pract. 1999;13(2):61-5. Language: English. Entry Date: 19990701. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X1. [pmid: 10196904].
255 Quinn C. Low-technology heart failure care in home health: improving patient outcomes. Home Healthc Nurse. Sep. 2006;24(8):533-40. Exclusion Code: X2. [pmid: 17012959].
256 Radhakrishnan K, Jacelon C. Impact of Telehealth on Patient Self-management of Heart Failure: A Review of Literature. J Cardiovasc Nurs. 2012. Jan-Feb. 2012;27(1):33-43. Language: English. Entry Date: 20120217. Revision Date: 20120217. Publication Type: journal article. Exclusion Code: X5. [pmid: 21558862].
257 Ramaekers BL, Janssen-Boyne JJ, Gorgels AP, et al. Adherence among telemonitored patients with heart failure to pharmacological and nonpharmacological recommendations. Telemed J E Health. Jul-Aug. 2009;15(6):517-24. Exclusion Code: X5. [pmid: 19566401].
258 Ritchie C, Richman J, Sobko H, et al. The E-coach transition support computer telephony implementation study: protocol of a randomized trial. Contemp Clin Trials. Nov. 2012;33(6):1172-9. Exclusion Code: X5. [pmid: 22922245].
259 Rosenman MB, Holmes AM, Ackermann RT, et al. The Indiana Chronic Disease Management Program. Milbank Q. 2006;84(1):135-63. Exclusion Code: X1. [pmid: 16529571].
260 Roth A, Kajiloti I, Elkayam I, et al. Telecardiology for patients with chronic heart failure: the ‘SHL’ experience in Israel. Int J Cardiol. Oct. 2004;97(1):49-55. Exclusion Code: X2. [pmid: 15336806].
261 Roth A, Korb H, Gadot R, et al. Telecardiology for patients with acute or chronic cardiac complaints: the ‘SHL’ experience in Israel and Germany. Int J Med Inform. Sep. 2006;75(9):643-5. Exclusion Code: X8. [pmid: 16765634].
262 Savard LA, Thompson DR, Clark AM. A meta-review of evidence on heart failure disease management programs: the challenges of describing and synthesizing evidence on complex interventions. Trials. 2011;12:194. Exclusion Code: X8 (SR). [pmid: 21846340].
263 Scalvini S, Capomolla S, Zanelli E, et al. Effect of home-based telecardiology on chronic heart failure: costs and outcomes. J Telemed Telecare. 2005;1:16-8. Exclusion Code: X2. [pmid: 16035980].
264 Scalvini S, Zanelli E, Paletta L, et al. Chronic heart failure home-based management with a telecardiology system: a comparison between patients followed by general practitioners and by a cardiology department. J Telemed Telecare. 2006;1:46-8. Exclusion Code: X8. [pmid: 16884578].
265 Scalvini S, Zanelli E, Volterrani M, et al. A pilot study of nurse-led, home-based telecardiology for patients with chronic heart failure. J Telemed Telecare. 2004;10(2):113-7. Exclusion Code: X2. [pmid: 15068649].
266 Scherr D, Kastner P, Kollmann A, et al. Effect of home-based telemonitoring using mobile phone technology on the outcome of heart failure patients after an episode of acute decompensation: randomized controlled trial. J Med Internet Res. 2009;11(3):e34. Exclusion Code: X2. [pmid: 19687005].
267 Schmidt S, Schuchert A, Krieg T, et al. Home telemonitoring in patients with chronic heart failure: a chance to improve patient care?. Dtsch Arztebl Int. Feb. 2010;107(8):131-8. Exclusion Code: X8 (SR). [pmid: 20300221].
268 Schneider JK, Hornberger S, Booker J, et al. A medication discharge planning program: measuring the effect on readmissions. Clin Nurs Res. Feb. 1993;2(1):41-53. Exclusion Code: X8. [pmid: 8453387].
269 Schou M, Gustafsson F, Videbaek L, et al. Extended heart failure clinic follow-up in low-risk patients: a randomized clinical trial (NorthStar). Eur Heart J. Feb. 2013;34(6):432-42. Exclusion Code: X2. [pmid: 22875412].
270 Scott LD, Setter-Kline K, Britton AS. The effects of nursing interventions to enhance mental health and quality of life among individuals with heart failure. Appl Nurs Res. Nov. 2004;17(4):248-56. Exclusion Code: X2. [pmid: 15573333].
271 Seibert PS, Whitmore TA, Patterson C, et al. Telemedicine facilitates CHF home health care for those with systolic dysfunction. Int J Telemed Appl. 2008;235031(10):235031. Exclusion Code: X2. [pmid: 18369411].
272 Senden PJ, Sabelis LW, Zonderland ML, et al. The effect of physical training on workload, upper leg muscle function and muscle areas in patients with chronic heart failure. Int J Cardiol. Apr. 20. 2005;100(2):293-300. Exclusion Code: X2. [pmid: 15823638].
273 Seto E. Cost comparison between telemonitoring and usual care of heart failure: a systematic review. Telemed J E Health. Sep. 2008;14(7):679-86. Exclusion Code: X1. [pmid: 18817497].
274 Seto E, Leonard KJ, Cafazzo JA, et al. Mobile phone-based telemonitoring for heart failure management: a randomized controlled trial. J Med Internet Res. 2012;14(1):e31. Exclusion Code: X2. [pmid: 22356799].
275 Seto E, Leonard KJ, Cafazzo JA, et al. Developing healthcare rule-based expert systems: case study of a heart failure telemonitoring system. Int J Med Inform. Aug. 2012;81(8):556-65. Exclusion Code: X2. [pmid: 22465288].
276 Shah MR, Flavell CM, Weintraub JR, et al. Intensity and focus of heart failure disease management after hospital discharge. Am Heart J. Apr. 2005;149(4):715-21. Exclusion Code: X5. [pmid: 15990758].
277 Shah MR, Whellan DJ, Peterson ED, et al. Delivering heart failure disease management in 3 tertiary care centers: key clinical components and venues of care. Am Heart J. Apr. e1. 2008;155(4):764-5. Exclusion Code: X5. [pmid: 18371490].
278 Shah NB, Der E, Ruggerio C, et al. Prevention of hospitalizations for heart failure with an interactive home monitoring program. Am Heart J. 1998;135(3):373-8. Exclusion Code: X2. [pmid: 9506321].
279 Shearer NB, Cisar N, Greenberg EA. A telephone-delivered empowerment intervention with patients diagnosed with heart failure. Heart Lung. May-Jun. 2007;36(3):159-69. Exclusion Code: X5. [pmid: 17509423].
280 Sisk JE, Hebert PL, Horowitz CR, et al. Effects of nurse management on the quality of heart failure care in minority communities: a randomized trial. Ann Intern Med. Aug. 15. 2006;145(4):273-83. Exclusion Code: X2. [pmid: 16908918].
281 Smart NA, Steele M. A comparison of 16 weeks of continuous vs intermittent exercise training in chronic heart failure patients. Congest Heart Fail. Jul-Aug. 2012;18(4):205-11. Exclusion Code: X2. [pmid: 22809258].
282 Smeulders ES, van Haastregt JC, Ambergen T, et al. The impact of a self-management group programme on health behaviour and healthcare utilization among congestive heart failure patients. Eur J Heart Fail. Jun. 2009;11(6):609-16. Exclusion Code: X2. [pmid: 19359326].
283 Smeulders ES, van Haastregt JC, Ambergen T, et al. Nurse-led self-management group programme for patients with congestive heart failure: randomized controlled trial. J Adv Nurs. Jul. 2010;66(7):1487-99. Exclusion Code: X2. [pmid: 20492026].
284 Smeulders ES, van Haastregt JC, Janssen-Boyne JJ, et al. Feasibility of a group-based self-management program among congestive heart failure patients. Heart Lung. Nov-Dec. 2009;38(6):499-512. Exclusion Code: X5. [pmid: 19944874].
285 Sochalski J, Jaarsma T, Krumholz HM, et al. What works in chronic care management: the case of heart failure. Health Aff (Millwood). 2009. Jan-Feb. 2009;28(1):179-89. Language: English. Entry Date: 20090306. Revision Date: 20110513. Publication Type: journal article. Exclusion Code: X8. [pmid: 19124869].
286 Sofer D. APNs: improved outcomes at lower costs: older adults with heart failure fare better with transitional care after hospitalization. Am J Nurs. Sep. 2004;104(9):19. Exclusion Code: X1. [pmid: 15365321].
287 Soran OZ, Feldman AM, Pina IL, et al. Cost of medical services in older patients with heart failure: those receiving enhanced monitoring using a computer-based telephonic monitoring system compared with those in usual care: the Heart Failure Home Care trial. J Card Fail. Nov. 2010;16(11):859-66. Exclusion Code: X2. [pmid: 21055649].
288 Soran OZ, Pina IL, Lamas GA, et al. A randomized clinical trial of the clinical effects of enhanced heart failure monitoring using a computer-based telephonic monitoring system in older minorities and women. J Card Fail. Nov. 2008;14(9):711-7. Exclusion Code: X2. [pmid: 18995174].
289 Spruit MA, Eterman RM, Hellwig VA, et al. Effects of moderate-to-high intensity resistance training in patients with chronic heart failure. Heart. Sep. 2009;95(17):1399-408. Exclusion Code: X5. [pmid: 19342376].
290 Stauffer BD, Fullerton C, Fleming N, et al. Effectiveness and cost of a transitional care program for heart failure: a prospective study with concurrent controls. Arch Intern Med. Jul. 25. 2011;171(14):1238-43. Exclusion Code: X8. [pmid: 21788541].
291 Stewart, Vandenbroek, Pearson. Prolonged beneficial effects of a home-based intervention on unplanned readmissions and mortality among congestive heart failure patients. [abstract]. Aust N Z J Med. 1999:112. CN-00319319. Exclusion Code: X6.
292 Stewart S, Carrington MJ, Marwick TH, et al. Impact of home versus clinic-based management of chronic heart failure: the WHICH? (Which Heart Failure Intervention Is Most Cost-Effective & Consumer Friendly in Reducing Hospital Care) multicenter, randomized trial. J Am Coll Cardiol. Oct. 2. 2012;60(14):1239-48. Exclusion Code: X2. [pmid: 23017533].
293 Stewart S, Horowitz JD. Home-based intervention in congestive heart failure: long-term implications on readmission and survival. Circulation. Jun. 18. 2002;105(24):2861-6. Exclusion Code: X6. [pmid: 12070114].
294 Stewart S, Horowitz JD. Detecting early clinical deterioration in chronic heart failure patients post-acute hospitalisation-a critical component of multidisciplinary, home-based intervention?. Eur J Heart Fail. Jun. 2002;4(3):345-51. Exclusion Code: X8. [pmid: 12034161].
295 Stewart S, Vandenbroek AJ, Pearson S, et al. Prolonged beneficial effects of a home-based intervention on unplanned readmissions and mortality among patients with congestive heart failure. Arch Intern Med. Feb. 8. 1999;159(3):257-61. Exclusion Code: X6. [pmid: 9989537].
296 Stewart S, Vandenbroek AJ, Pearson S, et al. A home-based intervention reduced out-of-hospital deaths and hospitalizations in CHF… including commentary by Farmer A. Evidence Based Medicine. 1999;4(4):115. Language: English. Entry Date: 19991001. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X1.
297 Stromberg A, Dahlstrom U, Fridlund B. Computer-based education for patients with chronic heart failure. A randomised, controlled, multicentre trial of the effects on knowledge, compliance and quality of life. Patient Educ Couns. Dec. 2006;64(1-3):128-35. Exclusion Code: X2. [pmid: 16469469].
298 Subramanian U, Hopp F, Lowery J, et al. Research in home-care telemedicine: challenges in patient recruitment. Telemed J E Health. Summer. 2004;10(2):155-61. Exclusion Code: X1. [pmid: 15319045].
299 Sullivan MJ, Wood L, Terry J, et al. The Support, Education, and Research in Chronic Heart Failure Study (SEARCH): a mindfulness-based psychoeducational intervention improves depression and clinical symptoms in patients with chronic heart failure. Am Heart J. Jan. 2009;157(1):84-90. Exclusion Code: X3. [pmid: 19081401].
300 Supervia A, Aranda D, Marquez MA, et al. Predicting length of hospitalisation of elderly patients, using the Barthel Index. Age Ageing. May. 2008;37(3):339-42. Exclusion Code: X3. [pmid: 18339617].
301 Swanson KS, Gevirtz RN, Brown M, et al. The effect of biofeedback on function in patients with heart failure. Appl Psychophysiol Biofeedback. Jun. 2009;34(2):71-91. Exclusion Code: X2. [pmid: 19205870].
302 Tabidze GA, Kobaladze NI, Tsibadze TA. Assessment of efficiency of patients ' therapeutic education in chronic heart failure treatment. Georgian medical news. 2009;(175):35-8. CN-00743741. Exclusion Code: X1. [pmid: 19893122].
303 Tai M, Meininger JC, Frazier LQ. A systematic review of exercise interventions in patients with heart failure. Biological Research for Nursing. 2008;10(2):156-82. Language: English. Entry Date: 20090116. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X3. [pmid: 18829599].
304 Takeda A, Taylor SJ, Taylor RS, et al. Clinical service organisation for heart failure. Cochrane Database Syst Rev. 2012;9:CD002752. Exclusion Code: X8 (SR). [pmid: 22972058].
305 Taylor Rod S, Dalal H, Jolly K, et al. Home-based versus centre-based cardiac rehabilitation. Cochrane Database of Systematic Reviews. Exclusion Code: X2. 2010;(1):CD007130. [pmid: 20091618].
306 Thomas R, Huntley A, Mann M, et al. Specialist clinics for reducing emergency admissions in patients with heart failure: a systematic review and meta-analysis of randomised controlled trials. Heart. Feb. 2013;99(4):233-9. Exclusion Code: X8 (SR). [pmid: 23355639].
307 Tomita MR, Tsai BM, Fisher NM, et al. Improving adherence to exercise in patients with heart failure through internet-based self-management. J Am Geriatr Soc. 2008;(10):1981-3. CN-00667339. Exclusion Code: X5. [pmid: 19054217].
308 Tompkins C, Orwat J. A Randomized Trial of Telemonitoring Heart Failure Patients. J Healthc Manag. 2010;55(5):312-22. Language: English. Entry Date: 20110107. Revision Date: 20110805. Publication Type: journal article. Exclusion Code: X2. [pmid: 21077581].
309 Topp R, Tucker D, Weber C. Effect of a clinical case manager/clinical nurse specialist on patients hospitalized with congestive heart failure. Nurs Case Manag. 1998;(4):140-7. CN-00497710. Exclusion Code: X8. [pmid: 9856058].
310 Tran K, Polisena J, Coyle D, et al. Home telehealth for chronic disease management (Structured abstract). Database of Abstracts of Reviews of Effects. 2008;(1):1. DARE-12010008017. Exclusion Code: X2.
311 Tribouilloy C, Rusinaru D, Mahjoub H, et al. Impact of echocardiography in patients hospitalized for heart failure: a prospective observational study. Arch Cardiovasc Dis. Jul-Aug. 2008;101(7-8):465-73. Exclusion Code: X3. [pmid: 18848689].
312 Tsuchihashi-Makaya M, Matsuo H, Kakinoki S, et al. Home-based disease management program to improve psychological status in patients with heart failure in Japan. Circ J. 2013;77(4):926-33. Exclusion Code: X6. [pmid: 23502992].
313 Turner DA, Paul S, Stone MA, et al. Cost-effectiveness of a disease management programme for secondary prevention of coronary heart disease and heart failure in primary care. Heart. 2008;94(12):1601-6. Language: English. Entry Date: 20090213. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X2. [pmid: 18450843].
314 Tyni-Lenné R, Gordon A, Sylvén C. Improved quality of life in chronic heart failure patients following local endurance training with leg muscles. J Card Fail. 1996;(2):111-7. CN-00129813. Exclusion Code: X2. [pmid: 8798112].
315 Valle R, Canali C, Giovinazzo P, et al. Is early discharge possible in patients with uncomplicated heart failure? Cost-efficacy analysis]. Italian heart journal. Supplement : official journal of the Italian Federation of Cardiology. 2003;(12):965-72. CN-00489029. Exclusion Code: X1.
316 Valle R, Carbonieri E, Tenderini P, et al. Proposed protocol for the ambulatory management of patients discharged with heart failure diagnosis: collaborative project Venice-HF. Italian heart journal. Supplement : official journal of the Italian Federation of Cardiology. 2004;(4):282-91. CN-00489742. Exclusion Code: X1.
317 Vallina H, Effken J. Telemonitoring and heart failure outcomes. Commun Nurs Res. 2010;43:433. Language: English. Entry Date: 20101210. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X8.
318 van der Meer S, Zwerink M, van Brussel M, et al. Effect of outpatient exercise training programmes in patients with chronic heart failure: a systematic review. Eur J Prev Cardiol. Aug. 2012;19(4):795-803. Exclusion Code: X3. [pmid: 22988592].
319 Varma S, McElnay JC, Hughes CM, et al. Pharmaceutical care of patients with congestive heart failure: interventions and outcomes. Pharmacotherapy. Jul. 1999;19(7):860-9. Exclusion Code: X2. [pmid: 10417035].
320 Vavouranakis I, Lambrogiannakis E, Markakis G, et al. Effect of home-based intervention on hospital readmission and quality of life in middle-aged patients with severe congestive heart failure: a 12-month follow up study. European Journal of Cardiovascular Nursing. 2003;2(2):105-11. Language: English. Entry Date: 20031017. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X6. [pmid: 14622635].
321 Veroff DR, Sullivan LA, Shoptaw EJ, et al. Improving self-care for heart failure for seniors: the impact of video and written education and decision aids. Popul Health Manag. Feb. 2012;15(1):37-45. Exclusion Code: X2. [pmid: 22004181].
322 Villani A, Malfatto G, Della Rosa F, et al. Disease management for heart failure patients: role of wireless technologies for telemedicine. The ICAROS project. Giornale italiano di cardiologia (2006). 2007;(2):107-14. CN-00579624. Exclusion Code: X1. [pmid: 17402355].
323 Vinson JM, Rich MW, Sperry JC, et al. Early readmission of elderly patients with congestive heart failure. J Am Geriatr Soc. Dec. 1990;38(12):1290-5. Exclusion Code: X3. [pmid: 2254567].
324 Wade MJ, Desai AS, Spettell CM, et al. Telemonitoring with case management for seniors with heart failure. Am J Manag Care. Mar. 2011;17(3):e71-9. Exclusion Code: X2. [pmid: 21504262].
325 Wakefield BJ, Boren SA, Groves PS, et al. Heart Failure Care Management Programs: A Review of Study Interventions and Meta-Analysis of Outcomes. J Cardiovasc Nurs. 2013. Jan-Feb. 2013;28(1):8-19. Language: English. Entry Date: 20130215. Revision Date: 20130215. Publication Type: journal article. Exclusion Code: X8 (SR). [pmid: 22343208].
326 Wall HK, Ballard J, Troped P, et al. Impact of home-based, supervised exercise on congestive heart failure. Int J Cardiol. 2010;(2):267-70. CN-00813626. Exclusion Code: X2. [pmid: 19854523].
327 Wang SP, Lin LC, Lee CM, et al. Effectiveness of a self-care program in improving symptom distress and quality of life in congestive heart failure patients: a preliminary study. J Nurs Res. Dec. 2011;19(4):257-66. Exclusion Code: X8. [pmid: 22089651].
328 Weinberger M, Oddone EZ, Henderson WG. Does increased access to primary care reduce hospital readmissions? Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. N Engl J Med. May. 30. 1996;334(22):1441-7. Exclusion Code: X2. [pmid: 8618584].
329 Weintraub A, Gregory D, Patel AR, et al. A multicenter randomized controlled evaluation of automated home monitoring and telephonic disease management in patients recently hospitalized for congestive heart failure: the SPAN-CHF II trial. J Card Fail. Apr. 2010;16(4):285-92. Exclusion Code: X2. [pmid: 20350694].
330 Wheeler EC, Waterhouse JK. Telephone interventions by nursing students: improving outcomes for heart failure patients in the community. J Community Health Nurs. Fall. 2006;23(3):137-46. Exclusion Code: X2. [pmid: 16863399].
331 Whellan DJ, Hasselblad V, Peterson E, et al. Metaanalysis and review of heart failure disease management randomized controlled clinical trials. Am Heart J. Apr. 2005;149(4):722-9. Exclusion Code: X8 (SR). [pmid: 15990759].
332 White M, Garbez R, Carroll M, et al. Is “teach-back” associated with knowledge retention and hospital readmission in hospitalized heart failure patients?. J Cardiovasc Nurs. Mar-Apr. 2013;28(2):137-46. Exclusion Code: X4. [pmid: 22580624].
333 Whitten P, Bergman A, Meese MA, et al. St. Vincent's Home telehealth for congestive heart failure patients. Telemed J E Health. 2009;15(2):148-53. Exclusion Code: X2. [pmid: 19292623].
334 Whitten P, Mickus M. Home telecare for COPD/CHF patients: outcomes and perceptions. J Telemed Telecare. 2007;(2):69-73. CN-00609354. Exclusion Code: X2. [pmid: 17359569].
335 Wielenga RP, Huisveld IA, Bol E, et al. Exercise training in elderly patients with chronic heart failure. [corrected] [published erratum appears in CORONARY ARTERY DIS 1999; 10(1): 57]. Coron Artery Dis. 1998;9(11):765-70. Language: English. Entry Date: 19991101. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X2. [pmid: 9919425].
336 Wierzchowiecki M, Poprawski K, Nowicka A, et al. New multidisciplinary heart failure care program (six-month preliminary observation). Polski merkuriusz lekarski : organ Polskiego Towarzystwa Lekarskiego. 2006;(126):511-5. CN-00587715. Exclusion Code: X1. [pmid: 17405287].
337 Wierzchowiecki M, Poprawski K, Nowicka A, et al. A new programme of multidisciplinary care for patients with heart failure in Poznan: one-year follow-up. Kardiol Pol. Oct. 2006;64(10):1063-70. discussion 71-2. Exclusion Code: X6. [pmid: 17089238].
338 Winkelmann ER, Chiappa GR, Lima CO, et al. Addition of inspiratory muscle training to aerobic training improves cardiorespiratory responses to exercise in patients with heart failure and inspiratory muscle weakness. Am Heart J. Nov. e1. 2009;158(5):768-7. Exclusion Code: X2. [pmid: 19853695].
339 Witham MD, Fulton RL, Greig CA, et al. Efficacy and cost of an exercise program for functionally impaired older patients with heart failure: a randomized controlled trial. Circ Heart Fail. Mar. 1. 2012;5(2):209-16. Exclusion Code: X2. [pmid: 22271753].
340 Wongpiriyayothar A, Pothiban L, Liehr P, et al. Effects of home-based care program on symptom alleviation and well-being among persons with chronic heart failure. Thai Journal of Nursing Research. 2008. Jan-Mar. 2008;12(1):25-39. Language: English. Entry Date: 20080606. Revision Date: 20101231. Publication Type: journal article. Exclusion Code: X5.
341 Wootton R, Gramotnev H, Hailey D. A randomized controlled trial of telephone-supported care coordination in patients with congestive heart failure. J Telemed Telecare. 2009;15(4):182-6. Exclusion Code: X2. [pmid: 19471029].
342 Wright SP, Walsh H, Ingley KM, et al. Uptake of self-management strategies in a heart failure management programme. Eur J Heart Fail. Jun. 2003;5(3):371-80. Exclusion Code: X6. [pmid: 12798837].
343 Yamada S, Shimizu Y, Suzuki M, et al. Functional limitations predict the risk of rehospitalization among patients with chronic heart failure. Circ J. 2012;76(7):1654-61. Exclusion Code: X2. [pmid: 22484978].
344 Yancy CW, Abraham WT, Albert NM, et al. Quality of care of and outcomes for African Americans hospitalized with heart failure: findings from the OPTIMIZE-HF (Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients With Heart Failure) registry. J Am Coll Cardiol. Apr. 29. 2008;51(17):1675-84. Exclusion Code: X4. [pmid: 18436120].
345 Yehle KS, Plake KS. Self-efficacy and educational interventions in heart failure: a review of the literature. J Cardiovasc Nurs. May-Jun. 2010;25(3):175-88. Exclusion Code: X5. [pmid: 20386241].
346 Yu DS, Thompson DR, Lee DT. Disease management programmes for older people with heart failure: crucial characteristics which improve post-discharge outcomes. Eur Heart J. Mar. 2006;27(5):596-612. Exclusion Code: X6. [pmid: 16299021].
347 Zugck C, Nelles M, Frankenstein L, et al. Telemonitoring in chronic heart failure patients. Which diagnostic finding prevents hospital readmission?. Herzschrittmachertherapie & Elektrophysiologie. 2005;(3):176. CN-00530465. Exclusion Code: X1. [pmid: 16177944].
348 Zwisler AD, Schou L, Soja AM, et al. A randomized clinical trial of hospital-based, comprehensive cardiac rehabilitation versus usual care for patients with congestive heart failure, ischemic heart disease, or high risk of ischemic heart disease (the DANREHAB trial)--design, intervention, and population. Am Heart J. 2005;(5):899. CN-0051971. Exclusion Code: X1. [pmid: 16290957].
349 Zwisler AD, Soja AM, Rasmussen S, et al. Hospital-based comprehensive cardiac rehabilitation versus usual care among patients with congestive heart failure, ischemic heart disease, or high risk of ischemic heart disease: 12-month results of a randomized clinical trial. Am Heart J. Jun. 2008;155(6):1106-13. Exclusion Code: X2. [pmid: 18513526].