# Literature Search Strategies

## Published Literature

4/26/13 PubMed: 1,295 records retrieved

Search String | Search Terms | Number of Results
#1 | Search (“congestive heart failure” OR “heart failure, congestive” OR “heart failure”[mesh]) | 95,131
#2 | Search (Readmission OR rehospitalization OR recurrence[mesh] OR “patient readmission”[mesh]) | 161,929
#3 | Search (“case management”[mesh] OR “rehabilitation”[mesh] OR “continuity of patient care”[mesh] OR “patient discharge”[mesh] OR “patient transfer”[mesh] OR transition* OR postdischarge OR post-discharge OR coordination OR coordinate OR transfer OR post-acute care OR postacute care OR post-hospital* OR posthospital* OR subacute care OR sub-acute care OR discharge OR referral OR continuity OR “critical pathways”[MeSH Terms] OR “critical pathways”[Text Word] OR “critical pathway”[All Fields] OR “critical path”[all fields] OR “critical paths”[all fields] OR “clinical path” [all fields] OR “clinical paths” [all fields] OR “clinical pathway” [all fields] OR “clinical pathways”[all fields] OR “telemedicine”[MeSH Terms] OR telemedicine[Text Word] OR telehealth[all fields] OR eHealth[all fields] OR “Mobile Health”[all fields] OR “Home Care Services, Hospital-Based”[MeSH] OR “Hospital Based Home Cares”[All Fields] OR “Hospital Home Care Services”[All Fields] OR “Hospital-Based Home Care”[All Fields] OR “Hospital Based Home Care”[All Fields] OR “Hospital-Based Home Cares”[All Fields] OR “home nursing”[MeSh] OR “Nonprofessional Home Care”[All Fields] OR “home nursing”[all fields] OR “Non-Professional Home Care”[All Fields] OR “Physical Therapy Modalities”[MeSH] OR “physical therapy”[All Fields] OR “physical therapies”[all fields] OR “Exercise Therapy”[MeSH] OR “exercise therapy”[All Fields]) | 1,132,712
#4 | Search (((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH])) | 533,347
#5 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 106,432
#6 | Search (“prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type]) | 520,244
#7 | Search (#1 AND (#2 OR #3) AND (#5 OR #4)) | 1,116
#8 | Search (#1 AND (#2 OR #3) AND #6) | 1,123
#9 | Search ((Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Congresses[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR In Vitro[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Lectures[Publication Type] OR Legal Cases[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Personal Narratives[Publication Type] OR Periodical Index[Publication Type] OR Pictorial works[Publication Type] OR Popular works[Publication Type] OR Portraits[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type] OR Webcasts[Publication Type])) | 3,486,741
#10 | Search (#7 NOT #9) | 1,094
#11 | Search (#7 NOT #9) Filters: Humans | 1,075
#12 | Search(#7 NOT #9) Filters: Humans; English | 1,009
#13 | Search (#7 NOT #9) Filters: Publication date from 2007/07/01; Humans; English | 511
#14 | Search (#8 NOT #9) | 1,109
#15 | Search (#8 NOT #9) Filters: Humans | 1,100
#16 | Search (#8 NOT #9) Filters: Humans; English | 1,044
#17 | Search (#8 NOT #9) Filters: Publication date from 1990/01/01; Humans; English | 1,017
#18 | Search (#13 OR #17) | 1,295

4/26/13 Cochrane Library: 1,174 records retrieved

Search String | Search Terms | Number of Results
#1 | “congestive heart failure” or “heart failure, congestive” | 3,574
#2 | MeSH descriptor: [Heart Failure] explode all trees | 4,968
#3 | #1 or #2 | 7,003
#4 | MeSH descriptor: [Recurrence] explode all trees | 11,228
#5 | MeSH descriptor: [Patient Readmission] explode all trees | 651
#6 | readmission or rehospitalization | 2,540
#7 | #4 or #5 or #6 | 13,619
#8 | MeSH descriptor: [Case Management] explode all trees | 569
#9 | MeSH descriptor: [Rehabilitation] explode all trees | 12,409
#10 | MeSH descriptor: [Continuity of Patient Care] explode all trees | 448
#11 | MeSH descriptor: [Patient Discharge] explode all trees | 910
#12 | MeSH descriptor: [Patient Transfer] explode all trees | 103
#13 | MeSH descriptor: [Critical Pathways] explode all trees | 223
#14 | MeSH descriptor: [Telemedicine] explode all trees | 961
#15 | MeSH descriptor: [Home Care Services, Hospital-Based] explode all trees | 227
#16 | MeSH descriptor: [Home Nursing] explode all trees | 297
#17 | MeSH descriptor: [Physical Therapy Modalities] explode all trees | 12,939
#18 | MeSH descriptor: [Exercise Therapy] explode all trees | 5,562
#19 | transition* or postdischarge or “post-discharge” or coordination or coordinate or transfer or “post-acute care” or “postacute care” or post-hospital* or posthospital* or “subacute care” or “sub-acute care” or discharge or referral or continuity or “critical pathways” or “critical pathway” or “critical path” or “critical paths” or “clinical path” or “clinical paths” or “clinical pathway” or “clinical pathways” or telemedicine or telehealth or eHealth or “Mobile Health” or “Hospital Based Home Cares” or “Hospital Home Care Services” or “Hospital-Based Home Care” or “Hospital Based Home Care” or “Hospital-Based Home Cares” or “Nonprofessional Home Care” or “home nursing” or “Non-Professional Home Care” or “physical therapy” or “physical therapies” or “exercise therapy” | 42,217
#20 | #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 | 53,644
#21 | #3 and (#7 or #20) | 1,431
#22 | #3 and (#7 or #20) in Trials | 889
#23 | #3 and (#7 or #20) from 1990, in Trials | 866
#24 | #3 and (#7 or #20) in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 375
#25 | #3 and (#7 or #20) from 2007, in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 308
#26 | #23 or #25 | 1,174

4/26/13 CINAHL: 283 records retrieved

Search String | Search Terms | Number of Results
S1 | (MH “Heart Failure”) | 16,241
S2 | ( (MH “Recurrence”) OR (MH “Readmission”) ) | 19,303
S3 | ((MH “Case Management”) OR (MH “Rehabilitation”) OR (MH “Continuity of Patient Care”) OR (MH “Patient Discharge”) OR (MH “Transfer, Discharge”) OR (MH “Critical Path”) OR (MH “Telemedicine”) OR (MH “Telehealth”) OR (MH “Home Health Care”) OR (MH “Home Rehabilitation”) OR (MH “Home Nursing”) OR (MH “Physical Therapy”) OR (MH “Therapeutic Exercise”)) | 82,649
S4 | (MH “Randomized Controlled Trials”) OR (MH “Nonrandomized Trials”) OR (MH “Single-Blind Studies”) OR (MH “Double-Blind Studies”) OR (MH “Random Assignment”) | 56,419
S5 | ( (MH “Meta Analysis”) OR (MH “Systematic Review”) ) | 23,286
S6 | (MH “Prospective Studies”) OR (MH “Clinical Trials”) | 210,981
S7 | S1 AND (S2 OR S3) AND (S5 OR S4) | 148
S8 | S1 AND (S2 OR S3) AND S6 | 342
S9 | Search (S7) Limiters - Human | 116
S10 | Search(S7) Limiters - Human; Language: English | 115
S11 | Search (S7) Limiters - Published Date from: 20070701-20130431; Human; Language: English | 70
S12 | Search (S8) Limiters - Human | 257
S13 | Search (S8) Limiters - Human; Language: English | 254
S14 | Search (S8) Limiters - Published Date from: 19900101-20130431; Human; Language: English | 254
S15 | S11 OR S14 | 302
S16 | (MH “Autobiographies”) OR (MH “Biographies”) OR (MH “Bibliography and References”) OR (MH “Bibliography, Descriptive”) OR (MH “Case Studies”) OR (MH “Congresses and Conferences”) OR (MH “Reference Books”) OR (MH “Edit and Review”) OR (MH “In Vitro Studies”) OR (MH “Interviews”) OR (MH “Lecture”) OR (MH “Legal Procedure”) OR (MH “Legislation”) OR (MH “News”) OR (MH “Newspapers”) OR (MH “Historical Records”) OR (MH “Narratives”) OR (MH “Life Histories”) OR (MH “Videorecording”) OR (MH “Audiovisuals”) OR (MH “Audiorecording”) OR (MH “World Wide Web Applications”) | 191483
S17 | S15 NOT S16 | 283

10/29/13 PubMed: 146 records retrieved

Search String | Search Terms | Number of Results
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“congestive heart failure” OR “heart failure, congestive” OR “heart failure”[mesh]) | 97,773 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Readmission OR rehospitalization OR recurrence[mesh] OR “patient readmission”[mesh]) | 165,738 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“case management”[mesh] OR “rehabilitation”[mesh] OR “continuity of patient care”[mesh] OR “patient discharge”[mesh] OR “patient transfer”[mesh] OR transition* OR postdischarge OR post-discharge OR coordination OR coordinate OR transfer OR post-acute care OR postacute care OR post-hospital* OR posthospital* OR subacute care OR sub-acute care OR discharge OR referral OR continuity OR “critical pathways”[MeSH Terms] OR “critical pathways”[Text Word] OR “critical pathway”[All Fields] OR “critical path”[all fields] OR “critical paths”[all fields] OR “clinical path” [all fields] OR “clinical paths” [all fields] OR “clinical pathway” [all fields] OR “clinical pathways”[all fields] OR “telemedicine”[MeSH Terms] OR telemedicine[Text Word] OR telehealth[all fields] OR eHealth[all fields] OR “Mobile Health”[all fields] OR “Home Care Services, Hospital-Based”[MeSH] OR “Hospital Based Home Cares”[All Fields] OR “Hospital Home Care Services”[All Fields] OR “Hospital-Based Home Care”[All Fields] OR “Hospital Based Home Care”[All Fields] OR “Hospital-Based Home Cares”[All Fields] OR “home nursing”[MeSh] OR “Nonprofessional Home Care”[All Fields] OR “home nursing”[all fields] OR “Non-Professional Home Care”[All Fields] OR “Physical Therapy Modalities”[MeSH] OR “physical therapy”[All Fields] OR “physical therapies”[all fields] OR “Exercise Therapy”[MeSH] OR “exercise therapy”[All Fields]) | 1,172,735 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH])) | 548,807 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 115,368 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“prospective cohort” OR “prospective studies”[MeSH] OR (prospective*[All Fields] AND cohort[All Fields] AND (study[All Fields] OR studies[All Fields])) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type]) | 538,994 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND (#2 OR #3) AND (#5 OR #4)) | 1,172 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND (#2 OR #3) AND #6) | 1,171 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((Autobiography[Publication Type] OR Bibliography[Publication Type] OR Biography[Publication Type] OR Case Reports[Publication Type] OR Classical Article[Publication Type] OR comment[Publication Type] OR Congresses[Publication Type] OR Consensus Development Conference[Publication Type] OR Dictionary[Publication Type] OR Directory[Publication Type] OR Editorial[Publication Type] OR Electronic supplementary materials[Publication Type] OR Festschrift[Publication Type] OR In Vitro[Publication Type] OR Interactive Tutorial[Publication Type] OR Interview[Publication Type] OR Lectures[Publication Type] OR Legal Cases[Publication Type] OR Legislation[Publication Type] OR Letter[Publication Type] OR News[Publication Type] OR Newspaper article[Publication Type] OR Patient Education Handout[Publication Type] OR Personal Narratives[Publication Type] OR Periodical Index[Publication Type] OR Pictorial works[Publication Type] OR Popular works[Publication Type] OR Portraits[Publication Type] OR Scientific Integrity Review[Publication Type] OR Video Audio Media[Publication Type] OR Webcasts[Publication Type])) | 3,555,938 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #9) | 1,146 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #9) Filters: Humans | 1,124 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search(#7 NOT #9) Filters: Humans; English | 1,057 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=33)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #9) Filters: Publication date from 2007/07/01; Humans; English | 559 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 NOT #9) | 1,156 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 NOT #9) Filters: Humans | 1,145 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 NOT #9) Filters: Humans; English | 1,088 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 NOT #9) Filters: Publication date from 1990/01/01; Humans; English | 1,061 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#13 OR #17) | 1,370 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#13 OR #17) AND (“2012/04/26”[Date - Entrez] : “3000”[Date - Entrez]) | 146 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)

10/29/13 Cochrane: 194 records retrieved

Search Strings | Search Terms | Results
#1 | “congestive heart failure” or “heart failure, congestive” | 3,664
#2 | MeSH descriptor: [Heart Failure] explode all trees | 5,118
#3 | #1 or #2 | 7,233
#4 | MeSH descriptor: [Recurrence] explode all trees | 11,510
#5 | MeSH descriptor: [Patient Readmission] explode all trees | 696
#6 | readmission or rehospitalization | 2,638
#7 | #4 or #5 or #6 | 13,992
#8 | MeSH descriptor: [Case Management] explode all trees | 591
#9 | MeSH descriptor: [Rehabilitation] explode all trees | 13,023
#10 | MeSH descriptor: [Continuity of Patient Care] explode all trees | 471
#11 | MeSH descriptor: [Patient Discharge] explode all trees | 953
#12 | MeSH descriptor: [Patient Transfer] explode all trees | 109
#13 | MeSH descriptor: [Critical Pathways] explode all trees | 235
#14 | MeSH descriptor: [Telemedicine] explode all trees | 1,046
#15 | MeSH descriptor: [Home Care Services, Hospital-Based] explode all trees | 235
#16 | MeSH descriptor: [Home Nursing] explode all trees | 300
#17 | MeSH descriptor: [Physical Therapy Modalities] explode all trees | 13,559
#18 | MeSH descriptor: [Exercise Therapy] explode all trees | 5,884
#19 | transition* or postdischarge or “post-discharge” or coordination or coordinate or transfer or “post-acute care” or “postacute care” or post-hospital* or posthospital* or “subacute care” or “sub-acute care” or discharge or referral or continuity or “critical pathways” or “critical pathway” or “critical path” or “critical paths” or “clinical path” or “clinical paths” or “clinical pathway” or “clinical pathways” or telemedicine or telehealth or eHealth or “Mobile Health” or “Hospital Based Home Cares” or “Hospital Home Care Services” or “Hospital-Based Home Care” or “Hospital Based Home Care” or “Hospital-Based Home Cares” or “Nonprofessional Home Care” or “home nursing” or “Non-Professional Home Care” or “physical therapy” or “physical therapies” or “exercise therapy” | 43,725
#20 | #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 | 55,669
#21 | #3 and (#7 or #20) | 1,506
#22 | #3 and (#7 or #20) in Trials | 915
#23 | #3 and (#7 or #20) from 1990, in Trials | 892
#24 | #3 and (#7 or #20) in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 419
#25 | #3 and (#7 or #20) from 2007, in Cochrane Reviews (Reviews and Protocols) and Other Reviews | 355
#26 | #23 or #25 | 1,247
#27 | #23 or #25 from 2012 | 194

10/29/13 CINAHL: 51 records retrieved

Search String | Search Terms | Number of Results
S1 | (MH “Heart Failure”) | 16,842
S2 | ( (MH “Recurrence”) OR (MH “Readmission”) ) | 20,137
S3 | ((MH “Case Management”) OR (MH “Rehabilitation”) OR (MH “Continuity of Patient Care”) OR (MH “Patient Discharge”) OR (MH “Transfer, Discharge”) OR (MH “Critical Path”) OR (MH “Telemedicine”) OR (MH “Telehealth”) OR (MH “Home Health Care”) OR (MH “Home Rehabilitation”) OR (MH “Home Nursing”) OR (MH “Physical Therapy”) OR (MH “Therapeutic Exercise”)) | 85,200
S4 | (MH “Randomized Controlled Trials”) OR (MH “Nonrandomized Trials”) OR (MH “Single-Blind Studies”) OR (MH “Double-Blind Studies”) OR (MH “Random Assignment”) | 59,126
S5 | ( (MH “Meta Analysis”) OR (MH “Systematic Review”) ) | 25,305
S6 | (MH “Prospective Studies”) OR (MH “Clinical Trials”) | 218,211
S7 | S1 AND (S2 OR S3) AND (S5 OR S4) | 162
S8 | S1 AND (S2 OR S3) AND S6 | 357
S9 | Search (S7) Limiters – Human | 129
S10 | Search(S7) Limiters - Human; Language: English | 128
S11 | Search (S7) Limiters - Published Date from: 20070701-; Human; Language: English | 83
S12 | Search (S8) Limiters – Human | 271
S13 | Search (S8) Limiters - Human; Language: English | 268
S14 | Search (S8) Limiters - Published Date from: 19900101-; Human; Language: English | 268
S15 | S11 OR S14 | 325
S16 | (MH “Autobiographies”) OR (MH “Biographies”) OR (MH “Bibliography and References”) OR (MH “Bibliography, Descriptive”) OR (MH “Case Studies”) OR (MH “Congresses and Conferences”) OR (MH “Reference Books”) OR (MH “Edit and Review”) OR (MH “In Vitro Studies”) OR (MH “Interviews”) OR (MH “Lecture”) OR (MH “Legal Procedure”) OR (MH “Legislation”) OR (MH “News”) OR (MH “Newspapers”) OR (MH “Historical Records”) OR (MH “Narratives”) OR (MH “Life Histories”) OR (MH “Videorecording”) OR (MH “Audiovisuals”) OR (MH “Audiorecording”) OR (MH “World Wide Web Applications”) | 199,321
S17 | S15 NOT S16 | 306
S18 | S15 NOT S16 Limiters – Published date from: 20120401- | 51

## Gray Literature

4/26/13 ClinicalTrials.gov: 455 records retrieved

Search String | Search Terms | Number of Results
#1 | Conditions: “congestive heart failure” OR “heart failure” | 2,109
#2 | Interventions: Readmission OR rehospitalization OR recurrence OR patient readmission | 954
#3 | Interventions: case management OR rehabilitation OR discharge OR transition OR post-discharge OR coordination OR transfer OR post-acute care OR post-hospital OR subacute care OR referral OR continuity OR critical path OR clinical path OR telemedicine OR telehealth | 11,879
#4 | Interventions: eHealth OR Mobile Health OR Hospital Based Home Care OR Nonprofessional Home Care OR home nursing OR physical therapy OR Exercise Therapy | 7,650
#5 | #1 AND #2 | 25
#6 | #1 AND #3 | 261
#7 | #1 AND #4 | 235
#8 | #5 OR #6 OR #7 | 455

4/26/13 WHO ICTRP: 70 records retrieved

Search String | Search Terms | Number of Results
#1 | Condition: heart failure | 2,162
#2 | Intervention: Readmission OR rehospitalization OR recurrence OR “patient readmission” | 306
#3 | Intervention: “case management” OR “rehabilitation” OR “discharge” OR “transition” OR “post-discharge” OR “coordination” OR “transfer” OR “post-acute care” OR “post-hospital” OR “subacute care” OR “referral” OR “continuity” OR “critical path” OR “clinical path” OR “telemedicine” OR telehealth | 88
#4 | Interventions: eHealth OR “Mobile Health” OR “Hospital Based Home Care” OR “Nonprofessional Home Care” OR “home nursing” OR “physical therapy” OR “Exercise Therapy” | 6,167
#5 | #1 AND #2 | 6
#6 | #1 AND #3 | 6
#7 | #1 AND #4 | 96
#8 | #5 OR #6 OR #7 | 102
#9 | (#5 OR #6 OR #7) NOT ClinicalTrials.gov | 70

2/5/14 ClinicalTrials.gov: 186 records retrieved

Search String | Search Terms | Number of Results
#1 | Conditions: “congestive heart failure” OR “heart failure” | 2,309
#2 | Interventions: Readmission OR rehospitalization OR recurrence OR patient readmission | 1,054
#3 | Interventions: case management OR rehabilitation OR discharge OR transition OR post-discharge OR coordination OR transfer OR post-acute care OR post-hospital OR subacute care OR referral OR continuity OR critical path OR clinical path OR telemedicine OR telehealth | 13,334
#4 | Interventions: eHealth OR Mobile Health OR Hospital Based Home Care OR Nonprofessional Home Care OR home nursing OR physical therapy OR Exercise Therapy | 8,667
#5 | #1 AND #2 | 30
#6 | #1 AND #3 | 299
#7 | #1 AND #4 | 268
#8 | #5 OR #6 OR #7 | 514
#9 | #5 OR #6 OR #7 AND ( “05/21/2013” : MAX ) [LAST-RELEASE-DATE] | 186

2/5/14 WHO ICTRP: 7 records retrieved

Search String | Search Terms | Number of Results
#1 | Condition: heart failure | 2,408
#2 | Intervention: Readmission OR rehospitalization OR recurrence OR “patient readmission” | 265
#3 | Intervention: “case management” OR “rehabilitation” OR “discharge” OR “transition” OR “post-discharge” OR “coordination” OR “transfer” OR “post-acute care” OR “post-hospital” OR “subacute care” OR “referral” OR “continuity” OR “critical path” OR “clinical path” OR “telemedicine” OR telehealth | 2,627
#4 | Intervention: eHealth OR “Mobile Health” OR “Hospital Based Home Care” OR “Nonprofessional Home Care” OR “home nursing” OR “physical therapy” OR “Exercise Therapy” | 360
#5 | #1 AND #2 | 3
#6 | #1 AND #3 | 60
#7 | #1 AND #4 | 3
#8 | #5 OR #6 OR #7 | 64
#9 | #5 OR #6 OR #7 AND Date of Registration from 21/05/2013 | 14
#10 | (#9) NOT ClinicalTrials.gov | 7