# Abbreviations and Acronyms

Abbreviation or Acronym: Definition
ACEI: Angiotensin-converting enzyme inhibitor
AF: Atrial fibrillation
AHA/ACC: American Heart Association/American College of Cardiology
AHRQ: Agency for Healthcare Research and Quality
AMA: American Medical Association
ARB: Angiotensin II receptor blocker
BB: Beta-blocker
CAD: Coronary artery disease
CD-ROM: Compact Disk Read-Only Memory
CI: Confidence interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CMS: Centers for Medicare and Medicaid Services
COPD: Chronic obstructive pulmonary disease
DM: Diabetes mellitus
EF: Ejection fraction
EPC: Evidence-based Practice Center
ER: Emergency room
EuroQoL or EQ-5D: European Quality of Life – 5 Dimensions
HF: Heart failure
HR: Hazard ratio
HV: Home visiting
IHD: Ischemic heart disease
ITT: Intention-to-treat
KQ: Key Question
LVEF: Left ventricular ejection fraction
MCI: Mild cognitive impairment
MDS: Multidisciplinary
MDS-HF: Multidisciplinary heart failure clinic
Med: Medium
MI: Myocardial infarction
MLWHFQ: Minnesota Living With Heart Failure Questionnaire
N: Number (group or sample size)
NA: Not applicable
NNT: Number needed to treat
NR: Not reported
NS: Not significant
NYHA: New York Heart Association functional classification
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, Settings
PRISMA: Preferred Reporting Items in Systematic Reviews and Meta-Analyses
ProBNP: Probrain natriuretic peptide
QOL: Quality of life
RCT: Randomized controlled trial
RD: Risk difference
RR: Relative risk
ROB: Risk of bias
SD: Standard deviation
SE: Standard error
SF-12: Medical Outcomes Study Short Form (12 items)
SF-36: Medical Outcomes Study Short Form (36 items)
SMD: Standardized mean difference
SOE: Strength of evidence
STS: Structured telephone support
TEP: Technical Expert Panel
TM: Telemonitoring
UC: Usual care
UK: United Kingdom
Unc: Unclear
US: United States
VA: Veterans Affairs
VAMC: Veterans Affairs Medical Center
WMD: Weighted mean difference
6MWT: 6 Minute Walk Test