# Results

## Results of Literature Searches

Figure 2 summarizes the search results. The literature search identified 4,293 unique citations. During the title and abstract screening we excluded 3,396 citations; during the full-text article screening we excluded 380 citations (Appendix D). Of the 14 companies contacted for SIPs, 5 companies responded. One company indicated that no relevant studies had been conducted. Four companies provided SIPs and the references provided by these four companies were carefully crosschecked against our existing database, yielding four new references, none of which were applicable to this review (Appendix E).

Figure 2 Summary of search (number of articles)

CHD = coronary heart disease; LDL = low-density lipoprotein; RCT = randomized controlled trial; SIP = Scientific Information Packet

^a^ Total exceeds the number of citations in the exclusion box because citations could be excluded for more than one reason.

^b^ Sharma M, Ansari MT, Soares-Weiser K, Abou-setta AM, Ooi TC, Sears M, Yazdi F, Tsertsvadze A, Moher D. Comparative Effectiveness of Lipid-Modifying Agents. Comparative Effectiveness Review No. 16. Prepared by the University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021. Rockville, MD. Agency for Healthcare Research and Quality. September. 2009. www.effectivehealthcare.ahrq.gov/reports/final.cfm.

Figure B and Figure 2 describe the flow of articles through the screening and review process. 4,293 unique citations were identified. During the title and abstract screening we excluded 3,303 citations; during the full-text article screening we excluded 380 citations. Fifty-five studies, reported in 59 articles, were included.

Fifty-five studies, all randomized controlled trials, reported in 59 articles, were included.

## Overview of Included Trials by Potency and Agent

Of the included trials, 6 trials addressed combination therapy with bile acid sequestrant, 40 trials addressed combination therapy with ezetimibe, 4 trials addressed combination therapy with fibrates, 5 trials addressed combination therapy with niacin and statin, and no trials addressed comparing combination therapy with omega-3 fatty acid (note that one study addressed multiple two combinations: omega 3 and fibrates). Thirty one trials were included from the previous review that met the current eligibility criteria and 28 trials were identified in the new searches (Tables 5 and 6).

Table 5 Randomized trials included in evidence synthesis according to statin potency

Statin | Evidence Report Year | Bile Acid Sequestrants | Ezetimibe | Fibrates | Niacin | Omega-3 Fatty Acids
Low potency combination therapy vs high potency monotherapy | 2009 | NR | Ballantyne, 2005^66^ Bays, 2004^67^ Davidson, 2002^68^ Goldberg, 2004^69^ | Athyros, 2001^70^ | NR | NR
Low potency combination therapy vs high potency monotherapy | 2013 | NR | Ahmed, 2008^71^ Araujo, 2010^72^ Floretin, 2011^73^ Lee, 2011^74^ Lee, 2012^75^ Liberopoulos, 2013^76^ Moutzouri, 2011^77^ Moutzouri, 2012^78^ Rudofsky, 2012^79^ Her, 2010^80^ | NR | Airan-Javia, 2009 81 | NR
Mid potency combination therapy vs high potency monotherapy | 2009 | Hunninghake, 2001^82^ Johansson, 1995^83^ | Ballantyne, 2003^84^ Ballantyne, 2005^66^ Barrios, 2005^85^ Bays, 2004^67^ Catapano, 2006^86^ Constance, 2007^87^ Davidson, 2002^68^ Gaudiani, 2005^88^ Goldberg, 2004^69^ Goldberg, 2006^89^ McKenney, 2007^90^ Piorkowski, 2007^91^ Roeters van Lennep, 2008^92^ Stein, 2004^93^ | Athyros, 2001^70^ Shah, 2007^94^ | Bays, 2003^95^ | NR
Mid potency combination therapy vs high potency monotherapy | 2013 | NR | Yamazaki, 2013^96^ Bardini, 2010^97^ Ben-Yehuda, 2011^98^; Zieve, 2010^99^Cho, 2011^100^ Foody, 2010^101^ Okada, 2011^102^ Ostad, 2009^103^ Pesaro, 2012^104^ Robinson, 2009^105^ Tomassini, 2009^106^ Hamdan, 2011^107^ Averna, 2010^108^ Lee, 2013^109^ | Mohiuddin, 2009^110^ Shah, 2007^111^ | NR | NR
Low potency combination therapy vs mid potency monotherapy | 2009 | Barbi, 1992^112^ Ismail, 1990^113^ PMSG II, 1993^114^ Knapp, 2001^115^ Schrott, 1995^116^ | Ballantyne, 2005^66^ Bays, 2004^67^ Davidson, 2002^68^ Feldman, 2004^117^ Goldberg, 2004^69^ Kerzner, 2003^118^ | NR | Gardner, 1996 119 Hunninghake, 2003^120^ Insull, 2004^121^ | NR
Low potency combination therapy vs mid potency monotherapy | 2013 | NR | Averna, 2010^108^ Hamdan, 2011^107^ Kawagoe, 2011^122^ | Farnier, 2011^123^ | NR | NR

NR = not reported; PMSG II = Pravastatin Multicenter Study Group II

Table 6 Randomized controlled trials included in evidence synthesis according to statin agent

Statin | Evidence Report Year | Bile Acid Sequestrants | Ezetimibe | Fibrates | Niacin | Omega-3 Fatty Acids
Atorvastatin | 2009 | Hunninghake, 2001^82^ | Ballantyne, 2003^84^ Piorkowski, 2007^91^ Stein, 2004^93^ | NR | NR | NR
Atorvastatin | 2013 | NR | Ben-Yehuda, 2011^98^ Hamdan, 2011^107^ Lee, 2011^74^ Lee, 2012^75^ Ostad, 2009^103^ Zieve, 2010^99^ | NR | NR | NR
Fluvastatin | 2009 | NR | NR | NR | NR | NR
Fluvastatin | 2013 | NR | Kawagoe, 2011^122^ | NR | NR | NR
Lovastatin | 2009 | Schrott, 1995^116^ | Kerzner, 2003^118^ | NR | Gardner, 1996 119 Hunninghake, 2003^120^ Insull, 2004^121^ | NR
Lovastatin | 2013 | NR | NR | NR | NR | NR
Pitavastatin | 2009 | NR | NR | NR | NR | NR
Pitavastatin | 2013 | NR | NR | NR | NR | NR
Pravastatin | 2009 | Barbi, 1992^112^ Ismail, 1990^113^ PMSG II, 1993^114^ | NR | NR | NR | NR
Pravastatin | 2013 | NR | NR | NR | NR | NR
Rosuvastatin | 2009 | NR | NR | NR | NR | NR
Rosuvastatin | 2013 | NR | Yamazaki, 2013^96^ | NR | NR | NR
Simvastatin | 2009 | Johansson, 1995^83^ Knapp, 2001^115^ | Bays, 2004^67^ Davidson, 2002^68^ Feldman, 2004^117^ Gaudiani, 2005^88^ Goldberg, 2004^69^ | NR | NR | NR
Simvastatin | 2013 | NR | Araujo, 2010^72^ Averna, 2010^108^ Bardini, 2010^97^ Floretin, 2011^73^ Liberopoulos, 2013^76^ Moutzouri, 2012^78^ Pesaro, 2012^104^ Rudofsky, 2012^79^ | Mohiuddin, 2009^110^ | Airan-Javia, 2009 81 | NR
Mixed Statins | 2009 | NR | Ballantyne, 2005^66^ Barrios, 2005^85^ Catapano, 2006^86^ Constance, 2007^87^ Goldberg, 2006^89^ McKenney, 2007^90^ Roeters van Lennep, 2008^92^ | Athyros, 2001^70^ Shah, 2007^94^ | Bays, 2003^95^ | NR
Mixed Statins | 2013 | NR | Ahmed, 2008^71^ Cho, 2011^100^ Foody, 2010^101^ Moutzouri, 2011^77^ Okada, 2011^102^ Robinson, 2009^105^ Tomassini, 2009^106^ | Farnier, 2011^123^ Shah, 2007^111^ | NR | NR

NR = not reported; PMSG = II Pravastatin Multicenter Study Group II

We present our results by combination agent. Each section follows the format listed below:

1. Study Characteristics
2. Population Characteristics
3. Interventions
4. Outcomes
  A. Key Points
  B. [underlined: Long-term benefits and serious adverse events (KQ1)]
    i. Mortality
    ii. Acute Coronary Events
    iii. Cerebrovascular Disease
    iv. Revascularization Procedures
    v. Serious Adverse Events
  C. [underlined: Surrogate outcomes, short-term side effects and adherence (KQ2)]
    i. LDL
    ii. HDL
    iii. Total Cholesterol:HDL
    iv. Atherosclerosis
    v. Adherence
    vi. Any Adverse Event
    vii. Withdrawal due to Adverse Events
    viii. Cancer
    ix. Elevated Liver Transaminases
    x. Musculoskeletal Adverse Events
    xi. New Onset Diabetes Mellitus
    xii. Acute Kidney Injury
  D. [underlined: Subgroups of patients (KQ3)]
    i. Patients with pre-existing CHD
      a. Long-term beneftis and serious adverse events
      b. Surrogate outcomes, short-term side effects, and adherence
    ii. Patients with diabetes mellitus
      a. Long-term beneftis and serious adverse events
      b. Surrogate outcomes, short-term side effects, and adherence
    iii. Other subgroups
      a. Long-term beneftis and serious adverse events
      b. Surrogate outcomes, short-term side effects, and adherence

## Results by Combination Therapy Regimen

### Combined Lipid-Modifying Therapy With Statin and Bile Acid Sequestrant Versus Intensification of Statin Monotherapy

#### Study Characteristics

We included 6 trials (410 participants in eligible arms) that compared bile acid sequestrant plus statin to intensification of statin monotherapy. The 6 trial results were reported in 7 articles.82,83,112-116 All trials were parallel arm randomized controlled trials. One trial took place in Europe,83 and all others took place in North America. All trials were multicenter, except for one single center trial.112,113 Eligibility criteria were similar across all trials. All trials included a dietary run in, followed by treatment ranging from 4 weeks to 24 weeks in duration. Two trials compared high potency statin monotherapy to mid potency statin in combination therapy.82,83 The other four trials compared mid potency statin monotherapy to low potency statin in combination therapy.112-116

#### Population Characteristics

The average participant was in their 50s with the mean age across trials ranging from 51-61 years. The number of female participants varied between trials. Race was reported in only two trials, where the majority of participants were white.114,115 Smoking status, prior cardiovascular disease, revascularization events, and diabetes were not consistently reported across trials. When reported, no significant between group differences existed in the trials.83,114-116

#### Interventions

Two trials compared high potency statin monotherapy to mid potency statin in combination with colsevelam82 or colestipol.83 These monotherapy arms used atorvastatin and simvastatin, and the combination arms used atorvastatin and simvastatin. Four trials compared mid potency statin monotherapy to low potency statin in combination with cholestyramine112-114, colsevelam115, or colestipol.116 These trials used lovastatin, pravastatin and simvastatin in the monotherapy arms, and lovastatin, pravastatin and simvastatin in the combination therapy arms.

#### Outcomes

##### Key Points

- Long-Term Benefits
  ○ Insufficient evidence for all potency comparisons.
- Serious Adverse Events
  ○ Insufficient evidence for all potency comparisons.
- Surrogate Outcomes
  ○ A low potency statin combined with bile acid sequestrant is more effective than mid potency statin monotherapy for lowering LDL-c (SOE: moderate). There is insufficient evidence for other potency comparisons.
  ○ There is insufficient evidence to evaluate the effectiveness on raising HDL-c for any potency comparison.
- Short-Term Side Effects
  ○ There is insufficient evidence to compare the rates of elevated liver transaminases for any potency comparison.
  ○ There is insufficient evidence to compare the rates of elevated creatinine phosphokinase for any potency comparison.
- Adherence
  ○ Insufficient evidence for all potency comparisons.
- Subgroups
  ○ Insufficient evidence for all potency comparisons.

##### Long-Term Benefits and Serious Adverse Events (KQ 1)

No study reported on the comparative effectiveness of bile acid sequestrant plus statin on long-term benefits or rates of serious adverse events as compared to intensification of statin monotherapy among adults. We graded the strength of evidence for mortality, acute coronary events, revascularization procedures, and serious adverse events as insufficient.

##### Surrogate Outcomes, Short-Term Side Effects and Adherence (KQ 2)

All included RCTs evaluated surrogate outcomes including LDL-c and HDL-c. In several RCTs, medication adherence and short-term side effects were evaluated including elevated liver transaminases and withdrawal due to adverse events. We identified no studies that compared high potency statin monotherapy to low potency statin combination therapy. We identified no eligible non-randomized extensions of RCTs or FDA reports.

###### LDL-c

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Two trials reported on mean percent LDL-c change.82,83 At 4 weeks, one trial found that statin monotherapy lowered LDL-c 7 percent more than combination therapy.82 At 12 weeks, the other trial showed that combination therapy with colestipol 10g + simvastatin 20mg lowered LDL-c 5 percent more than statin monotherapy. However, the other combination arm in this trial, which used a lower dose of colestipol (5g) in combination with simvastatin 20mg, was less effective than statin monotherapy at reducing LDL-c (between group difference 2 percent that favored monotherapy). Overall, the results showed inconsistent effects on lowering LDL-c, we graded the strength of evidence as insufficient (Table 7).

Table 7 Mid potency statin combination therapy with bile acid sequestrants as compared to high potency statin monotherapy: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 2 (122) | Medium [1 trial with Jadad score<3] | Indirect [Calculated LDL in both trials] | Inconsistent [2 comparisons effect favors monotherapy, 1 comparison favors combination therapy] | Imprecise | Not detected None | Two studies with inconsistent results on LDL-c. | Insufficient
HDL-c | 2 (122) | Medium [1 trial with Jadad score<3] | Direct [Measured HDL-c in both trials] | Inconsistent [2 comparisons effect favors combination therapy, 1 comparison favors monotherapy] | Imprecise | Not detected None | Two studies with inconsistent results on HDL-c. | Insufficient

HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Four trials reported mean percent change in LDL-c (5 comparisons).112-116 In four comparisons, the difference between combination therapy and statin monotherapy on lowering LDL-c ranged from 8 percent to 14 percent, favoring combination therapy. Duration of therapy ranged from 6 to 12 weeks. One trial that used a lower dose of colestipol with statin in one of its combination arms found no difference between combination therapy and statin monotherapy at lowering LDL-c, which may have contributed to the lack of significant difference in this comparison.116

The results of almost all comparisons favored low potency statin in combination with bile acid sequestrant for lowering LDL-c. We graded the strength of evidence as moderate (Table 8). Only two trials reported or provided sufficient information for us to calculate SE for the LDL-c difference in differences, and therefore, we did not perform meta-analyses.

Table 8 Low potency statin combination therapy with bile acid sequestrants as compared to mid potency statin monotherapy: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 4 (288) | Medium [2 trials with Jadad score<3] | Indirect [Calculated LDL in all trials] | Consistent [4 comparisons favor combination therapy, 1 comparison no difference] | Imprecise | Not detected None | Studies favor low potency statin in combination with bile acid sequestrant by lowering LDL-c up to 14% more than mid potency statin monotherapy at 6-12 weeks. | Moderate
HDL-c | 4 (288) | Medium [2 trials with Jadad score<3] | Direct [Measured HDL-c in all trials] | Inconsistent [2 comparisons favor combination, 2 comparisons favor monotherapy, 1 comparison no difference] | Imprecise | Not detected None | Four studies with inconsistent results on HDL-c. | Insufficient

HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

###### HDL-c

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Two trials reported on mean percent change in HDL-c.82,83 At 4 weeks, one trial found that combination therapy raised HDL-c 6 percent more than monotherapy.82 At 12 weeks, the other trial showed that combination therapy with colestipol 5g + simvastatin 20mg raised HDL-c 3 percent more than statin monotherapy. However, the other combination arm in this trial, which used a higher dose of colestipol (10g) in combination with simvastatin 20mg, was less effective than statin monotherapy at raising HDL-c (between group difference 1 percent that favored monotherapy). Overall, the results showed inconsistent effects on raising HDL-c, we graded the strength of evidence as insufficient (Table 7).

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Four trials reported on mean percent change in HDL-c. In these trials,112-116 the effects on raising HDL-c were inconsistent and showed little to no absolute difference between combination therapy and statin monotherapy (range 2 percent difference in favor of monotherapy to 5 percent difference in favor of combination therapy). Duration of therapy ranged from 6-12 weeks. We graded the strength of evidence as insufficient (Table 8). Only two trials reported or provided sufficient information for us to calculate SE for the LDL-c difference in differences, and therefore, we did not perform meta-analyses.

###### Total Cholesterol: HDL

No studies reported on total cholesterol:HDL ratio.

###### Atherosclerosis

No studies reported on atherosclerosis.

###### Adherence

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported on treatment adherence,82 which was assessed with a pill count at 4 weeks. In the statin monotherapy arm, adherence was 88 percent and was 91 percent in the combination arm.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One trial reported on treatment adherence.116 Adherence to medications was 95 percent in the statin monotherapy arm and 93 percent in the combination arm at 12 weeks. The authors did not describe how adherence with medication was assessed.

###### Any Adverse Event

No studies reported on the occurrence of any adverse events.

###### Withdrawal Due to Adverse Events

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported on withdrawals due to adverse events.82 Both the statin monotherapy arm and the combination therapy arm had one person withdraw.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Only one trial reported the number of participants who withdrew from the study due to an adverse event.115 At 6 weeks, no participants in the monotherapy arm had withdrawn, while 1 participant in the combination arm withdrew due to an adverse event.

###### Cancer

No studies reported on cancer.

###### Elevated Liver Transaminases

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported on withdrawals due to elevated liver transaminases.82 No significant elevations of AST and/or ALT >3 times the upper limit of normal occurred in either arm.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

No studies reported elevated liver transaminases.

###### Adverse Musculoskeletal Events

No studies reported on adverse musculoskeletal events such as elevated CPK, myalgia or rhabodomyolysis.

###### New Onset Diabetes Mellitus

No studies reported on any diabetes-related outcomes.

##### Subgroups of Patients (KQ 3)

No study reported on the comparative effectiveness of bile acid sequestrant plus statin on benefits or harms as compared to intensification of statin monotherapy among subgroups.

### Combined Lipid-Modifying Therapy With Statin and Ezetimibe Versus Intensification of Statin Monotherapy

#### Study Characteristics

We included 40 trials (10,439 participants randomized to eligible arms – 5 studies with no baseline N by arm available) that compared intensification of statin monotherapy to lower potency statin therapy in combination with ezetimibe. The 40 trials were reported in 43 articles.66-69,71-80,84-93,96-109,117,118,122,124,125 All studies were parallel arm RCTs, except one crossover RCT.72 The studies were conducted in various geographic locations including Europe, Middle East, Asia, Latin America, North America, and some on multiple continents. Two trials did not report their location.84,86 There were 17 single center trials71-80,91,103,104,107,109,122,125, and 24 multicenter trials.66-69,85,87-90,92,93,96,97,99,101,102,105,108,117,118,126 Most trials recruited patients with hyperlipidemia;67-69,84,86,90,118,66,71-78,80,101,105,117,122; however, several studies recruited only patients with preexisting CHD (n=14)85,91-93,96-100,102-104,107,108,125 or patients with DM (n=6).87-89 79,109,122 Treatment duration ranged from 4 to 24 weeks. Thirteen studies compared low potency statin in combination with ezetimibe to high potency statin monotherapy among general populations of patients with hyperlipidemia66-69,71-78,80; while there were no studies that evaluated this comparison among patients with preexisiting CHD and one study that evaluated this comparison among patients with DM.79 Eleven studies compared mid potency statin in combination with ezetimibe to high potency statin monotherapy among general populations of patients with hyperlipidemia;66-69,84,86,90,93,98,99,101,105 while 12 studies evaluated this comparison among patients with preexisiting CHD85,91,92,96,97,100,102-104,107,108,125 and 4 studies evaluated this comparison among patients with DM.87-89,106,109,124 Finally, 6 studies compared low potency statin in combination with ezetimibe to mid potency statin monotherapy among general populations with hyperlipidemia;66-69,117,118 while no studies evaluated this comparison among patients with preexisiting CHD and one study evaluated this comparison among patients with DM122 (Appendix E Evidence Tables).

#### Population Characteristics

Most participants were in their 50s-60s.66-69,84-93,117,118,71-79,97-101,103-108,122,124 Two studies had participants whose mean age was in the 70s.96,102 One trial reported a significant between group difference with respect to age, where the combination therapy arm was significantly older (p=0.04).79 Female participants varied between trials, ranging from 12 percent to 70 percent. One study had only men.71 Race was reported in most trials, and the majority were white (56 percent to 96 percent), with black, Hispanic, and Asian participants the next most common groups. Smoking status was reported in less than half of studies (n=17), and current smoking status varied between studies (range 6 percent to 69 percent).68,84,90,91,93,118,73-78,96,100,102-104 Some trials included only diabetics (n=5)79,87-89,109,122 and other trials had no diabetics (n=2).71,77 DM status was reported in 23 other trials, and ranged from 0 percent to 67 percent of participants.84,85,90-93,117,118,73-75,79,96,99-105,107,80,125 Prior CHD and revascularization events were not consistently reported across trials.

#### Interventions

Fourteen studies compared low potency statin in combination with ezetimibe to high potency statin monotherapy.66-69,71-79,80 The statin monotherapy regimens included simvastatin, rosuvastatin, and atorvastatin. The combination therapy regimens included simvastatin and atorvastatin in combination with ezetimibe. Twenty-seven studies compared high potency statin monotherapy to mid potency statin in combination with ezetimibe.66-69,84-93,106,124,96-105,107-109,125 The monotherapy regimens included simvastatin, rosuvastatin, and atorvastatin. The combination therapy included rosuvastatin, simvastatin and atorvastatin in combination with ezetimibe. Seven studies compared low potency statin in combination with ezetimibe to mid potency statin monotherapy.66-69,117,118,122 The monotherapy regimens included simvastatin, rosuvastatin, fluvastatin and atorvastatin. The combination therapy included simvastatin, rosuvastatin, fluvastatin, lovastatin and atorvastatin in combination with ezetimibe.

#### Outcomes

##### Key Points

- Long-Term Benefits
  ○ Insufficient evidence for all potency comparisons.
- Serious Adverse Events
  ○ Insufficient evidence for all potency comparisons.
- Surrogate Outcomes
  ○ A low potency statin combined with ezetimibe is more effective than high potency statin monotherapy for lowering LDL-c (SOE: low).
  ○ A mid potency statin combined with ezetimibe is more effective than high potency statin monotherapy for lowering LDL-c (SOE: moderate).
  ○ A low potency statin combined with ezetimibe is more effective than mid potency statin monotherapy for lowering LDL-c (SOE: moderate).
  ○ A low potency statin combined with ezetimibe is more effective than high potency statin monotherapy for raising HDL-c (SOE: low).
  ○ A mid potency statin combined with ezetimibe is more effective than high potency statin monotherapy for raising HDL-c (SOE: low).
  ○ A low potency statin combined with ezetimibe is more effective than mid potency statin monotherapy for raising HDL-c (SOE: low).
- Short-Term Side Effects
  ○ There is insufficient evidence to compare the rates of adverse events for any potency comparison.
  ○ There is insufficient evidence to compare the rates of elevated liver transaminases for any potency comparison.
  ○ There is insufficient evidence to compare the rates of adverse musculoskeletal events for any potency comparison.
- Adherence
  ○ Insufficient evidence for all potency comparisons.
- Subgroups
  ○ CHD
    ■ Harms:
      - Insufficient evidence for all potency comparisons.
    ■ Benefits:
      - A mid potency statin combined with ezetimibe is more effective than high potency statin monotherapy for lowering LDL-c among CHD patients (SOE: moderate). There is insufficient evidence within other potency comparisons.
      - There is no difference between a mid potency statin combined with ezetimibe and high potency statin monotherapy for raising HDL-c among CHD patients (SOE: low). There is insufficient evidence within other potency comparisons.
  ○ DM
    ■ Harms:
      - Insufficient evidence for all potency comparisons.
    ■ Benefits
      - A mid potency statin with ezetimibe is more effective than High potency statin monotherapy for lowering LDL-c among DM patients (SOE: moderate). There is insufficient evidence within other potency comparisons.
      - A mid potency statin combined with ezetimibe is more effective than high potency statin monotherapy for raising HDL-c among DM patients (SOE: moderate). There is insufficient evidence within other potency comparisons.

##### Long-Term Benefits and Serious Adverse Events (KQ 1)

###### Mortality

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Two studies reported mortality.67,68. No deaths occurred in eligible arms in either trial. We graded the strength of evidence as insufficient.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Six studies reported mortality.67,68,86,98,99,101,105 Overall, mortality was very low with very few deaths. Monotherapy was favored in the studies that showed a difference between treatments; however, the between-group differences were not statistically significant (Table 9). Given the limited number of events, we are unable to compare the effect between groups and have graded the evidence as insufficient.

Table 9 Percentage of deaths in each arm of [underlined: mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy

Author, Year | Regimen | Percentage of Deaths, Combination Therapy Arm | Percentage of Deaths, Monotherapy Arm
Zieve 2010^98^, Ben-Yehuda 2011^99^ | A10/E10 v A40 | <1 | <1
Foody 2010^101^ | S20/E10 v A40 | 0.4 | 0.4
Foody 2010^101^ | S20/E10 v A20 | 0.4 | 0
Robinson 2009^105^ | S20/E10 v A40 | 0 | 0
Robinson 2009^105^ | S20/E10 v A20 | 0 | 0
Bays 2004^67^ | S20/E10 v A80 | NR^a^ | 0
Bays 2004^67^ | S20/E10 v S40 | NR^a^ | 0
Davidson 2002^68^ | S20/E10 v S80 | 1.72 | NR
Davidson 2002^68^ | S20/E10 v S40 | 1.72 | NR
Catapano 2006^86^ | S20/E10 v R40 | 0 | 0
Catapano 2006^86^ | S20/E10 v R40 | 0 | 0

A = atorvastatin; E = ezetimibe; NR = not recorded; R = rosuvastatin; S = simvastatin;

a 1 death in the combination therapy arm but cannot calculate proportion.

###### Low Potency Statin Combination Therapy Versus Mid Potency Statin Monotherapy

Two studies reported mortality.67,68 No deaths occurred in eligible arms in either trial. We graded the strength of evidence as insufficient.

###### Acute Coronary Events

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

No studies reported on acute coronary events.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One study reported on acute coronary events.93 There was one fatal MI reported in the combination arm of that study (ezetimibe 10mg + atorvastatin 10mg). There were no fatal MIs reported in the monotherapy arm. We graded the strength of evidence as insufficient.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

No studies reported on acute coronary events.

###### Cerebrovascular Disease

No studies reported on cerebrovascular events.

###### Revascularization Procedures

No studies reported on revascularization events.

###### Serious Adverse Events

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

No studies reported on serious adverse events.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Three studies reported serious adverse events93,98,99,101 (Table 10).

Table 10 Percentage of SAE in each arm of [underlined: mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy

Author, Year | Regimen | N Analyzed by Group | % with SAE, Monotherapy | % With SAE, Combination Therapy | Calculated p-value
Foody, 2010 101 | ATV 20mg SMV 20mg + EZE 10mg | 258 256 | 1.2 | 3.1 | 0.22
Foody, 2010 101 | ATV 40mg SMV 20mg + EZE 10mg | 256 256 | 2.0 | 3.1 | 0.57
Stein, 2004 93 | ATV 20mg ATV 10mg + EZE 10mg | 525 526 | 2.8 | 3.9 | 0.45
Zieve, 2010; Ben-Yehuda, 2011 98 ,99 | ATV 40mg ATV 10mg + EZE 10mg | 316 305 | 2.7 | 2.9 | 0.86

As shown in Table 10, the percentage of patients in each arm experiencing an SAE in each arm was low overall. Two of these trials occurred in similar populations with similar interventions.103,100,101 The study by Stein et al. (2004) was a 14-week trial that included different potency comparisons during different phases, of which only one period (weeks 0 to 4) were eligible for inclusion in this review.95 However, the SAE were reported only during the course of the entire trial, and therefore, we could not determine what events, if any, occurred during the relevant period. We have elected to report the overall trial results from this study for completeness. Given that there were only two eligible trials, we did not perform meta-analysis and we graded the strength of evidence as insufficient.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One study reported serious adverse events.117 The SAE rates were low overall (8% in combination therapy, and 5% in monotherapy) and the difference was not statistically significant (p-values calculated). We graded the strength of evidence as insufficient.

##### Surrogate Outcomes, Short-Term Side Effects and Adherence (KQ2)

Almost all included RCTs evaluated surrogate outcomes including LDL-c and HDL-c. In several RCTs, medication adherence and short-term side effects were evaluated including elevated liver transaminases and elevated creatinine phosphokinase. We identified no eligible non-randomized extensions of RCTs or FDA reports.

###### LDL-c

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Thirteen studies evaluated LDL-c outcomes, with some trials reporting on multiple eligible arms for this potency comparison (20 arms).66-69,71-78,80 Duration of therapy ranged from 6-12 weeks. As shown in Figure 3, six comparisons favored combination therapy for lowering LDL-c as compared to monotherapy (difference 2 percent to 12 percent).71,73,75-78 Three comparisons favored monotherapy (difference 4 percent to 6 percent)66,67,72 and four showed no difference.68,69,74 Six studies had multiple arms comparing low potency statin combination therapy with different doses of high potency statin monotherapy.66-69,77,80 Only the highest dose of statin monotherapy when the same statin was used is shown in the figure. Of the other comparison arms, six out of seven favored combination therapy (difference 3.4 percent to 8 percent).67-69 One comparison favored monotherapy (difference 1.2 percent).66 No studies reported LDL-c goal attainment.

Figure 3 Mean difference in percent LDL change from baseline to time point comparing low potency combination therapy with ezetimibe to high potency monotherapy

ATV = atorvastatin; SMV = simvastatin; NR = not reported

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 3 shows mean difference in percent LDL change from baseline to time point comparing low potency combination therapy with ezetimibe to high potency monotherapy.

We graded the strength of evidence as low. We considered performing meta-analysis, however, few (31%) of the trials had a calculable standard error for the difference in difference, therefore, we did not feel that a meta-analysis would be an accurate pooling of the available literature (Figure 3).

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Eleven studies evaluated LDL-c outcomes with some trials reporting on multiple eligible arms for this potency comparison (22 arms).66-69,84,86,90,93,98,101,105,99 As shown in Figure 4, eight comparisons favored combination therapy for lowering LDL-c as compared to monotherapy (difference 3% to 14%).67,69,84,90,93,98,99,101,105 Duration of therapy ranged from 4 to 12 weeks. Two comparisons favored monotherapy (difference 2% to 5%).66,86 and two comparisons were neutral.68,84 Eight studies had multiple arms comparing mid potency statin combination therapy with different doses of high potency statin monotherapy.66-69,84,86,101,105 Only the highest dose of statin monotherapy is shown in the figure 3. Of the other comparison arms, ten out of eleven favored combination therapy (difference 2.3% to 11.3%)66,67,69,84,101,105, and the other was neutral (0.8% difference).68 In addition, 3 studies (5 comparisons) reported on attainment of ATP III LDL-c goals.98,99,101,105 In five comparisons, more patients in the combination therapy group achieved LDL target (difference 7.5% to 25.0%).98,99,101,105

Figure 4 Mean difference in percent LDL change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency monotherapy

ATV = atorvastatin; NR = not reported; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 4 shows mean difference in percent LDL change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency monotherapy.

We graded the strength of evidence as moderate. We considered performing meta-analysis, however, few (30%) of the trials had a calculable standard error for the difference in difference, therefore, we did not feel that a meta-analysis would be an accurate pooling of the available literature.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Six studies evaluated LDL-c outcomes with some trials reporting on multiple eligible arms for this potency comparison (7 comparisons).66-69,117,118 All comparisons favored combination therapy for lowering LDL-c as compared to monotherapy (difference 3% to 11.3%).66-69,117,118 Duration of therapy ranged from 5 to 12 weeks. No studies reported LDL-c goal attainment.

The results of all studies favored mid potency statin in combination with ezetimibe for lowering LDL-c (Figure 5). We graded the strength of evidence as moderate. We considered performing meta-analysis, however, few (43%) of the trials had a calculable standard error for the difference in difference, therefore, we did not feel that a meta-analysis would be an accurate pooling of the available literature.

Figure 5 Mean difference in percent LDL change from baseline to time point comparing low potency combination therapy with ezetimibe to mid potency monotherapy

ATV = atorvastatin; LOV = lovastatin; NR = not reported; RSV = rosuvastatin; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 5 shows mean difference in percent LDL change from baseline to time point comparing low potency combination therapy with ezetimibe to mid potency monotherapy.

###### HDL-c

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Eleven studies (sixteen comparisons) evaluated HDL-c.66-68,72-78,80 As shown in Figure 6, three comparisons favored combination therapy for raising HDL-c as compared to monotherapy (difference 5.14% to 6.3%).66,72,75 Duration of therapy ranged from 4 to 12 weeks. Six comparisons were neutral 66-68,73,74,76,80 and one comparison favored monotherapy (difference 3.28%)78 Three studies had multiple arms comparing low potency statin combination therapy with different doses of high potency statin monotherapy.66-68 Only the highest dose of statin monotherapy is shown in the figure. Of the other comparison arms, four out of five favored combination therapy (difference 2.6% to 3.9%)66,68,80 and one was neutral (0.5% difference).67,71

Figure 6 Mean difference in percent HDL change from baseline to time point comparing low potency combination therapy with ezetimibe to high potency monotherapy

ATV = atrovastatin; NR = not reported; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 6 shows mean difference in percent HDL Change from baseline to time point comparing low potency combination therapy with ezetimibe to high potency monotherapy.

We graded the strength of evidence as low (Table 11). We considered performing meta-analysis, however, few (27%) of the trials had a calculable standard error for the difference in difference, therefore, we did not feel that a meta-analysis would be an accurate pooling of the available literature (Figure 7).

Table 11 Low potency statin in combination with ezetimibe as compared to high potency statin monotherapy in [underlined: general populations]: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | 2^a^ | Low | NA | Consistent | Imprecise | Not detected None | No deaths in any arm | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 13^a^ (2392) | Moderate | Indirect [LDL not directly measured in all trials] | Inconsistent [six favored combination, three neutral, three monotherapy] | Imprecise | Not detected None | Six comparisons favored combination therapy for lowering LDL-c as compared to monotherapy (difference 2 percent to 12 percent), three favored monotherapy, four showed no difference. | Low
HDL-c | 11 (2128) | Moderate | Direct [HDL directly measured] | Inconsistent [three favored combination, six neutral, one monotherapy]] | Imprecise | Not detected None | Three comparisons favored combination therapy for raising HDL-c as compared to monotherapy (difference5.14 percent to 6.3 percent). | Low

HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

a Missing N in at least one trial.

Figure 7 Mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency statin monotherapy

ATV = atorvastatin; EZE = ezetimibe; NR = not reported; RSV = rosuvastatin; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 7 shows mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency statin monotherapy.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Ten studies (21 comparisons) evaluated HDL-c.66-69,84,86,90,93,98,99,101,105 Six studies favored combination therapy for raising HDL-c as compared to monotherapy (difference 1.8% to 6%).66,67,69,84,98,99,101,105 Four studies were neutral.93,68,86,90 Duration of therapy ranged from 4 to 12 weeks. Seven studies had multiple arms comparing low potency statin combination therapy with different doses of high potency statin monotherapy.66,66-68,86,101,105 Only the highest dose of statin monotherapy is shown in the figure. Of the other comparison arms, ten out of eleven favored combination therapy (difference 1.2% to 5%)66-68,84,86,93 and two were neutral (difference 0.8 percent to 1.1 percent).101,105

We graded the strength of evidence as low (Table 12). We considered performing meta-analysis, however, few (44%) of the trials had a calculable standard error for the difference in difference, therefore, we did not feel that a meta-analysis would be an accurate pooling of the available literature.

Table 12 Mid potency statin in combination with ezetimibe as compared to high potency statin monotherapy in [underlined: general populations]: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | 6^a^ (1565) | Low | Direct | Inconsistent | Imprecise [does not meet OIS of 4864] | Not detected None | Very few events; similar mortality in combination therapy and monotherapy arms. | Insufficient
Acute Coronary Events | 1 (596) | Low | Direct | NA | Imprecise | Not detected None | Only one event occurring in a combination arm. | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Serious Adverse Events | 2 (1391) | Low | Direct | Consistent [no statistically significant difference in SAE in any comparison] | Imprecise [does not meet OIS of 1490] | Not detected None | No difference. | Insufficient
Surrogate Clinical Outcomes
LDL-c | 11^a^ (6694) | Low | Indirect [LDL calculated not directly measured in most trials] | Consistent [Eight studies favored combination therapy, two were neutral, two favored monotherapy] | Imprecise | Not detected None | Eight comparisons favored combination therapy for lowering LDL-c as compared to monotherapy (difference 3 percent to 14 percent) | Moderate
HDL-c | 10^a^ (6434) | Low | Direct [HDL directly measured] | Inconsistent [Six studies favored combination therapy, five neutral] | Imprecise | Not detected None | Six comparisons favored combination therapy for raising HDL-c as compared to monotherapy (difference 1.8 percent to 6 percent) | Low

HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

a Missing N in at least one trial.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Six studies evaluated HDL-c.66-69,117,118 Three studies favored combination therapy for raising HDL-c as compared to monotherapy (difference 3% to 4%) (Figure 8).68,118 Both comparisons in the Kersner et al study 118 were included in the figure because there were different low potency statin combination regimens used. Three studies were neutral (difference 0.05% to 1.1%).66,67,117 We graded the strength of evidence as low (Table 13). Only one trial reported or provided sufficient information for us to calculate SE for the HDL-c difference in differences, and therefore, we did not perform meta-analysis.

Figure 8 Mean difference in percent HDL change from baseline to time point comparing low potency combination therapy with ezetimibe to mid potency statin monotherapy

ATV = atrovastatin; LOV = lovastatin; NR = not reported; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 8 shows mean difference in percent HDL change from baseline to time point comparing low potency combination therapy with ezetimibe to mid potency statin monotherapy

Table 13 Low potency statin in combination with ezetimibe as compared to mid potency statin monotherapy in [underlined: general populations]: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | 2^a^ (604) | Low | NA | NA [no deaths either arm] | Imprecise | Not detected None | No deaths in included arms. | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Serious Adverse Events | 1 (596) | High | Direct | NA | Imprecise [OIS 640] | NA | There were more SAEs in the combination therapy arm than the monotherapy arm (not statistically significant) | Insufficient
Surrogate Clinical Outcomes
LDL-c | 6^a^ (1615) | Low | Indirect [LDL calculated not directly measured in both trials] | Consistent [All trials favor combination therapy] | Imprecise | Not detected None | All comparisons favored combination therapy for lowering LDL-c as compared to monotherapy (difference 3 percent to 11.3 percent). | Moderate
HDL-c | 5^a^ (1356) | Low | Direct [HDL calculated directly] | Inconsistent [Three trials favored combination therapy, three were neutral] | Imprecise | Not detected None | Three studies favored combination therapy for raising HDL-c as compared to monotherapy (difference 3 percent to 4 percent) | Low

HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

a Missing N in at least one trial.

###### Total Cholesterol: HDL

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One study reported total cholesterol:HDL ratio.67 The effects on lowering total cholesterol:HDL were inconsistent and showed little to no absolute difference between combination therapy and statin monotherapy.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Seven studies (12 arms) reported total cholesterol:HDL ratio.68,69,84,86,90,93,98,99,101,105 Most comparisons favored monotherapy for lowering total cholesterol:HDL as compared to combination therapy (difference 1.6% to 11.8%).68,69,84,90 ,93,98,99,101,105 Duration of therapy ranged from 6-12 weeks. However, two comparisons favored combination therapy (difference 1.1% to 4.2%).86

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

No studies reported total cholesterol:HDL ratio.

###### Atherosclerosis

No studies reported on atherosclerosis

###### Adherence

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

No studies reported adherence.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One studies reported on adherence.90 One study favored combination therapy with 98 percent adherence among combination therapy patients and 84 percent adherence among monotherapy patients (defined as returning 75 and 125% of dispensed tablets).90

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

No studies reported adherence.

###### Any Adverse Event

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

No studies reported adverse events.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Three studies reported adverse events.93,98,99,101 In one comparison98,99, more patients in the monotherapy arm experienced at least one adverse event (difference 3%). In three comparisons, more patients in the combination therapy arm experienced at least one adverse event (difference 2.5% to 5%).93,101

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One study reported adverse events.117 More participants in the monotherapy group had an adverse event (66%) than the combination therapy group (56%) (p=0.02).

###### Withdrawal Due to Adverse Events

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One study reported withdrawals due to adverse events.68 In one monotherapy arm (simvastatin 40mg), 3 percent of patients withdrew due to adverse events. No participants in the combination arm or other monotherapy arm (simvastatin 80mg) withdrew due to adverse events.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Three studies reported withdrawals due to adverse events (8 arms).68,98,99,101 In one comparison, there was no difference in withdrawal due to adverse events between the combination therapy and monotherapy arms68 with no event in either arm. In three comparisons, more patients in the combination therapy group withdrew due to adverse event (difference 1% to 2.3%).98,99,101 In one comparison, more patients in the monotherapy group withdrew due to AE (difference 3.3 percent).68

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Two studies reported withdrawals due to adverse events.68,117 The combination arms in both studies had fewer withdrawals due to adverse events than the monotherapy arms (difference range 1% to 11% favoring combination therapy).

###### Cancer

No studies reported on cancer.

###### Elevated Liver Transaminases

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Three studies reported on elevated liver transaminases (AST and/or ALT > 3 times ULN).74,75,80 No participants experienced elevated liver enzymes.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Six studies reported on elevated liver transaminases (AST and/or ALT > 3 times ULN).86,90,93,98,99,101,105 Overall, few patients experienced elevated transaminases in any arm. In three comparisons, more patients in the combination therapy group experienced elevated liver transaminases (difference 0.2% to 1.4%).86,90,101 In four comparisons, more patients in the monotherapy group experienced elevated liver transaminases (difference 0.7% to 1.8%).93,101,105

One comparison86 (rosuvastatin 40 vs. simvastatin 20/ ezetimibe 10) showed no difference in the proportion of patients with elevated liver transaminases.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One study reported on elevated liver transaminases.117 Overall, few patients experienced elevated transaminases in this trial (0% in monotherapy and 0.4% in combination therapy).

###### Musculoskeletal Adverse Events

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Three studies reported on CPK > 10 times ULN.74,75,80 No patients in any eligible arm experienced CPK elevations. One reported on myalgia80, with one reported case of myalgia in the monotherapy arm.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Six studies reported on CPK > 10 times ULN.86,90,93,98,99 ,101,105 Overall, few patients experienced CPK elevations regardless of treatment arm. In two comparisons, more patients in the combination therapy group experienced CPK > 10× ULN (difference 0.4% in both).105 In two comparisons, more patients in the monotherapy group experienced CPK > 10× ULN (difference 0.1% to 0.3%).93,86 Four comparisons showed no difference.86,90,101 Three studies reported on myalgia.86,93,98,99 There was little to no difference between treatment arms with respect to reports of myalgia (difference range 0% to 1%).

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One study reported on CPK > 10 times ULN.117 No participants in the combination arm experienced CPK elevations, and only 1 percent of participants in the monotherapy arm had CPK elevations. No studies reported on myalgia.

###### New Onset Diabetes Mellitus

No studies reported on new-onset diabetes mellitus.

###### Acute Kidney Injury

No studies reported on acute kidney injury.

##### Subgroups of Patients (KQ 3)

There were many studies involving participants with DM and CHD. There were few studies making subgroup comparisons by gender (female), race (Black, Hispanic, and Asian), or age (> 75 years old). Surrogate clinical markers were commonly reported by subgroup; however, serious adverse events and mortality were not commonly reported by subgroup (Appendix Table E60).

###### Patients With Preexisting Coronary Heart Disease

Overall, 12 studies included analyses of patient populations with preexisiting CHD. No studies compared low potency statin in combination with ezetimibe to high potency statin monotherapy among patients with preexisting CHD (Table 14). Twelve studies compared mid potency statin in combination with ezetimibe to high potency statin monotherapy among patients with preexisiting CHD.85,91,92,96,97,100,102-104,107,108,125

Table 14 Low potency statin in combination with ezetimibe as compared to high potency statin monotherapy among [underlined: patients with CHD]: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
HDL-c | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient

CHD = coronary heart disease; HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable;

No studies compared low potency statin in combination with ezetimibe to mid potency statin monotherapy among patients with preexisting CHD.

###### Mortality

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No studies reported mortality among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Three studies reported mortality among patients with preexisting CHD.85,92,108 No deaths occurred in these studies. We graded the strength of evidence as insufficient (Table 15).

Table 15 Mid potency statin in combination with ezetimibe as compared to high potency statin monotherapy among [underlined: patients with CHD]: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | 3^a^ (539) | Low | Direct | NA | Imprecise | Not detected None | No mortality in any arm. | Insufficient
Acute Coronary Events | 1 (49) | High | Direct | NA | Imprecise | Not detected None | Fatal MI in the combination arm. | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Serious Adverse Events | 3 (632) | Low | Direct | Inconsistent [2 favored mono, 1 favored combo] | Imprecise [does not meet OIS of 1864] | Not detected None | Two studies favored monotherapy; one favored combination therapy. | Insufficient
Surrogate Clinical Outcomes
LDL-c | 12^a^ (1233) | Low | Indirect [LDL calculated not directly measured in all trials] | Consistent [most but not all favored combo] | Imprecise | Not detected None | In nine comparisons, combination therapy lowered LDL more than monotherapy (difference 5 percent to 15 percent) | Moderate
HDL-c | 11^a^ (1233) | Low | Direct [HDL directly measured] | Inconsistent [Mixed results – most neutral] | Imprecise | Not detected None | Most studies were neutral (difference 0.1 percent to 5.6%, NS) | Low

CHD = coronary heart disease; LDL = low-density lipoprotein; HDL = high-density lipoprotein; NA = not applicable

a Missing N in at least one trial.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No studies reported mortality among patients with preexisting CHD.

###### Acute Coronary Events

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No studies reported acute coronary events among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study reported on acute coronary events, specifically fatal MI, among patients with preexisting CHD.103 No fatal MI occurred in the monotherapy arm and one fatal MI occurred in the combination therapy arm. We graded the strength of evidence as insufficient (Table 15).

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No studies reported acute coronary events among patients with preexisting CHD.

###### Cerebrovascular Events

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported cerebrovascular events among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study reported cerebrovascular events among patients with preexisting CHD, specifically transient ischemic attack (TIA).108 One TIA occurred in the monotherapy arm (2%) and no events occurred in the combination arm, which was not a significant difference.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported cerebrovascular events among patients with preexisting CHD.

###### Revascularization Procedures

No studies reported on revascularization procedures among patients with preexisting CHD.

###### Serious Adverse Events

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported serious adverse events among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Three studies reported serious adverse events among patients with preexisting CHD.85,97,108 Overall, the numbers of events were low. In two comparisons, more combination therapy patients experienced SAE (difference 0.02% to 1.4%).85,97 In one comparison, more monotherapy group patients experienced SAE (difference 1.7 percent). We graded the strength of evidence as insufficient (Table 15).

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported serious adverse events among patients with preexisting CHD.

###### LDL-c

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No studies reported on LDL-c outcomes among patients with preexisting CHD. We graded the strength of evidence as insufficient (Table 14).

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Twelve studies reported on LDL-c outcomes among patients with preexisting CHD.85,91,92,96,97,100,102-104,107,108,125 In nine comparisons, combination therapy lowered LDL more than monotherapy (difference 5% to 15%).85,91,92,97,102,107,108 Three studies were neutral (difference 1% to 3.1%)96,100,104 and one study favored monotherapy.103

In addition, one study reported LDL-c change among female participants with preexisting CHD.85 This study favored combination therapy for LDL-c reduction in female participants with CHD. Mean percent change in the monotherapy group was 21 percent, while mean percent change in the combination therapy group was 34 percent.

Four studies reported attainment of LDL-c < 100 mg/dL among patients with preexisting CHD.85,91,92,108 Most comparisons favored combination therapy over monotherapy for attaining this LDL-c goal (difference range 13% to 49% favoring combination therapy), which was a statistically significant difference in 3 trials.85,92,108

We graded the strength of evidence as moderate (Table 15).

Summary estimates from meta-analysis are not reported due to high heterogeneity (I^2^=94.5%) (Figure 9).

Figure 9 Mean difference in percent LDL-c change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency monotherapy among CHD patients

ATV = atorvastatin; NR = not reported; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 9 shows mean difference in percent LDL-c change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency monotherapy among CHD patients

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No studies reported on LDL-c outcomes among patients with preexisting CHD. We graded the strength of evidence as insufficient (Table 16).

Table 16 Low potency statin in combination with ezetimibe as compared to mid potency statin monotherapy among [underlined: patients with CHD]: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
HDL-c | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient

CHD = coronary heart disease; HDL= high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

###### HDL-c

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No studies reported on HDL-c among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Eleven studies reported HDL-c among patients with preexisting CHD.85,91,97,100,102-104,107,108,96,125 One study favored combination therapy (difference 7.33%).102 One study favored monotherapy (difference 6%).107 However, most results were neutral (difference 0.1% to 5.6%, NS).85,91,97,100,103,104,108 Given that the results were inconsistent with respect to raising HDL-c among patients with preexisting CHD (Figure 10), we graded the strength of evidence as low for no effect (Table 15). We considered performing meta-analysis, however, few (45%) of the trials had a calculable standard error for the difference in difference, therefore, we did not feel that a meta-analysis would be an accurate pooling of the available literature.

Figure 10 Mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency statin monotherapy in patients with CHD

ATV = atorvastatin; NR = not reported; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 10 shows mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency statin monotherapy in patients with CHD

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No studies reported on HDL-c among patients with preexisting CHD. We graded the strength of evidence as insufficient (Table 16).

###### Total Cholesterol: HDL-c

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported total cholesterol: HDL-c ratio among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study reported total cholesterol:HDL-c ratio among patients with preexisting CHD.85 Combination therapy reduced total cholesterol: HDL by 9 percent more than monotherapy.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported total cholesterol: HDL-c ratio among patients with preexisting CHD.

###### Atherosclerosis

No study reported on atherosclerosis measures among patients with preexisting CHD.

###### Adherence

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on adherence among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Two studies reported on adherence among patients with preexisting CHD.97,100 One study100 showed similar adherence between groups, with adherence reported at >99 percent in both groups, although the authors did not provide detail on how they assessed adherence. The other study97 assessed adherence by tablet count and showed a slight advantage to combination therapy (difference 1.5%).

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on adherence among patients with preexisting CHD.

###### Any Adverse Event

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on occurrence of any adverse events among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Three studies reported on the occurrence of any adverse events among patients with preexisting CHD.85,97,108 In one comparison, there was no difference between the two groups.108 In two comparisons, more monotherapy group patients experienced this outcome (difference 3.9% to 7.5%).85,97

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on occurrence of any adverse events among patients with preexisting CHD.

###### Withdrawal Due to Adverse Events

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on withdrawals due to adverse events among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Five studies reported on withdrawals due to adverse events among patients with preexisting CHD.85,97,103,107,108 In all comparisons, more monotherapy patients experienced this outcome (difference 1.4% to 17.9%).

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on withdrawals due to adverse events among patients with preexisting CHD.

###### Elevated Liver Transaminases

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on elevated liver transaminases among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Six studies reported elevated liver transaminases (AST and/or ALT > 3 times ULN) among patients with preexisting CHD.85,97,100,104,107,108 In four comparisons, there was no difference in this outcome. In one comparison, more combination therapy patients experienced LFT elevation (difference 0.5%)85; in another comparison more monotherapy patients experienced this adverse event (difference 2.6%)100

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on elevated liver transaminases among patients with preexisting CHD.

###### Musculoskeletal Adverse Events

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on elevation in CPK or cases of myalgia among patients with preexisting CHD.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Four studies reported on elevations in CPK > 10 times ULN among patients with preexisting CHD.85,97,100,108 No participant experienced this event in any trial. One study reported on occurrence of myalgia among patients with preexisting CHD.104 There were no reported cases of myalgia in either group.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on elevation in CPK or cases of myalgia among patients with preexisting CHD.

###### Cancer

No study reported on cancer among patients with preexisting CHD.

###### New Onset Diabetes Mellitus

No study reported on cases of new onset diabetes mellitus among patients with preexisting CHD.

###### Acute Kidney Injury

No study reported on cases of acute kidney injury among patients with preexisting CHD.

###### Patients With Diabetes Mellitus

One study compared low potency statin therapy in combination with ezetimibe to high potency statin monotherapy in patients with DM.79 Four studies compared mid potency statin in combination with ezetimibe to high potency statin monotherapy in patients with DM. 87-89,106,109,124 One study compared low potency statin in combination with ezetimibe to mid potency statin monotherapy in patients with DM.122

###### Mortality

[underlined: Low] potency statin combination therapy [underlined: versus] high potency statin monotherapy. No study reported on mortality among patients with DM (Table 17).

Table 17 Low potency statin in combination with ezetimibe as compared to high potency statin monotherapy among [underlined: patients with DM]: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 1 (21) | Low | Indirect [LDL calculated ] | NA | Imprecise | Not detected None | Monotherapy therapy lowered LDL-c 2 percent more than combination therapy. | Insufficient
HDL-c | 1 (21) | Low | Direct [HDL calculated directly] | NA | Imprecise | Not detected None | Combination therapy resulted in no change in HDL-c; however, monotherapy lowered HDL-c by 6 percent. | Insufficient

DM = diabetes mellitus; HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Two studies reported mortality among patients with DM.87,89,106,124 Events were low. Two arms favored combination therapy, with 0.4 percent deaths in the monotherapy arm compared with 0 deaths in the combination arm and 0.5 percent deaths in the monotherapy arm compared with 0 deaths in the combination arm. P-value was not reported in one study87 and was reported as non-significant in the other.89,106,124 We graded the strength of evidence as insufficient (Table 18).

Table 18 Mid potency statin in combination with ezetimibe as compared to high potency statin monotherapy among [underlined: patients with DM]: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | 2 (806) | Low | Direct | Consistent [favored combo] | Imprecise | Not detected None | Two arms favored combination therapy, with 0.4 percent deaths in the monotherapy arm compared with 0 deaths in the combination arm and 0.5 percent deaths in the monotherapy arm compared with 0 deaths in the combination arm. | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Serious Adverse Events | 5 (1641) | Low | Direct | Inconsistent | Precise [meets OIS of 1208] | Not detected None | In four comparisons, there were more SAEs in the combo therapy group (difference 0.02% to 3.9%). In one comparison, there were more SAEs in the monotherapy group (difference 1.8%). One study reported no SAEs in either arm. | Insufficient
Surrogate Clinical Outcomes
LDL-c | 8^a^ (1807) | Low [< 1/2 trials low quality] | Indirect [LDL not directly measured in all trials] | Consistent [All trials favor high potency statin monotherapy] | Precise | Not detected None | In all studies, combination therapy lowered LDL more than monotherapy (difference 2.7 percent to 20.5 percent). | Moderate
HDL-c | 5 (1578) | Low | Direct [HDL calculated directly] | Consistent [favor mono therapy or neutral] | Imprecise | Not detected None | In three studies, combination therapy increased HDL-c more than monotherapy (difference 1.8 percent to 5.7 percent) | Moderate

DM = diabetes mellitus; HDL= high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

a Missing N in at least one trial.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on mortality among patients with DM.

###### Acute Coronary Events

No study reported on acute coronary events among patients with DM.

###### Cerebrovascular Disease

No study reported on cerebrovascular events among patients with DM.

###### Revascularization Procedures

No study reported on revascularization procedures among patients with DM.

###### Serious Adverse Events

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on serious adverse events among patients with DM.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Five studies (six arms) reported serious adverse events among patients with DM.87,88,97,101,109 In four comparisons, there were more SAEs in the combo therapy group (difference 0.02% to 3.9%). In one comparison, there were more SAEs in the monotherapy group (difference 1.8%). One study reported no SAEs in either arm109. We graded the strength of evidence as insufficient (Table 18).

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on serious adverse events among patients with DM.

###### LDL-c

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study reported LDL-c outcomes among patients with DM.79 Monotherapy therapy lowered LDL-c 2 percent more than combination therapy. No studies reported LDL-c goal attainment. We graded the strength of evidence as insufficient (Table 17).

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Eight studies reported LDL-c outcomes among patients with DM.87-89,97,106,109,124,101,85,98,99 In all studies, combination therapy lowered LDL-c more than monotherapy (difference 2.7% to 20.5%). We graded the strength of evidence as moderate. Although the direction of effect was consistent, the magnitude of effect varied widely, in part due to different doses and different endpoints. Two studies had multiple arms comparing mid potency statin combination therapy with different doses of high potency statin monotherapy.89,106,101,124 Only the highest dose of statin monotherapy is shown in the Figure 11. Of the other comparison arms, both favored combination therapy (difference 7.6% to 9%). Meta-analysis is not reported due to high heterogeneity (I^2^=93.6%).

Figure 11 Mean difference in percent LDL-c change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency monotherapy among patients with DM

ATV = atorvastatin; RSV = rosuvastatin; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 11 shows mean difference in percent LDL-c change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency monotherapy among patients with DM.

Three studies reported LDL-c goal attainment (LDL-c <100 mg/dL) among patients with DM.87-89,106,124 Two studies reported that 2 percent to 37 percent more patients attained this LDL-c goal when taking combination therapy as compared to monotherapy;88,89 however, the other study reported that 20 percent more patients in the monotherapy arm achieve this LDL-c goal as compared to combination therapy.87 Another study reported on patients attaining an LDL-c <70 mg/dL among patients with DM.97 This trial found that 18 percent more patients in the combination arm attained this LDL-c goal as compared to monotherapy.

One study also reported LDL-c outcomes by ethnic subgroups and found similar benefits for black and Hispanic patients with diabetes as those for the general diabetic population.88 The LS mean percent change comparing combination therapy – monotherapy was -15 percent in black patients and -26 percent in Hispanic patients. 88 Since this is only one trial, the strength of evidence for black patients with diabetes and Hispanic patients with diabetes is still insufficient.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One study reported LDL-c outcomes among patients with DM.122 Combination therapy lowered LDL-c 10 percent more than monotherapy. No studies reported LDL-c goal attainment. We graded the strength of evidence as insufficient (Table 19).

Table 19 Low potency statin in combination with ezetimibe as compared to mid potency statin monotherapy among [underlined: patients with DM]: strength of evidence

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 1 (24) | High | NR [not recorded if LDL was measured or calculated] | NA | Imprecise | Not detected None | Combination therapy lowered LDL-c 10% more than monotherapy. | Insufficient
HDL-c | 1 (24) | Low | Direct [HDL calculated directly] | NA | Imprecise | Not detected None | Combination therapy increased HDL-c by 1% more than monotherapy. | Insufficient

DM = diabetes mellitus; HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

###### HDL-c

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study reported HDL-c among patients with DM.79 Combination therapy resulted in no change in HDL-c; however, monotherapy lowered HDL-c by 6 percent. We graded the strength of evidence as insufficient (Table 17).

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Five studies reported HDL-c among patients with DM (8 comparisons).87-89,101,106,124,97 In three studies, combination therapy increased HDL-c more than monotherapy (difference 1.8% to 5.7%).88,101 Three studies were neutral (difference 0.1% to 0.74%)88 Two studies had multiple arms comparing mid potency statin combination therapy with different doses of high potency statin monotherapy.87,101 Only the highest dose of statin monotherapy is shown in the Figure 12. Of the other comparison arms, two out of two favored combination therapy (difference 3.8% to 4.5%).

Figure 12 Mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency monotherapy in patients with DM

ATV = atrovastatin; NR = not reported; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 12 shows mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with ezetimibe to high potency monotherapy in patients with DM.

We graded the strength of evidence as moderate (Table 18). In meta-analysis, the pooled effect size was -1.02 (95% CI -2.91, 0.86), I^2^=15.1%.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One study reported HDL-c among patients with DM.122 Combination therapy increased HDL-c by 1 percent more than monotherapy. We graded the strength of evidence as insufficient (Table 19).

###### Total Cholesterol: HDL-c

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on total cholesterol: HDL-c ratio among patients with DM.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Two studies reported total cholesterol:HDL ratio among patients with DM.87,88 Combination therapy lowered total cholesterol: HDL-c by 9.41 percent to 13.5 percent more than monotherapy.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on total cholesterol: HDL-c ratio among patients with DM.

###### Non-HDL-c

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on non-HDL-c among patients with DM.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Three studies reported on non-HDL-c among patients with DM (4 arms).87-89,106,124 Three arms favored combination therapy for lowering non-HDL,88,89 lowering non-HDL by 20 to 47.9 percent (difference 1.7% to 18.3%). One arm favored monotherapy87, and in that study non-HDL was raised in both groups (raised by 7.43% in the atorvastatin 20 arm and raised by 20.91% in the simvastatin 20/ezetimibe10 arm).

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on non-HDL-c among patients with DM.

###### Triglycerides

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on triglycerides among patients with DM.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Five studies reported on triglycerides among patients with DM (four arms).87-89,106,124 97,109 Three arms 89 106 87 ,124 ,125 favored monotherapy for triglyceride reduction (difference 2.7% to 4.26%). Two arms favored combination therapy 88 ,97 for triglyceride reduction (difference 4.5% to 6.7%).

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on triglycerides among patients with DM.

###### Atherosclerosis

No study reported on measures of atherosclerosis among patients with DM.

###### Adherence

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on adherence among patients with DM.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study reported adherence87, and showed similar high (98% adherence) adherence between both arms, although the authors did not provide details on how adherence was assessed.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on adherence among patients with DM.

###### Musculoskeletal Adverse Events

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on elevations in CPK or cases of myalgia among patients with DM.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Three studies reported on cases of myalgia among patients with DM.87,88,109 Events were low and one study favored monotherapy (0.5% in combination therapy patients, 0% in monotherapy patients).87 One study favored combination therapy (4.8% in monotherapy patients, 1.6% in combination therapy patients) In the third study no events were reported in either arm.88 One study reported on elevations of CPK > 10 times ULN.88 Monotherapy was favored.

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on elevations in CPK or cases of myalgia among patients with DM.

###### Elevated Liver Transaminases

No study reported on elevations in liver transaminases among patients with DM.

###### Withdrawal Due to Adverse Events

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on withdrawals due to adverse events among patients with DM.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Four studies reported withdrawals due to adverse events among patients with DM.87,88,97,101 Outcomes were low. In two comparisons, there were more withdrawals due to AE in the monotherapy arm than in the combination therapy arm (difference 1.5% to 2.9%)88,97 In three comparisons, there were more withdrawals in the combination therapy group (difference 0.5% to 2.3%).88,101

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on withdrawals due to adverse events among patients with DM.

###### Any Adverse Event

[underlined: Low] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No study reported on occurrence of any adverse events among patients with DM.

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Four studies (five comparisons) reported on occurrence of any adverse events among patients with DM.87,88,97,101 In four comparisons, there were more AEs in the combination therapy group (difference 1.5% to 8.3%). In one comparison, there were more AEs in the monotherapy group (difference 7.5%).

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. No study reported on occurrence of any adverse events among patients with DM.

###### Cancer

No study reported on cancer among patients with DM.

###### Acute Kidney Injury

No study reported on acute kidney injury among patients with DM.

###### Elderly Patients (> 75 Years Old)

Two studies reported outcomes for elderly participants.98,99,101 These trials compared mid potency statin in combination with ezetimibe to high potency statin monotherapy. With respect to clinical outcomes, these studies only reported on mortality and serious adverse events. With respect to surrogate outcomes, they reported on LDL-c, HDL-c, and total cholesterol:HDL ratio. With respect to short-term harms, these trials reported only on.

###### Mortality

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. No deaths occurred in the one study that examined this outcome among elderly patients.98,99 We graded the strength of evidence as insufficient

###### Serious Adverse Events

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study reported on serious adverse events among elderly patients.98,99 This study reported that 3 percent of elderly patients in the combination arm had a serious adverse event, while no elderly patients in the monotherapy group experienced a serious adverse event. We graded the strength of evidence as insufficient.

###### LDL-c

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Two studies reported on LDL-c outcomes among elderly patients.98 ,99 ,101

The LS mean percent change in LDL-c was 14 percent among the elderly participants in the monotherapy arm vs. 28.4 percent among the elderly participants in the combination therapy arm at 6 weeks (p<0.05); the LS mean percent change in LDL-c was -20.2 percent in the monotherapy group and -20.6 percent in the combination therapy group at 12 weeks (p>0.05).

Another study reported LDL-c change in the elderly subgroup 101 and favored combination therapy for LDL-c change (47.5% decrease in the monotherapy arm compared with 58% decrease in the combination therapy arm).

One study 98 ,99 examined LDL-c goal attainment in elderly patients, and reported that 45 percent of elderly patients in the combination therapy arm and 56 percent of patients in the monotherapy arm attained LDL-c goals at 12 weeks. We graded the strength of evidence as insufficient.

###### HDL-c

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study examined HDL-c among elderly patients.98,99 This study favored combination therapy at 6 weeks (0.6% HDL-c increase in monotherapy group at 6 weeks, 3.6% HDL-c increase in monotherapy group at 6 weeks) and at 12 weeks (1.4% HDL-c decrease in monotherapy group at 12 weeks, 2.4% HDL-c increase in combination therapy group at 12 weeks). We graded the strength of evidence as insufficient.

###### Total Cholesterol: HDL

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study examined total cholesterol: HDL-c change in elderly patients.98,99 Combination therapy was favored, with a 7.8 percent decrease in total cholesterol:HDL in monotherapy arm participants at 6 weeks, a 19 percent decrease in combination therapy arm participants at 6 weeks; a 10.8 percent decrease in monotherapy participants at 12 weeks and a 14.2 percent decrease in combination therapy patients at 12 weeks.

###### Any Adverse Event

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study 98,99 reported adverse events in elderly patients. 31 percent of elderly participants in the monotherapy arm had an AE by 12 weeks, while 30 percent in the combination arm had an AE by 12 weeks.

###### Withdrawal AE

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study 98 ,99 reported withdrawal due to adverse events in elderly patients. 2 percent of elderly participants in the monotherapy arm withdrew due to AE by 12 weeks, while 6 percent in the combination arm withdrew due to AE by 12 weeks.

###### Elevated Liver Transaminases

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study examined elevated liver transaminases in elderly patients, which was 0 percent in both groups at 12 weeks.98,99

###### Musculoskeletal Adverse Events

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study 98,99 examined elevated CPK > 10× ULN in elderly patients, which was 0 percent in both groups at 12 weeks.

###### Female Patients

Two studies reported outcomes for female participants.98,99,101 Both trials compared a mid potency statin in combination with ezetimibe to high potency statin monotherapy. These trials only reported on LDL-c outcomes.

###### LDL-c

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Three studies reported LDL-c outcome among female participants.88,98,99,101 Combination therapy lowered LDL-c more than monotherapy (difference 8 percent to 18 percent). We graded the strength of evidence as insufficient.

###### Asian Patients

One study reported outcomes for Asian participants.101 This trial compared a mid potency statin in combination with ezetimibe to high potency statin monotherapy. This trial only reported on LDL-c outcomes.

###### LDL-c

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. The one study that reported on LDL-c among Asian participants reported that monotherapy decreased LDL-c by 8 percent more than combination therapy. We graded the strength of evidence as insufficient.

###### Black Patients

One study reported outcomes for black participants.101 This trial compared a mid potency statin in combination with ezetimibe to high potency statin monotherapy. This trial only reported on LDL-c outcomes.

###### LDL-c

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. Two studies88,101 reported on LDL-c among black participants. Combination therapy decreased LDL-c by 15 to 16 percent more than monotherapy. We graded the strength of evidence as insufficient.

###### Hispanic Patients

One study reported outcomes for Hispanic participants.101 This trial compared a mid potency statin in combination with ezetimibe to high potency statin monotherapy. This trial only reported on LDL-c outcomes.

###### LDL-c

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One study88 reported on LDL-c among Hispanic participants. Combination therapy decreased LDL-c by 26 percent more than monotherapy. We graded the strength of evidence as insufficient.

### Combined Lipid-Modifying Therapy With Statin and Fibrate Versus Intensification of Statin Monotherapy

#### Study Characteristics

We included 4 RCTs (1,341 participants in eligible arms) that compared fibrate plus statin to intensification of statin monotherapy.70,110,111,123 All trials were parallel arm RCTs. One study was a multicenter trials conducted in North America.110 Two studies occurred in Europe, one was multicenter123 and the other single center.70 The final study was a single center trial in Asia.111 The treatment duration ranged from 12 to 52 weeks. Two trials included general populations of patients with hyperlipidemia.70,110 One study included only patients with recent ACS requiring percutaneous inventions, which was one of our subgroups of interest.111 Another study included only patients with type 2 diabetes with no known coronary artery disease, which was also one of our subgroups of interest.123 Three trials compared high potency statin monotherapy to mid potency statin in combination therapy.70,110,111 One trial also allowed comparisons of high potency statin monotherapy to low potency statin in combination with fibrate.70 One study compared mid potency statin monotherapy to low potency statin in combination therapy among patients with diabetes123 (Appendix E Evidence Tables).

#### Population Characteristics

The average participant was in their 50s for all trials. The proportion of female participants varied across trials, ranging from 4 percent to 55 percent. Race, smoking status, prior cardiovascular disease, revascularization events, and diabetes were not consistently reported across trials (Appendix E Evidence Tables).

#### Interventions

Two trials compared mid potency statin in combination with fibrates to high potency statin monotherapy in general populations.70,110 Both used simvastatin. One study compared low potency statin in combination with fibrates to high potency statin monotherapy, and used pravastatin.70 One study compared mid potency statin in combination with fibrates to high potency statin among patients with preexisting CHD, and used atorvastatin and simvastatin.111 One study compared low potency statin in combination with fibrates to mid potency statin monotherapy among diabetics,123 and used simvastatin. The trials used fenofibric acid, fenofibrate, gemfibrozil, or ciprofibrate in the combination arms.

#### Outcomes

##### Key Points

- Long-Term Benefits
  ○ Insufficient evidence for all potency comparisons.
- Serious Adverse Events
  ○ Insufficient evidence for all potency comparisons.
- Surrogate Outcomes
  ○ There is insufficient evidence to evaluate LDL-c or HDL-c effects of any statin potency.
- Short-Term Side Effects
  ○ Insufficient evidence for all potency comparisons.
- Adherence
  ○ Insufficient evidence for all potency comparisons.
- Subgroups
  ○ Insufficient evidence for all potency comparisons.

##### Long-Term Benefits and Serious Adverse Events (KQ1)

No studies reported on the comparative effectiveness of fibrate plus statin on long-term benefits as compared to intensification of statin monotherapy among adults regardless of statin potency. We graded the strength of evidence for mortality, acute coronary events, revascularization procedures, and serious adverse events as insufficient.

##### Surrogate Outcomes, Short-Term Side Effects and Adherence (KQ2)

All included RCTs evaluated surrogate outcomes including LDL -c and HDL-c. In a few RCTs, LDL-c goal attainment, total cholesterol:HDL ratio, medication adherence and adverse events including withdrawal, elevated liver transaminases elevated creatinine phosphokinase, rhabdomyolysis, myalgia, and new diagnosis of acute kidney injury were evaluated. We identified no studies that compared low potency statin in combination with fibrate to mid potency statin monotherapy. We identified no eligible non-randomized extensions of RCTs or FDA reports.

###### LDL-c

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported mean percent change in LDL-c.70 At 12 months, monotherapy lowered LDL-c 6 percent and 11 percent more than the two combination arms. This trial also reported LDL-c goal attainment, which similarly favored monotherapy (32 percent and 45 percent more patients in monotherapy arm). We graded the strength of evidence as insufficient. (Table 20).

Table 20 Low potency statin in combination with fibrate as compared to high potency statin monotherapy in [underlined: general populations]: strength of evidence domains and summary of key findings

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 1 (396) | Low [Jadad score 3] | Indirect [Calculated] | NA | Precise | None detected None | High potency statin monotherapy lowered LDL-c 6-11% more than combination arms at 12 months. | Insufficient
HDL-c | 1 (396) | Low [Jadad score 3] | Direct [Measured] | NA | Precise | None detected None | Low potency combination therapy raises HDL-c by 9-11% more than high potency statin monotherapy at 12 months. | Insufficient

NA = not applicable

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Overall, two trials reported mean percent change in LDL-c.70,110,127 Monotherapy lowered LDL-c 7 percent to 17 percent more than combination therapy.70,110 These differences were statistically significant in both trials. Duration of these trials ranged from 12 weeks to 12 months. One trial also reported the proportion of patients achieving LDL-c target and favored monotherapy.70 The results of all comparisons favored high potency statin monotherapy for lowering LDL-c (Figure 13). We graded the strength of evidence as insuffienct given the paucity of studies (Table 21).

Figure 13 Mean difference in percent LDL change from baseline to time point comparing mid potency combination therapy with fibrates to high potency statin monotherapy

ATV = atorvastatin; NR = not reported; RSV = rosuvastatin; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 13 shows mean difference in percent LDL change from baseline to time point comparing mid potency combination therapy with fibrates to high potency statin monotherapy

Table 21 Mid potency statin in combination with fibrate as compared to high potency statin monotherapy in [underlined: general populations]: strength of evidence domains and summary of key findings

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 2 (683) | Moderate [Jadad<3 in 1 trial] | Direct | Consistent [Comparisons favor monotherapy] | Precise | None detected None | High potency statin monotherapy lowers LDL-c by 7% to 17% more than combination therapy. | Insufficient
HDL-c | 2 (683) | Moderate [Jadad<3 in 1 trial] | Direct | Consistent [Comparisons favor combination therapy] | Precise | None detected None | Combination therapy raises HDL-c 8% to 14% more than high potency statin monotherapy. | Insufficient

NA = not applicable

###### HDL-c

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported mean percent change in HDL-c.70 At 12 months, combination therapy was more effective at increasing HDL-c than monotherapy (difference 9% and 11% favoring combination therapy arms). We graded the strength of evidence as insufficient (Table 20).

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Two trials reported mean percent change in HDL-c. 70 ,110 Combination therapy raised HDL-c 8 percent to 14 percent more than monotherapy (Figure 14). Duration of trials ranged from 12 weeks to 12 months. We graded the strength of evidence as insufficient (Table 21).

Figure 14 Mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with fibrates to high potency statin monotherapy

ATV = atorvastatin; NR = not reported; RSV = rosuvastatin; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 14 shows mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with fibrates to high potency statin monotherapy.

###### Total Cholesterol:HDL Ratio

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported mean percent change in total cholesterol:HDL ratio.70 The monotherapy arm decresed total cholesterol:HDL by 0 percent to 4 percent more than combination therapy. There was no statistically significant between group differences.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported mean percent change in total cholesterol:HDL ratio.70 Combination significantly lowered total cholesterol:HDL by 2 percent more than monotherapy at 12 months, which was a statistically significant difference.70

###### Adherence

No studies reported on adherence.

###### Any Adverse Events

No studies reported on occurrence of at least one adverse event.

###### Withdrawal Due to Adverse Events

No studies reported on withdrawals due to an adverse event.

###### Cancer

No studies reported on cancer.

###### Elevated Liver Transaminases

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported on elevated liver transaminases (AST and/or ALT greater than 3 times ULN).70 At 12 months, no cases of elevated liver transaminases were found in the monotherapy arm, while 1 case found in a combination arm.70

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Two trials reported on elevated liver transaminases (AST and/or ALT greater than 3 times ULN).70,110 Overall, few cases of elevated liver transaminases occurred. One trial had one case in the monotherapy arm, while none were reported in the combination arm.110 At 12 months, the other trial reported no cases of elevated liver transaminases in the monotherapy arm, while 3 cases were found in each of the two combination therapy arms.70

###### Musculoskeletal Adverse Events

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported on elevations of CPK greater than 3 times the upper limit of normal.70 At 12 months, there were no reported cases in the monotherapy arm and one case was identified in one of low potency statin in combination therapy arms.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported on elevations of CPK greater than 10 times the upper limit of normal. 110 At 12 weeks, there were 2 cases in the combination arm and none in monotherapy arm. Another trial reported elevationsof CPK greater than 3 times the upper limit of normal. There were no cases in the monotherapy arm and 1 case in one of two combination therapy arms at 12 months.70

One trial reported on occurrences of myalgia.110 In this trial, 5 percent of participants had myalgia in the both monotherapy arms and 4 percent of participants had mylagia in the combination arm.110 This study also reported on the occurrence of rhabdomyolysis, of which there were no cases identified in either arm during follow up.110

###### New Onset Diabetes Mellitus

No studies reported on new onset diabetes.

###### Acute Kidney Injury

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

No studies reported on acute kidney injury for this comparison.

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported on the occurrence of elevated creatinine.110 No cases occurred in the monotherapy arms and 4 cases occurred in the combination therapy arm (3.4%).

##### Subgroups of Patients (KQ 3)

We identified two trials that occurred exclusively among two of our a priori defined subgroups of interest: patients with preexisting CHD111 and patients with diabetes mellitus.123

###### Patients With Preexisting Coronary Heart Disease

One parallel arm RCT (102 eligible participants) compared high potency statin to mid potency statin in combination with fibrate among patients with preexisting CHD.111 The study did not report on the comparative effectiveness of fibrate plus statin on long-term benefits as compared to intensification of statin monotherapy for clinical outcomes including mortality, acute coronary events, and revascularization procedures, nor serious adverse events. Given the paucity of studies, we graded the strength of evidence for all outcomes as insufficient (Table 22).

Table 22 Mid potency statin in combination with fibrate as compared to high potency statin monotherapy among [underlined: patients with CHD]: strength of evidence domains and summary of key findings

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | N/A | N/A | NA | NA | NA NA | No eligible studies | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 1 (102) | High [Jadad<3] | Direct [Measured] | N/A | Imprecise | None detected None | Monotherapy lowered LDL-c by 1% to 14% percent more than combination therapy | Insufficient
HDL-c | 1 (102) | High [Jadad<3] | Direct [Measured] | N/A | Imprecise | None detected None | Combination therapy raised HDL-c by 4% to 24% more than atorvastatin monotherapy | Insufficient

CHD = coronary heart disease; NA = not applicable

###### LDL-c

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One trial reported on mean percent change in LDL-c among patients with preexisting CHD.111 Monotherapy lowered LDL-c by 1 percent to 14 percent more than combination therapy. We graded the strength of evidence as insufficient.

###### HDL-c

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One trial reported on mean percent change in HDL-c among patients with preexisting CHD.111 Combination therapy with atorvastatin raised HDL-c by 4 percent to 24 percent more than cmonotherapy. Combination therapy with simvastatin raised HDL-c 16 percent more than atorvastatin monotherapy; however, simvastatin monotherapy produced a 3 percent greater increase in HDL-c as compared to this combination. We graded the strength of evidence as insufficient.

###### Total Cholesterol: HDL-c Ratio

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One trial reported on mean percent change in total cholesterol:HDL-c ratio among patients with preexisting CHD.111 At 12 weeks, total cholesterol:HDL-c decreased by 14 percent in the atorvastatin monotherapy arm and by 17 percent in simvastatin monotherapy arm. In the two combination therapy arms, total cholesterol:HDL-c decreased by 23 percent (combination with mid potency atorvastatin) and 16 percent (combination with mid potency simvastatin).111

###### Elevated Liver Transaminases

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One trial reported on occurrence of elevated liver transaminases among patients with preexisting CHD.111 At 12 weeks, there was no significant elevations of AST and/or ALT greater than 3 times the upper limit of normal found in any arm.

###### Adverse Musculoskeletal Events

[underlined: Mid] potency statin combination therapy versus [underlined: high] potency statin monotherapy. One trial reported on myalgia among patients with preexisting CHD.111 At 12 weeks, there were no reported cases on myalgia in the atorvastatin monotherapy arm and 2 cases in simvastatin monotherapy arm. There were no cases in either mid potency statin combination therapy arms.

###### Patients With Diabetes Mellitus

One parallel arm RCT (291 eligible participants) compared mid potency statin to low potency statin in combination with fibrate.123 The study did not report on the comparative effectiveness of fibrate plus statin on long-term benefits as compared to intensification of statin monotherapy for mortality or revascularization procedures. Given the paucity of studies, we graded the strength of evidence for all outcomes as insufficient (Table 23).

Table 23 Low potency statin in combination with fibrates as compared to mid potency statin monotherapy among [underlined: patients with diabetes mellitus]: strength of evidence domains and summary of key findings

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | 1 (291) | Low | Direct | NA | Imprecise | None detected None | No reported deaths in both arms | Insufficient
Acute Coronary Events | 1 (291) | Low | Direct | NA | Imprecise | None detected None | No difference between groups | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Serious Adverse Events | 1 (291) | Low | Direct | NA | Precise | None detected None | No difference between groups | Insufficient
Surrogate Clinical Outcomes
LDL-c | 1 (291) | Low | Direct | N/A | Precise | None detected None | Monotherapy decreased LDL-c 2% more than combination therapy | Insufficient
HDL-c | 1 (291) | Low | Direct | N/A | Precise | None detected None | Combination therapy significantly raised HDL-c 4 % more than monotherapy | Insufficient

NA = not applicable

###### Acute Coronary Events

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported on acute coronary events among patients with DM.123 At 24 weeks, no cases of MI occured in the monotherapy arm and one MI occured in combination therapy arm.

###### Cerebrovascular Disease

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported on cerebrovascular events among patients with DM.123 At 24 weeks, one TIA occurred in the monotherapy arm and no events in the combination therapy arm.

###### Serious Adverse Events

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported on serious adverse events among patients with DM.123 At 24 weeks, one serious adverse event in each arm (1% of patients).

###### LDL-c

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported the mean percent LDL-c change among patients with DM.123 Monotherapy decreased LDL-c 2 percent more than combination therapy, which was not a significant between group differences. This trial also reported proporiton of patient that achieve an LDL-c <100 mg/dL. Interestingly, 6 percent more patients in the combination arm attained this LDL-c goal as compared to the monotherapy group at 12 weeks followup.

###### HDL-c

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported the mean percent HDL-c change among patients with DM.123 Combination therapy significantly raised HDL-c 4 percent more than the monotherapy arm.

###### Non-HDL-c

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported the mean percent non-HDL-c change among patients with DM.123 Combination therapy decreased non-HDL-c 6 percent more than monotherapy.

###### Triglycerides

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported the mean percent change in triglycerides among patients with DM.123 Combination therapy lowered triglycerides 31 percent more than monotherapy at 12 weeks.

###### Adherence

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported on adherence among patients with DM.123 At 12 weeks, the trial reported 98 percent treatment adherence in the mid potency statin monotherapy arm and 99 percent treatment adherence in the low potency statin combination arm. In this trial, adherence to medication was defined >80 percent compliance.123

###### Any Adverse Event

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported the occurrence of at least one adverse event among patients with DM.123 At 12 weeks, the trial reported 15 percent of participants in the monotherapy arm and 17 percent in the combination therapy arm had at least one adverse event.

###### Musculoskeletal Adverse Events

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported on the occurrence of CPK elevations among patients with DM.123 There were no cases of CPK elevations >10 times ULN in either arm.

###### Acute Kidney Injury

[underlined: Low] potency statin combination therapy versus [underlined: mid] potency statin monotherapy. One trial reported the occurrence of acute kidney injury among patients with DM.123 There were no cases in either arm.

### Combined Lipid-Modifying Therapy With Statin and Niacin Versus Intensification of Statin Monotherapy

#### Study Characteristics

We included five trials (612 participants in eligible arms) that compared niacin plus statin to intensification of statin monotherapy. All trials were parallel arm randomized controlled trials that took place in North America.81,95,119-121 All trials were multicenter, except for one single center trial.119 Eligibility criteria were similar across all trials. All trials included a dietary run in, followed by treatment ranging from 6 weeks to 52 weeks in duration. Two trials compared mid potency statin in combination therapy to high potency statin monotherapy.81,95 The other three trials compared low potency statin in combination therapy to mid potency statin monotherapy119-121 (Appendix E Evidence Tables).

#### Population Characteristics

In four trials,90,95,119-121 the average participant was in their 50s with the mean age ranging from 49-61 years. In the other trial, the study's average participant was in their 70s.81 Female participants varied between trials and ranged from 21 to 79 percent in each arm. Race was reported in most trials, and the majority of participants were white (range 61 to 96 percent of participants in included arms). The arms in one trial differed significantly by race.81 Smoking status, prior cardiovascular disease, revascularization events, and diabetes were not consistently reported across trials. When reported, no significant between group differences existed in the trials95,119,120 (Appendix E Evidence Tables).

#### Interventions

Two trials compared mid potency statin in combination with extended release niacin to high potency statin monotherapy.81,95 These monotherapy arms used atorvastatin, and simvastatin, and the combination arms used lovastatin or simvastatin. Three trials compared mid potency statin monotherapy to low potency statin in combination with niacin.119-121 All these trials used lovastatin as the statin in both the monotherapy and combination therapy arms. Across all trials, patients had their dose of niacin titrated up over the study period with the final doses ranging from 1g to 2.5g.

#### Outcomes

##### Key Points

- Long-Term Benefits
  ○ Insufficient evidence for all potency comparisons.
- Serious Adverse Events
  ○ Insufficient evidence for all potency comparisons.
- Surrogate Outcomes
  ○ There is insufficient evidence to compare combined lipid-modifying therapy with niacin and statin to instensificatin of statin monotherapy on lowering LDL-c, regardless of statin potency
  ○ A low potency statin monotherpy with niacin is more effective than mid potency statin monotherapy for raising HDL-c (SOE: moderate). There is insufficient evidence within other potency comparisons.
- Adherence
  ○ Insufficient evidence for all potency comparisons.
- Short-Term Side Effects
  ○ There is insufficient evidence to compare the rates of adverse events for any statin potency comparisons.
  ○ The evidence suggests that there is no difference in the rates of elevated liver transaminases between combined lipid-modifying therapy with niacin and mid potency statin to high potency statin monotherapy. There is insufficient evidence within other potency comparisons.
  ○ There is insufficient evidence to compare the rates of adverse musculoskeletal events for any statin potency comparisons.
- Subgroups
  ○ Insufficient evidence for all potency comparisons.

##### Long-Term Benefits and Serious Adverse Events (KQ 1)

Few studies reported on the comparative effectiveness of niacin plus statin on long-term benefits as compared to intensification of statin monotherapy among adults. We graded the strength of evidence for mortality, acute coronary events, revascularization procedures, and serious adverse events as insufficient (Table 24). We identified no studies that compared low potency statin combination therapy to high potency statin monotherapy.

Table 24 Mid potency statin in combination with niacin as compared to high potency statin monotherapy in [underlined: general populations]: strength of evidence domains and key findings

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Acute Coronary Events | 1 (50) | Low [Double blind; low attrition] | Direct | NA | Imprecise | None detected None | One ACS event in the high potency monotherapy arm and no events in the combination arm at 12 months. | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 2 (365) | Moderate [1 trials with Jadad score<3; 1 trial from 2013 update with low risk of bias] | Indirect [LDL calculated in 1 trials] | Inconsistent [2 comparisons favor statin monotherapy; 2 comparisons favors combination therapy; 1 comparison no difference] | Imprecise | None detected None | Inconsistent effects on LDL-c when comparing combination therapy with niacin and statin to intensification of statin monotherapy. | Insufficient
HDL-c | 2 (365) | Moderate [1 trials with Jadad score<3; 1 trial from 2013 update with low risk of bias] | Direct [HDL measured in all trials] | Consistent [All comparisons favor combination therapy] | Imprecise | None detected None | All studies favor mid potency combination therapy by raising HDL-c by 10-26% more than high potency statin monotherapy at 8-26 weeks. | Insufficient

HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

###### Mortality

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

No studies reported deaths.

###### [underlined: Low Potency] Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One study reported the number of deaths during the trial.120 There was one death in both the mid potency statin monotherapy arm and the low potency statin combination arm; both were considered vascular deaths.

###### Acute Coronary Events

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One study evaluated counts of ACS events during the 12-month study period.81 One ACS event occurred in the monotherapy arm, while there were no events in the combination therapy arm. There was no between group difference reported.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

No studies reported on acute coronary events.

###### Cerebrovascular Disease

No studies reported on cerebrovascular events.

###### Revascularization Procedures

No studies reported on revascularization procedures.

###### Serious Adverse Events

No studies reported on serious adverse events.

##### Surrogate Outcomes, Short-Term Side Effects and Adherence (KQ 2)

All included RCTs evaluated surrogate outcomes including LDL-c and HDL-c. In several RCTs, medication adherence and short-term side effects were evaluated including elevated liver transaminases and elevated creatinine phosphokinase. We identified no studies that compared high potency statin monotherapy to low potency statin combination therapy. We identified no eligible non-randomized extensions of RCTs or FDA reports.

###### LDL-c

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Two trials reported mean percent change in LDL-c (3 comparisons).81,95 In one trial, one comparison favored monotherapy for lowering LDL-c (1 percent to 12 percent greater decrease) as compared to combination therapy.95 In one trial, one comparison found no difference between monotherapy and combination therapy for lowering LDL-c.95 Finally, two comparisons reported in two trials favored combination therapy for lowering LDL-c (3 percent to 22 percent greater decrease) as compared to monotherapy.81,95

The results did not favor either high potency statin monotherapy or mid potency statin in combination with niacin for lowering LDL-c (Figure 15). One trial strongly trial favored combination therapy,81 and differed from the other trial in several ways. First, patients had to have hyperlipidemia and at least 30 percent carotid stenosis on ultrasound to be included, whereas all other trials recruited patients based only on have hyperlipidemia. Second, the baseline LDL values in this trial were much lower than the other trial, as there was no washout of prior lipid-lowering medications. Finally, the baseline LDL value in the monotherapy arm was lower (median 107 mg/dL) than the combination therapy arm (124mg/dL). All three of these factors may explain the different results in this trial. We graded the strength of evidence as insufficient (Table 24).

Figure 15 Mean difference in percent LDL change from baseline to time point comparing mid potency combination therapy with niacin to high potency monotherapy

ATV = atrovastatin; ER = extended release; LOV = Lovastatin; NR = not reported; RSV = rosuvastatin; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 15 shows mean difference in percent LDL change from baseline to time point comparing mid potency combination therapy with niacin to high potency monotherapy.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Three trials reported mean percent LDL-c change.119-121 Overall, the effects on LDL-c were variable. At 6 weeks,119 one trial found that both the statin monotherapy arm and combination arm reduced LDL-c by 8 percent. At 20 weeks,121 another trial found that the two combination arms each reduced LDL-c 12 percent more than the statin monotherapy arm. At 28 weeks, the final trial found that monotherapy decreased LDL-c 4 percent more than combination therapy.120

The results did not favor either mid potency statin monotherapy or low potency statin in combination with niacin for lowering LDL-c. In one trial that favored combination therapy,121 investigators used higher doses of niacin-ER (2.5g) than the other trial that favored statin monotherapy (niacin-ER 1g).120 This difference in niacin dose may explain the difference in LDL effect among these trials. We graded the strength of evidence as insufficient (Table 25). While three trials reported on this comparison, only one of the trials reported or provided sufficient information for us to calculate SE for the LDL-c difference in differences. Therefore, we did not perform meta-analysis.

Table 25 Low potency statin in combination with niacin as compared to mid potency statin monotherapy in [underlined: general populations]: strength of evidence domains and key findings

Outcome | No. Studies (N) | Risk of Bias | Directness | Consistency | Precision | Reporting Bias Other Issues | Findings and Magnitude of Effect | Strength of Evidence
Long-Term Benefits and Serious Adverse Events
Mortality | 1 (118) | Low [Jadad score≥3] | Direct | NA | Imprecise | None detected None | One death in the mid potency statin monotherapy group and one death in the low potency statin in combination with niacin group at 28 weeks. | Insufficient
Acute Coronary Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Revascularization Procedures | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Serious Adverse Events | None | NA | NA | NA | NA | NA NA | No eligible studies | Insufficient
Surrogate Clinical Outcomes
LDL-c | 3 (247) | Low [1 trial with Jadad score<3] | Indirect [LDL calculated in 2 trials] | Inconsistent [1 comparison favors monotherapy; 2 comparisons favor combination therapy; 1 comparison with no difference] | Imprecise | None detected None | Three studies show no consistent effect in LDL-c reduction between mid potency statin montherapy and low potency statin in combination with niacin at 6-28 weeks. | Insufficient
HDL-c | 3 (247) | Low [1 trial with Jadad score<3] | Direct [HDL measured in all trials] | Consistent [All trials favor combination therapy] | Imprecise | None detected None | All studies favor low potency combination therapy by raising HDL-c by 15-27% more than mid potency statin monotherapy at 6-28 weeks. | Moderate

HDL = high-density lipoprotein; LDL = low-density lipoprotein; NA = not applicable

###### HDL-c

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Two trials reported mean percent change in HDL-c.81 ,95 Both trials favored combination therapy in raising HDL-c (10 percent to 26 percent greater increase) as compared to monotherapy (Figure 16). Treatment duration ranged from 8 weeks to 12 months. We graded the strength of evidence as insufficient, given the paacity of studies.

Figure 16 Mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with niacin to high potency statin monotherapy

ATV = atrovastatin; ER = extended-release; NR = not reported; RSV = rosuvastatin; SMV = simvastatin

Note: For diamonds without confidence intervals, SE/SD could not be calculated.

Figure 16 shows mean difference in percent HDL change from baseline to time point comparing mid potency combination therapy with niacin to high potency statin monotherapy.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Three trials reported mean percent change in HDL-c.119-121 All trials favored combination therapy in raising HDL-c (15 percent to 27 percent greater increase) as compared to monotherapy. We graded the strength of evidence as moderate (Table 23). While three trials reported on this comparison, only one of the trials reported or provided sufficient information for us to calculate SE for the HDL-c difference in differences. Therefore, we did not perform meta-analysis.

###### Total Cholesterol: HDL

No studies reported mean percent change in total cholesterol:HDL ratio.

###### Atherosclerosis

No studies reported on atherosclerosis.

###### Adherence

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported on treatment adherence.95 ,128 Adherence was ≥94 percent in all arms at 16 weeks.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One trial reported on treatment adherence.121 Adherence to medications was 96 percent in both arms at 20 weeks.

###### Any Adverse Event

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

No studies reported on the occurrence of at least one adverse event for this comparison.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One trial reported the number of participants who experienced at least one adverse event.121 In the statin monotherapy arm, 52 percent of participants had at least one adverse event, while 44 percent in one combination arm (N-ER 2.5g + LOV 10mg) and 62 percent in the other combination arm (N-ER 2.5g + LOV 20mg) had at least one adverse event during the 20-week study period. Calculated p-values for these comparisons were not significant.

###### Withdrawal Due to Adverse Events

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

No studies reported withdrawals due to adverse events.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One trial reported the number of participants who withdrew from the study due to an adverse event.120 At 28 weeks, 19 percent of participants in the mid potency statin monotherapy arm and 10 percent in the low potency statin combination arm withdrew due to an adverse event, which was not significantly different.

###### Cancer

No studies reported on cancer.

###### Elevated Liver Transaminases

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

Two trials reported on significant elevations in AST and/or ALT.81,95,128 There were no reported cases of elevated AST and/or ALT greater than 3 times the ULN in one trial.95,128 The other trial reported that 1 participant experienced liver transaminase elevations in the high potency statin monotherapy arm and no cases in the mid potency statin combination arm.81

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Two trials reported on significant elevations in AST and/or ALT.120,121 There were two cases of elevated AST and/or ALT greater than 3 times the ULN at 20 weeks in one trial, one in each combination arm (N-ER 2.5g + LOV 10mg and N-ER 2.5g + LOV 20mg).121 While there was one case of elevated AST and/or ALT greater than 3 times the ULN in the statin monotherapy arm at 28 weeks in the other trial.120

###### Adverse Musculoskeletal Events

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

One trial reported on occurrences of myalgia.81 There were 2 cases of muscle cramping in the high potency statin monotherapy arm and no cases in the mid potency combination arm.81

One trial reported on elevations of CPK.95 No cases of CPK elevations greater than 5 times the upper limit of normal were identified at 16 weeks.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

One trial reported on occurrences of myalgia.120 At 28 weeks, 7 percent of participants in the monotherapy arm and 4 percent in the combination arm reported muscle aches.

Two trials reported on elevations of CPK.120,121 One trial reported on CPK elevations greater than 3 times the ULN at 20 weeks,121 while the other reported on CPK elevations greater than 10 times the ULN at 28 weeks.120 No cases of CPK elevations were identified in either trial.

###### New Onset Diabetes Mellitus

###### [underlined: Mid] Potency Statin Combination Therapy Versus [underlined: High] Potency Statin Monotherapy

No studies compared any diabetes-related outcomes.

###### [underlined: Low] Potency Statin Combination Therapy Versus [underlined: Mid] Potency Statin Monotherapy

Two trials reported on hyperglycemia.120,121 At 20 weeks, there were no cases of hyperglycemia in the statin monotherapy arm, while 6 percent and 3 percent of patients in the combination therapy arms (N-ER 2.5g + LOV 10mg and N-ER 2.5g + LOV 20mg, respectively) experienced hyperglycemia.121 In the other trial, 7 percent of monotherapy arm participants and 4 percent of combination arm participants had fasting glucose elevated greater than 1.3 times the ULN at 28 weeks.120

###### Acute Kidney Injury

No studies reported on acute kidney injury.

##### Subgroups of Patients (KQ 3)

No studies reported on the comparative effectiveness of niacin plus statin on benefits or harms as compared to intensification of statin monotherapy among subgroups.

### Combined Lipid-Modifying Therapy With Statin and Omega-3 Fatty Acid Versus Intensification of Statin Monotherapy

We identified no relevant studies that included omega-3 fatty acids.