# Methods

## Topic Development

This review is an update of an evidence report completed in 2009.^56^ The summary of changes from the previous systematic review is shown in Table 2. The protocol for our review was posted on the AHRQ Web site (www.effectivehealthcare.ahrq.gov) on May 17, 2013.

Table 2 Summary of changes from prior report

Population | We included adults at moderate and high risk of cardiovascular disease (the prior report had no restrictions by patient CVD risk level). We specifically excluded studies of patients with homozygous familial hypercholesterolemia.
Intervention | We included drugs that were not FDA-approved at the time of the prior review.
Outcomes | We added diabetes mellitus and acute kidney injury/chronic kidney disease as potential harms.
Type of Study and Timing | We reviewed nonrandomized studies that were extensions of RCTs. The prior evidence report considered any nonrandomized study over 24 weeks' duration.
Data Synthesis | In order to avoid multiple comparisons across numerous permutations of lower versus higher dose statins, we grouped statins based on their potency to reduce LDL-c.

## Search Strategy

Using the same basic search rules used for the original report (with the addition of terms for newly added drugs), we searched the following databases for primary studies: MEDLINE^®^, Embase^®^, and the Cochrane Central Register of Controlled Trials (CENTRAL). Our search strategy for MEDLINE is shown in Appendix B. The search for the prior review included MEDLINE from 1966 to May 2009, Embase from 1980 to May 2009, and The Cochrane Library to the third quarter of 2008. We included an overlap in search dates, per AHRQ guidance on updating reviews,57 searching MEDLINE from May 2008 to July 2013, Embase from May 2008 to July 2013, and The Cochrane Library from the fourth quarter of 2007 to July 2013. We also reviewed references from relevant review articles. Pharmaceutical companies who produce the drugs included in this review were asked to provide information as Scientific Information Packets (SIPs) about pertinent studies (published or unpublished).

## Study Selection

Abstracts were screened independently by two trained reviewers, and were excluded if both reviewers agreed that the article met one or more of the exclusion criteria (see inclusion and exclusion criteria listed in Table 3 and the Abstract Screen Form in Appendix C). In brief, we included randomized controlled trials (RCT) of adults that compared a higher potency of statin monotherapy to a lower potency statin in combination with another agent (bile acid sequestrant, ezetimibe, fibrate, niacin, or omega-3 fatty acid). The clinical outcomes of interest were mortality, coronary heart disease events, cerebrovascular events, revascularization procedures, and serious adverse events (as reported by investigators), while our surrogate clinical outcomes included lipid measures (e.g., LDL-c, HDL-c), atherosclerosis, and medication adherence. Triglycerides and non-HDL-c were only considered for diabetic subgroup as per ATP III guidelines. Adverse effects included cancer, elevated liver transaminases, musculoskeletal adverse events, diabetes mellitus, and acute kidney injury. Given the limited duration of many RCTs, we also considered observational trials to examine clinical outcomes, serious adverse events and harms. As in the prior evidence report, we considered non-randomized comparative studies of 24 weeks or more in duration for clinical outcomes, serious adverse events, and harms, which were extensions of controlled clinical trials. These are trials in which patients are unblinded and continue to receive the therapies they were originally assigned. Finally, we also searched FDA reports for serious adverse events and harms. Differences between reviewers regarding abstract eligibility were resolved through consensus.

Table 3 List of inclusion/exclusion criteria

Population and condition of interest | Adults with moderate (10-year CHD risk 10-20% or LDL≥160 mg/dL) or high (10-year CHD risk≥20% or LDL≥190 mg/dL) cardiovascular disease risk Excluded studies if they included only adults with low cardiovascular disease risk (CHD risk<10% or LDL<160 mg/dL) Excluded studies that included only patients with homozygous familial hypercholesterolemia (FH)
Interventions and approaches | Studies must have evaluated a combination regimen of interest Included studies of bile acid sequestrants + statin Included studies of ezetimibe + statin Included studies of fibrates + statin Included studies of niacin + statin Included studies of omega-3 fatty acids + statin Excluded studies of lifestyle modifications Excluded studies of drugs approved only for the treatment of homozygous FH Excluded studies of drugs not approved by the FDA or investigational drug Excluded studies of prepackaged medications that contained non lipid-lowering medications
Comparisons of interest | Included comparisons of higher potency statin monotherapy Excluded studies if a study statin monotherapy was of the same or lower potency than combination arm Excluded studies if there was no comparison, only placebo comparison, or comparison to other combination therapy regimen.
Outcomes and Timing | Clinical outcomes including mortality, cardiovascular events, cerebrovascular events, revascularization procedures at any time point Surrogate outcomes including LDL-c, HDL-c, TC:HDL-c ratio, NCEP ATP IIL LDL-c target attainment, measures of atherosclerosis (e.g., carotid intimal media wall thickness, coronary artery calcification score, etc) at any time point. Triglycerides and non-HDL-c in diabetes subgroup. Adherence and harms outcomes including adherence, serious adverse events (as reported by investigators), withdrawal due to adverse events, cancer, elevated liver transaminases, adverse musculoskeletal events, diabetes mellitus, acute kidney injury at any time point
Type of study | Included studies with any sample size that met all other criteria. Included studies from the prior report that met all other criteria. Included randomized controlled trials () Included non-randomized extension of clinical trial over 24 weeks duration (clinical outcomes, SAE and harms only), and Included FDA reports (SAE and harms only) Excluded studies with other observational designs. Excluded studies with no original data (reviews, editorials, comments, letters, modeling only studies). Excluded studies published only as abstracts. Excluded qualitative studies. Excluded crossover trials with fewer than 4 weeks washout and/or lacking paired observation, within person differences, or pre-crossover data. Excluded non-English publications.

CHD = coronary heart disease; FDA = Food and Drug Administration; FH = familial hypercholesterolemia; HDL = high-density lipoprotein; LDL = low-density lipoprotein; RCT = randomized controlled trial; SAE = serious adverse event; TC = total cholesterol

Citations promoted on the basis of abstract screen underwent independent paired-reviewer screen using the full text article (Appendix C, Article Screen Form). Differences regarding article inclusion were resolved through consensus.

At this level, we also screened all studies included in the prior review to ensure that they met the current eligibility criteria.

## Data Abstraction and Data Management

We used DistillerSR (EvidencePartners, 2010) to manage the screening process. We uploaded to the system all citations identified by the search strategies.

We created and pilot tested standardized forms for data extraction (Appendix C). We used the Systematic Review Data Repository™ (SRDR) for data abstraction. Data were exported from SRDR into a project-specific database (Access, Microsoft, Redmond, WA) to serve as archived copy and to create evidence tables and summary tables.

Reviewers extracted information on general study characteristics (e.g., study design, study period, and followup), study participants (e.g., age, sex, race/ethnicity, etc.), eligibility criteria, interventions (e.g., medication name, medication dose), outcome measures and the method of ascertainment, and the results of each outcome including measures of variability. We incorporated cross-over trials by taking all measurements from combination regimen intervention periods and all measurements from monotherapy regimen intervention periods and analyzing them as if the trial were a parallel group trial. One reviewer completed data abstraction and a second reviewer confirmed the first reviewer's abstraction for completeness and accuracy. Because data previously abstracted from the trials included in the prior review were incomplete for our needs, we abstracted the data from the studies that met the current eligibility criteria in order to have a complete repository of data for analysis. Reviewer pairs included personnel with both clinical and methodological expertise. We resolved differences between reviewer pairs through discussion and, as needed, through consensus among the larger group of investigators.

## Risk of Bias Assessment

We used the Cochrane Collaboration's tool for assessing the risk of bias of controlled studies.58 Two trained reviewers independently assessed the included studies according to the guidelines in Chapter 8 of the Cochrane Handbook for Systematic Reviews of Interventions. For studies included from the prior review, we used the prior quality assessments reported, which were based on the Jadad Score.

## Data Synthesis

For each KQ, we created a detailed set of evidence tables containing all information abstracted from eligible studies. We integrated the results of all studies (RCTs + NRSs) qualitatively. In all comparisons, we noted that the evidence base uses different statins both within studies (monotherapy arms uses one statin and combination therapy uses a different statin) and across studies. In addition, a variety of statin doses were also used across studies. Therefore, synthesizing data by statin and statin dose would limit the number of studies amenable to pooling. A recent systematic review grouped statins and statin doses based on their potency to reduce LDL-c (Table 4).59 We opted to use this potency strategy to group together different statins and statin doses to make comparisons, which increased out number of studies amenable to pooling. This represents a change from the approach used in the original review, in which statins were grouped according to dose.

Table 4 List of different dosing of specific statins based on potency to reduce LDL-c

Statin | Atorvastatin (mg/day) | Fluvastatin (mg/day) | Fluvasatin XL (mg/day) | Lovastatin (mg/day) | Pitavastatin (mg/day) | Pravastatin (mg/day) | Rosuvastatin (mg/day) | Simvastatin (mg/day)
Low Potency (<30% LDL reduction) | 5 | 20 and/or 40 | -- | 5 and/or 10 and/or 20 | 1 | 10 and/or 20 and/or 40 | -- | 10
Mid Potency (30-40% LDL reduction) | 10 | 80 | 80 | 40 and/or 80 | 2 and/or 4 | 80 | 2.5^a^ | 20
High Potency (>40% LDL reduction) | 20 and/or 40 and/or 80 | -- | -- | -- | -- | -- | 5, 10, 20 and/or 40 | 40 and/or 80^b^

a Dose not included in this review; information obtained from “FDA Advisory Committee Meeting Briefing Document NDA 21-366 for the use of CRESTOR.”

b Studies that use simvastatin 80mg in statin naïve patients will be excluded.

Meta-analysis was considered for outcomes selected as most important for grading the strength of evidence (see below). Studies were grouped such that meta-analyses included the same potency comparisons (i.e., high potency monotherapy versus mid potency combination therapy). For studies that had two monotherapy arms of the same potency, we used only one of these arms as the comparator to the combination arm(s). We used the following rules to select which monotherapy arm to use:

1. If the arms use the same statin, we used the arm with the higher dose.
2. If the arms use different statins, we selected the arm based on the following prioritization of statin agent if it met higher potency criteria: rosuvastatin, atorvastatin, simvastatin, lovastatin, pravastatin, fluvastatin.60 We identified no studies that used pitavastatin.

We only conducted meta-analyses when there were sufficient data (at least 3 studies of the same design that reported or provided data to calculate SE for difference in differences) and studies were judged to be sufficiently homogenous with respect to key variables (population characteristics, intervention, and outcome). Many studies did not provide sufficient data to calculate SE for difference in differences. When SE was available for most studies included within a specific comparison, we imputed the SE for these other studies. We averaged the reported SE and used this value for the imputed SE.61 We then conducted sensitivity analysis by completing meta-analyses with and without the imputed SE.

For studies amenable to meta-analysis, we calculated a weighted mean difference using a random effects model with the DerSimonian and Laird formula for continuous outcomes.62 We evaluated statistical heterogeneity among studies using an I^2^ statistic. We had no dichotomous or event outcomes that met our criteria to consider conducting meta-analyses. Given the lack of outcomes meeting our criteria for meta-analysis and significant heterogeneity detected when meta-analyses were conducted (I^2^>50%), we report qualitative synthesis of data for all outcomes. We examined the forest plots to identify trials that appeared to have quite different results and considered if these trials had different characteristics. We plannted to conduct sensitivity analysis by excluding such trials and rerunning meta-analyses, but in all cases we identified no trials meeting this criteria or removing these trials would have left fewer than 3 trials to be pooled. The limited number of studies included in each meta-analysis precluded any further sensitivity analyses of subgroups or meta-regression to determine the source of heterogeneity. All analyses were conducted using STATA versions 11.0 and 12.0 (StataCorp LP).

## Strength of the Body of Evidence

We graded the strength of evidence using the grading scheme recommended by the Methods Guide for Effectiveness and Comparative Effectiveness Reviews (Methods Guide).63 For this report, we graded the strength of evidence for the outcomes determined to be most important: mortality, acute coronary events, revascularization procedures, serious adverse events, LDL-c and HDL-c.

In assigning evidence grades, we considered the four required domains including risk of bias, directness, consistency and precision. For outcomes where meta-analysis was not conducted, precision was determined based on the measures of dispersion provided by the studies. The body of evidence for a particular outcome was also considered imprecise if the results were inconsistent or sample size across trials was considered insufficient. If judgement could not be made on those factors, optimal information size (OIS) was calculated to determine sufficiency of sample size.

We classified the strength of evidence into four basic categories: 1) “high” grade (indicating high confidence that the evidence reflects the true effect, and further research is very unlikely to change our confidence in the estimate of the effect); 2) “moderate” grade (indicating moderate confidence that the evidence reflects the true effect, and further research may change our confidence in the estimate of the effect and may change the estimate); 3) “low” grade (indicating low confidence that the evidence reflects the true effect, and further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate); and 4) “insufficient” grade (evidence is unavailable or does not permit a conclusion). A comparison-outcome pair with high strength of evidence was one with low risk of bias, directness, consistency, and precision. Moderate strength of evidence indicated a high risk of bias was noted or that two of the following were observed: a moderate risk of bias, inconsistency, indirectness or imprecision. Low strength of evidence indicated two or more of the following: a moderate risk of bias, a high risk of bias, inconsistency, indirectness and imprecision. Our judgments were first based on the ability to make a conclusion (if not able to make a conclusion, then “insufficient” was assigned) and then on the confidence in the conclusion (classified as low, moderate or high with increasing certainty). We considered any study that calculated LDL-c as indirect, as the option to measure LDL-c directly does exist and new evidence exists that the Friedewald equation tends to underestimate LDL-c among high-risk patients.64

Investigators writing each section completed the strength of evidence grading. The team members reviewed and discussed grading throughout the report writing.

## Applicability

Applicability was assessed separately for the different outcomes for the entire body of evidence guided by the PICOS framework as recommended in the Methods Guide.65 We considered important population characteristics (e.g., women, minorities, diabetics), treatment characteristics (e.g., statin type, statin potency, length of intervention/therapy, dose escalation), and timing that may cause heterogeneity of treatment effects and limit applicability of the findings.

## Peer Review and Public Comment

A full draft report was reviewed by experts and posted for public commentary from August 5, 2013, through September 3, 2013. Comments received from either invited reviewers or through the public comment website were compiled and addressed. A disposition of comments will be posted on the Effective Healthcare Program Web site 3 months after the release of the evidence report.