# Introduction

## Cardiovascular Disease (CVD)

Cardiovascular disease (CVD) includes conditions such as coronary heart disease, stroke, heart failure, arrhythmia, heart valve disease, congenital heart disease, and hypertension. The American Heart Association (AHA) has estimated that CVD affects 83.6 million individuals, contributes to 32.3 percent of deaths, and CVD is a leading cause of disability.1 CVD prevalence has been projected to rise in the future, with over 40 percent of the U.S. population having CVD by 2030.^2^ In addition, the total direct medical costs attributable to CVD are expected to increase from $273 billion in 2010 to $818 billion by 2030.^3^

While CVD is the leading cause of death for men and women, some gender differences exist. The CVD death rate for U.S. women is estimated as 123.7 per 100,000 women, while for U.S. men the estimated CVD death rate is 249.8 per 100,000 men.1 In addition, there are differences in rates of CVD by race/ethnicity. Recently, the Centers for Disease Control examined differences in self-reported CVD by race/ethnicity. They found that Native American and black men self-reported higher proportions of CVD (13.4% and 9.4%, respectively) as compared to the median percentage of men with CVD among the locations surveyed (8.8%), while Hispanic and Asian men had lower percentages (7.7% and 6.6%, respectively).4 A similar trend was seen for women; the median percentage of women with CVD was 6.3 percent, while 12.4 percent of Native American women, 10.3 percent of black women, 5.7 percent of Hispanic women, and 4.4 percent of Asian women reported having CVD.4

## Atherosclerotic CVD and Lipids

Atherosclerosis plays a major role in the development of atherosclerotic CVD, which is a subset of CVD that includes coronary heart disease (CHD), cerebrovascular disease, and peripheral artery disease. The American Heart Association estimates that atherosclerotic CVD affects 15.4 million Americans.1 CHD, which includes coronary artery disease (CAD), myocardial infarction (MI), unstable angina (UA), and heart failure, is a leading cause of death for both men and women in the U.S.5 By 2030, the prevalence of CHD will rise by 16.6 percent and result in over $106 billion in direct healthcare costs.3

### Role of LDL in Atherosclerotic CVD

Abnormal lipoprotein metabolism predisposes individuals to atherosclerosis, especially increased concentrations of apo B-100-containing low-density lipoprotein (LDL-c). Oxidized LDL-c is atherogenic, causing endothelial damage, alteration of vascular tone, and recruitment of monocytes and macrophages.6 Many studies have underscored the importance of LDL-c in development of atherosclerotic CVD.7,8 Due to the consistent and robust association of higher LDL-c levels with atherosclerotic CVD across experimental and epidemiologic studies, therapeutic strategies to decrease risk have focused on LDL-c reduction as a primary goal. While the prevalence of elevated LDL-c levels among adults has decreased by 33 percent from 1999 to 2006, the most recent estimates still report that 28 percent of U.S. adults have elevated LDL-c.1

### Role of Other Lipoproteins in Atherosclerotic CVD

In contrast to LDL-c, high-density lipoprotein (HDL-c) has been associated with reduced risk of atherosclerotic CVD. HDL-c may inhibit LDL-c oxidation through various enzymes, as well as reverse cholesterol transport.6 These enzymes stop the formation of or destroy the atherogenic, oxidized LDL-c, thereby preventing the inflammatory reaction that results in endothelial damage and plaque formation. Epidemiologic studies have demonstrated an inverse association between HDL-c and CVD. Low HDL-c levels are independent predictors of CHD9,10 and have been associated with increased CVD risk among patients without vascular disease at baseline.11 However, only the VA-HIT study showed clinical benefit of raising HDL-c among men with low baseline HDL-c.12

## Evidence for Lipid-Modifying Therapy

Lipid-modifying medications include 3-hydroxy-3-methylglutaryl coenzyme A (HMG-CoA) reductase inhibitors, bile acid sequestrants, cholesterol absorption inhibitor, fibric acids, nicotinic acid, and omega-3 fatty acids, which have various mechanisms of action and pharmacokinetic properties. Table 1 provides an overview of the expected lipid effects of these agents based on mechanism of action and reported effects in clinical trials.

Table 1 Lipid modifying agents and their expected lipid effects

Agent | LDL | HDL
HMG-CoA Reductase Inhibitors | Decrease | Increase
Bile Acid Sequestrants^a^ | Decrease | None
Cholesterol Absorption Inhibitor | Decrease | None
Fibric Acids | Variable | Increase
Nicotinic Acid | Decrease | Increase
Omega-3 Fatty Acids | Variable | None

a Contraindicated in patients with triglycerides more than 300 mg/dl.

### Mechanism of Action of HMG-CoA Reductase Inhibitors

The most widely prescribed lipid-lowering agents are the HMG-CoA reductase inhibitors or “statins.” These agents inhibit the enzyme, HMG-CoA reductase, which is the catalyst for the rate-limiting step in cholesterol synthesis throughout the body.13 As a result, the lower intracellular cholesterol concentration triggers increased expression of hepatic LDL receptors, which then enhances the clearance of LDL-c from the plasma.14 Statins may also inhibit hepatic synthesis of apolipoprotein B-100, as well as decrease the synthesis and secretion of other lipoproteins.15,16 Studies have demonstrated that statins result in significant reductions in LDL-c, and modest increases in HDL-c.17,18A recent meta-analysis of trials targeting LDL-c reduction with statins found that reducing LDL-c by 39 mg/dL resulted in reductions in the annual incidence of MI, revascularization, and ischemic stroke by one fifth.19 The effect size for improvement in these outcomes increases after the third year of therapy (RR of major vascular event per 1 mmol/L reduction in LDL−C 0.72 at Year 3)19 Efficacy and safety of more intensive lowering of LDL cholesterol: a meta-analysis of data from 170,000 participants in 26 randomised trials.19 Statins may also contribute to regression of atherosclerosis,20 stabilize plaque,21 decrease inflammation,22 and reduce endothelial dysfunction.23 Statins have shown clear benefits in overall mortality and in primary and secondary prevention of CHD. In patients without CHD, statins have decreased nonfatal myocardial infarctions,24 incidence of a first major coronary event,25,26 and all-cause mortality.27 In patients with known CHD or CHD risk equivalents (e.g., diabetes), statins reduce major coronary events, cardiovascular mortality, and all-cause mortality.28,29 Another meta-analysis found that statin use reduced all-cause mortality by 17 percent, reduced fatal and non-fatal CVD endpoints by 30 percent, and reduced the revascularization rates by 34 percent.30 There are 7 statins currently approved by the FDA: atorvastatin, fluvastatin, lovastatin, pitavastatin, pravastatin, rosuvastatin, and simvastatin. There have been concerns regarding adverse effects of intensive statin therapy. For example, intensive statin therapy has been associated with an increased risk of diabetes compared to moderate statin therapy.31 Rhabdomyolysis is a rare but dangerous complication of statin with higher risk at higher statin doses.32,33

### Mechanism of Action of Bile Acid Sequestrants

Bile acid sequestrants (BAS) bind bile acids in the bowel, which prevents them from being reabsorbed the intestine and effectively interrupts their enterohepatic circulation.34 As a result, the liver increases its synthesis of cholesterol and uptake of circulating LDL-c to produce more of these bile acids. This process ultimately results in the lowering of circulating LDL-c. BAS have no effects on HDL. There are 3 BAS currently approved by the FDA: cholestyramine, colesevelam, and colestipol.

### Mechanism of Action of Cholesterol Absorption Inhibitor

Cholesterol absorption inhibitor blocks the Niemann-Pick C1-like protein (NPC1L1) in the small intestine, which thereby prevents the uptake of cholesterol from the gut. Ultimately, this process leads to relative depletion of cholesterol in the liver, which responds by increasing cholesterol synthesis and uptake of circulating LDL-c.35,36 This process ultimately results in the lowering of circulating LDL-c. Cholesterol absorption inhibitor has no effects on HDL-c.37,38 Currently, there is one FDA approved cholesterol absorption inhibitor, ezetimibe.

### Mechanism of Action of Fibric Acids

Fibric acids or “fibrates” may modulate lipoprotein levels through a variety of mechanisms including induction of lipoprotein lipolysis, induction of fatty acid uptake, reduction of hepatic triglyceride production, increased removal of LDL-c particles, and increased production of HDL-c.39 Typically, fibrates will result in a mild decrease in LDL-c, mild increase in HDL-c, and significantly reduce triglycerides. There are 3 fibrates currently approved by the FDA: fenofibrate, fenofibric acid, and gemfibrozil.

### Mechanism of Action of Nicotinic Acid

Nicotinic acid or “niacin” inhibits the synthesis of LDL-c, as well as delays clearance of circulating HDL-c.40 Typically, niacin moderately decreases LDL-c and moderately increases HDL-c.41,42 Niacin has demonstrated modest benefit in decreasing nonfatal recurrent MI, but has not lead to decreases in mortality.43 Niacin is the only nicotinic acid currently approved by the FDA, and comes in three forms: immediate/regular release (Niacor®): sustained/controlled release (over-the-counter formulations) and extended release (Niaspan®). Adverse effects such as flushing may vary with these forms.

### Mechanism of Action of Omega-3 Fatty Acids

Dietary consumption of marine-sourced omega-3 fatty acids has been linked with positive cardiovascular benefits for many years. Available prescription omega-3 fatty acids contain eicosapentaenoic acid (EPA) with/without docosahexaenoic acid (DHA). While the mechanism of omega-3 fatty acids is not fully understood, they have been hypothesized to inhibit acyl CoA:1,2 diacylglycerol acyltransferase, increase hepatic beta-oxidation, reduce the hepatic synthesis of triglycerides, or increase plasma lipoprotein lipase activity. Typically, omega-3 fatty acids lead to decreases in triglycerides and potentially increase large particle LDL-c, which may be less atherogenic.44 These medications were linked with reduced risk of death, nonfatal MI and nonfatal stroke in early research;45 however, more recent studies have not shown a reduction in CVD outcomes with omega-3 fatty acid therapy.46 There are currently 2 omega-3 fatty acids approved by the FDA: omega-3 acid ethyl ester and icosapent ethyl.

## Current Guidelines and Controversies for Lipid-Modifying Therapy

Until recently, lipid therapy focused on attaining different presepcified cholesterol targets based upon pateints CVD risk. The National Cholesterol Education Program (NCEP) Adult Treatment Panel (ATP) III provided guidelines on both when to initiate lipid-lowering therapy based on LDL-c level and CHD risk factors and recommended LDL-c targets for optimal CHD risk reduction.2 Clinicians could use statin monotherapy or combination therapy with statin and another agent to achieve these LDL-c goals. There are potential benefits to treating with multiple agents, as the different mechanisms of action of the other lipid-modifying agents may produce other benefits unlikely to be achieved with statin alone. For example, a fibrate or niacin in combination with a statin may increase HDL-c and decrease triglycerides above what is achieved with statin treatment alone.47 Conversely, a combination of agents could result in an increase in side effects, as patients may experience the side effects common to both drugs. Individual agents may have benefits on non-lipid outcomces in particular groups. For example, colesevelam HCl, one of the bile acid sequestrants, has been shown to lower HbA1c when used in diabetic patients on oral agents or insulin.48

Despite the generally favorable effects of combination regimens on surrogate lipid markers in clinical trials, combination regimens have not consistently been shown to improve clinical outcomes.47,47,49,50 In the ACCORD trial, the addition of fenofibrate to simvastatin did not reduce the rates of cardiovascular deaths, MI or stroke more than same-dose simvastatin monotherapy among patients with diabetes.51 In addition, this combination therapy conferred possible benefit for men and possible harms for women. In the AIM-HIGH trial, patients with preexisting atherosclerotic CVD received niacin in addition to simvastatin or simvastatin monotherapy.47 While the patients taking combination therapy had greater increases in their HDL-c, there were no benefits on incidence of cardiovascular death, MI, stroke, or revascularization procedures. The ENHANCE compared the effect of ezetimibe in addition simvastatin to simvastatin alone on carotid intima-media thickness (CIMT) in patients with hyperlipidemia. There was no difference in CIMT changes between the two groups despite significantly lower LDL-c levels in the combination therapy group. However, the subsequent ARBITER-6 HALTS study comparing statin+niacin with statin+ezetimibe revealed lower incidence of major cardiovascular events with statin+niacin than with statin+ezetimibe.50 Interestingly, the CVD benefits with combination therapy with niacin seen in ARBITER-6 HALTS was not replicated in AIM-HIGH, as the trial showed no reduction in CVD outcomes from adding niacin to a statin.47 Based on the combination of findings from these trials, investigators have suggested that ezetimibe either has no effect on or possibly worsens CVD outcomes as a possible theory to explain these discrepancies.50 The ongoing IMPROVE-IT trial will compare ezetimibe added to simvastatin to simvastatin monotherapy on cardiovascular death, MI, revascularization, or stroke (completion expected in September 2014) may help clarify the picture.52 Overall, these trials comparing statin monotherapy to combination therapy with the same statin dose plus another lipid lowering drug have demonstrated that this “add on” combination therapy can lead to superior lipid outcomes, but fails to reduce atherosclerosis or lead to decreased rates of cardiovascular death, MI, revascularization, or stroke.53

These studies call into question previous assumptions that lowering LDL-c or raising HDL-c are always reliable predictors of improved clinical outcomes. The ACCF, AHA, American College of Physicians, and others have advocated for the approach of prescribing at least a moderate dose statin to all patients with ischemic coronary heart disease, regardless of LDL-c value.54 New ACC/AHA lipid management guidelines released in November 2013 reflect this approach. No specific LDL-c targets (e.g. LDL-c ≤ 70 mg/dL) were presented in the new guidelines given the lack of RCT evidence supporting specific targets. Rather, four “statin benefit groups” were identified: individuals with clinical atherosclerotic CVD, individuals with LDL-c ≥ 190 mg/dL, diabetics aged 40-75, and individuals aged 40-75 with a ≥ 7.5% 10-year atherosclerotic CVD risk. Individuals in one of these groups are recommended for treatment with moderate- or high-potency statin monotherapy. The expected response to a moderate-potency statin is an LDL-c reduction of 30-50%, while the expected response to a high-potency statin is an LDL-c reduction of ≥ 50%. For individuals who do not have an expected response, once adherence has been assessed, the guidelines recommend considering intensification of statin therapy if the patient is not at maximum dose or the addition of a non-statin agent with proven efficacy in reducing CVD events. In addition, combination therapy can be considered in patients who cannot tolerate a high or moderate potency statin. These guidelines represent a significant change from the ATP III, which has generated considerable discussion around the calculation of CVD risk, lack of cholesterol treatment targets, and reliance on RCT data only.

## 2013 Update of the Comparative Effectiveness Review: Overview

In 2009, the Agency for Healthcare Research and Quality (AHRQ) released an evidence report examining lipid-modifying agents.55,56 This prior review initially intended to examine the long-term benefits and rates of serious adverse effects of co-administration of different lipid-lowering agents vs. higher dose statin monotherapy for patients at high CHD risk (ten-year risk > 20%). However, the authors found a paucity of evidence to address this question, so conducted additional analyses unrestricted by patient risk, statin type or statin dose. Despite this increase in scope, the authors concluded that there was insufficient evidence to determine whether combination therapy held benefit over monotherapy. Since the initial review, additional trials on efficacy and safety outcomes have been published. The evidence base for all three key questions has been expanded, which led to the decision to update the prior review.

To provide additional guidance to clinicians treating patients with moderate or high CHD risk, this update review addresses long-term benefits and rates of serious adverse events (SAEs) associated with co-administration of different lipid-modifying agents compared with higher potency statin monotherapy. We included studies examining patients at moderate and high CHD risk, defined as a 10-year CHD risk greater than 10 percent or LDL-c greater than 160 mg/dL, as these patients may require intensive lipid modifying therapy to achieve their LDL-c goals. Studies focusing on lower risk patients with a 10-year CHD risk less than 10 percent were excluded, as these patients are likely to achieve their LDL-c goal with typical statin monotherapy. This update review additionally examines surrogate markers of CHD events including lipid levels and atherosclerosis, as well as side effects/tolerability and medication adherence. Similar to the prior review, we sought to evaluate clinical/surrogate benefits and harms among the following subgroups: females, patients older than 75, diabetics, patients with established vascular disease, and participants of African and Asian descent as well as Hispanics. The choice of subgroups reflects populations in whom the risk of adverse effects, CVD risk, and need for intensive lipid-lowering therapy differs as compared with the general population.

## Scope and Key Questions

We aimed to assess the effectiveness, safety, and tolerability of combination of statin and other lipid-modifying medication to intensification of statin monotherapy. Our scope was limited to comparing combination of statin with other lipid-modifying medication to intensification of statin monotherapy as proposed in the key questions. This review will address the important question of whether there is benefit to adding another lipid-modifying agent to lower potency statin compared with higher potency statin monotherapy, which may be particularly relevant for patients who cannot tolerate high-dose statin therapy, yet desire to achieve their LDL-c goals.

Of note, the review does not address other clinical questions. For example, another important question is whether adding on another lipid-modifying agent to the same potency statin therapy will improve clinical outcomes (“add-on” combination therapy). Many of the high-profile studies including ACCORD, AIM-HIGH, HSP-2 THRIVE, and ENHANCE have evaluated add-on combination therapy, and are not included in this review. Another reason for not expanding the scope to evaluate add-on combination therapy was the upcoming release of the results from the IMPROVE-IT trial that will be critical in characterizing the effect of add-on combination therapy with ezetimibe+statin on important clinical outcomes. Several trials have shown that non-statin monotherapy may not improve clinical outcomes; however, we did not include non-statin monotherapy as a comparison group because it was outside the scope of this update. We sought to answer the questions below by reviewing trials of adults that compared a higher potency of statin monotherapy to a lower potency statin in combination with another agent (bile acid sequestrant, ezetimibe, fibrate, niacin, or omega-3 fatty acid).

The analytic framework for the review is shown in Figure 1.

Figure 1 Analytic framework for comparative effectiveness of lipid-modifying agents

CVD = cardiovascular disease; DM = diabetes mellitus; HDL = high-density lipoprotein; KQ = Key Question; LDL = low-density lipoprotein

Figure 1 is our analytic framework, presenting the Key Questions (KQ) in terms of: 1) the populations (Patients with moderate or greater high risk of cardiovascular disease ); 2) the interventions (dual-agent therapy vs. intensification of statin therapy; 3) the clinical outcomes (Mortality, Coronary heart disease, Cerebrovascular disease, Revascularization procedure, Sever adverse effects); 4) Surrogate clinical outcomes (LDL goals, HDL goals, Triglyceride goals, Atherosclerosis, Adherence); 5)Adherence and Harms (Adverse events, Cancer, Hepatitis, Myositis, Diabetes mellitus)

The specific Key Questions (KQ) are:

KQ 1: | For patients who require intensive lipid-modifying therapy, what are the comparative long-term benefits and rates of serious adverse events of co-administration of different lipid-modifying agents (i.e., a statin plus another lipid-modifying agent) compared with higher dose statin monotherapy?
KQ 2: | Do these regimens differ in reaching LDL targets (or other surrogate markers), short-term side effects, tolerability, and/or adherence?
KQ 3: | Compared with higher dose statins and to one another, do combination regimens differ in benefits and harms within subgroups of patients?