# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Elliott Marshall Antman, M.D.
  Brigham and Women's Hospital, Harvard Medical School
  Boston, MA
- Courtney Jordan Baechler, M.D., M.S.
  Penny George Institute for Health and Healing
  Minneapolis, MN
- Iffat N. Chowdhury, M.D.
  U.S. Food and Drug Administration
  Silver Spring, MD
- John Wilson Epling, Jr., M.D., FAAFP
  State University of New York, Upstate Medical University
  Syracuse, NY
- Antonio M. Gotto, Jr., M.D., D.Phil., FACC
  Weill Medical College, Cornell University
  New York, NY
- Lewis Kuller, M.D., Dr.P.H.
  University of Pittsburgh Graduate School of Public Health
  Pittsburgh, PA
- Neil J. Stone, M.D, MACP, FAHA, FACC
  Feinberg School of Medicine, Northwestern University
  Chicago, IL