# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Iffat N. Chowdhury, M.D.
  U.S. Food and Drug Administration
  Silver Spring, MD
- John Wilson Epling, Jr., M.D., FAAFP
  State University of New York, Upstate Medical University
  Syracuse, NY
- Antonio M. Gotto, Jr., M.D., D.Phil., FACC
  Weill Medical College, Cornell University
  New York, NY
- James Howard, M.D., MACP
  MedStar Washington Hospital Center
  Washington, DC
- Neil J. Stone, M.D, MACP, FAHA, FACC
  Feinberg School of Medicine, Northwestern University
  Chicago, IL
- Karol E. Watson, M.D., Ph.D., FACC
  Geffen School of Medicine
  University of California, Los Angeles
  Los Angeles, CA