# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Elisabeth U. Kato. We would like to thank Edgar R. Miller for his thoughtful feedback and Sonal Singh for his input regarding the meta-analysis. We also express our gratitude to the following individuals for their contributions to this project: Oluwakemi Fawole, Shauna Linn, and Brian G. Ockerse.

We extend our appreciation to the members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our process.