# Discussion

## Key Findings and Implications

The evidence suggests that some combination therapy regimens may confer benefits with respect to lowering LDL-c including bile acid sequestrants (up to 14 percent greater LDL-c reduction) and ezetimibe (up to 21 percent greater LDL-c reduction). LDL-c is an important factor in the development of atherosclerotic cardiovascular disease and higher levels of LDL-c have been associated with greater risk of this disease.7,8 However, there is insufficient evidence to address whether these LDL-c lowering benefits achieved with these medications translate into decreased rates of atherosclerotic cardiovascular disease. Prior trials comparing combination regimens to statin monotherapy such as ENHANCE, AIM-HIGH, and ACCORD-lipid have demonstrated that combination therapy can lead to superior lipid outcomes, but fail to reduce clinical outcomes such as cardiovascular death, MI, revascularization, or stroke.47 ,51 ,53

We also found that some combination therapy regimens may confer benefts with respect to raising HDL-c including ezetimibe and niacin (up to 6 percent and up to 27 percent, respectively). In particular, given that only one prior study has demonstrated benefit of pharmacologically raising HDL-c with respect to prevention of CVD events, the potential long-term clinical benefits of these combination regimens with respect to their HDL-c effects is unclear.12

The strength of evidence for all observed comparisons in general populations is provided in Table 26 and in subgroups in Table 27. Most trials included in this report were of relatively short duration (<3 months). In this limited timeframe, investigators are unlikely to capture any changes in a chronic condition like atherosclerotic cardiovascular disease, which typically develops and progresses over a number of years. Powering such studies is especially difficult, given that both arms are taking statins which would reduce the baseline incidence of cardiovascular events. Therefore currently it is not possible to draw conclusions about the clinical implications of the surrogate marker changes identified. However, until additional data are available, these results may help healthcare providers tailor lipid-modifying regimens based on individual patient needs and concerns for adverse events.129

Table 26 Summary of the strength of evidence for [underlined: general populations]

Therapy | Potency Comparison (combination therapy vs. monotherapy) | Clinical Events | | | Serious Adverse Events | Surrogate Markers
Therapy | Potency Comparison (combination therapy vs. monotherapy) | Mortality | Acute Coronary Events | Revascularization Procedures | Serious Adverse Events | LDL-c | HDL-c
Bile Acid Sequestrant | Low potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Bile Acid Sequestrant | Mid potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Bile Acid Sequestrant | Low potency combination therapy vs mid potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | MODERATE Combination therapy favored with 0-14% greater LDL reduction | Insufficient
Ezetimibe | Low potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | LOW Combination therapy favored with 2 to 12% greater LDL reduction | LOW Combination therapy favored with up to 5 to 6% greater increase in HDL
Ezetimibe | Mid potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | MODERATE Combination therapy favored with 3 to 14% greater LDL reduction | LOW Combination therapy favored with 2 to 6% greater increase in HDL
Ezetimibe | Low potency combination therapy vs mid potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | MODERATE Combination therapy favored with 3 to 11% greater LDL reduction | LOW Combination therapy favored with 3 to 4% greater increase in HDL
Fibrates | Low potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Fibrates | Mid potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Fibrates | Low potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Niacin | Low potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Niacin | Mid potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Niacin | Low potency combination therapy vs mid potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | MODERATE Combination therapy favored with 15-27% greater increase in HDL
Omega-3 Fatty Acid | Low potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Omega-3 Fatty Acid | Mid potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Omega-3 Fatty Acid | Low potency combination therapy vs mid potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient

HDL = high-density lipoprotein; LDL = low-density lipoprotein

Note: Comparisons for which there was evidence are shown in bold.

Table 27 Summary of the strength of evidence for [underlined: subgroups]

Subgroup | Combination Agent | Potency Comparison (combination therapy vs. monotherapy) | Clinical Events | | | Serious Adverse Events | Surrogate Markers
Subgroup | Combination Agent | Potency Comparison (combination therapy vs. monotherapy) | Mortality | Acute Coronary Events | Revascularization Procedures | Serious Adverse Events | LDL-c | HDL-c
Preexisting CHD | Ezetimibe | Low potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Preexisting CHD | Ezetimibe | Mid potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | MODERATE Combination therapy favored with 5 to 15% greater LDL reduction | LOW No between group difference in raising HDL
Preexisting CHD | Ezetimibe | Low potency combination therapy vs mid potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Preexisting CHD | Fibrates | Mid potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diabetes | Ezetimibe | Low potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diabetes | Ezetimibe | Mid potency combination therapy vs high potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | MODERATE Combination therapy favored with 3 to 21% greater LDL reduction | MODERATE Combination therapy favored with 2 to 6% greater increase in HDL
Diabetes | Ezetimibe | Low potency combination therapy vs mid potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Diabetes | Fibrates | Low potency combination therapy vs mid potency monotherapy | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient

CHD = coronary heart disease; LDL = low-density lipoprotein

Note: Comparisons for which there was evidence are shown in bold.

## Evidence

### Combination Therapy With Bile Acid Sequestrant and Statin Compared to Intensification of Statin Monotherapy

Six randomized trials (410 participants) were identified. There is insufficient evidence to compare the benefits of combined lipid-modifying therapy with a bile acid sequestrant and statin to intensification of statin monotherapy on long-term clinical outcomes or harms, regardless of statin potency.

The results from four trials comparing low potency statin in combination with a bile acid sequestrant to mid potency statin monotherapy (288 participants) suggest that this combination lowers LDL-c up to 14 percent more than mid potency statin monotherapy (SOE: moderate). Evidence for other potency comparisons and outcomes was insufficient.

### Combination Therapy With Ezetimibe and Statin Compared to Intensification of Statin Monotherapy

Forty randomized trials (10,955 participants) were identified. Evidence for all clinical outcomes was insufficient, but there was some evidence that combination therapy may have impact on LDL-c and HDL-c. Results from 13 trials suggest that low potency statin in combination with ezetimibe more effectively lowers LDL-c and raises HDL-c as compared to high potency statin monotherapy among general populations (SOE: low for both). Results from 11 trials suggest that mid potency statin combined with ezetimibe more effectively lowers LDL-c and raises HDL-c as compared to high potency statin monotherapyamong general populations (SOE: moderate and low, respectively). Finally, results from six trials suggest that low potency statin in combination with ezetimibe more effectively lowers LDL-c and raises HDL-c as compared to mid potency statin monotherapy (SOE: moderate and low, respectively).

We also identified data on surrogate markers in special populations. Twleve trials among patients with preexisting coronary heart disease favored mid potency statin in combination with ezetimibe for lowering LDL-c as compared to high potency statin monotherapy (SOE: moderate). Four trials among patients with diabetes mellitus also favored mid potency statin plus ezetimbe to a high potency statin monotherapy for lowering LDL-c and raising HDL-c (SOE: moderate for both). Unfortunately, there was insufficient evidence to evaluate harms among the coronary heart disease and diabetes subgroups.

### Combination Therapy With Fibrate and Statin Compared to Intensification of Statin Monotherapy

No trials evaluated the benefits of combined lipid-modifying therapy with fibrate and statin to intensification of statin monotherapy on long-term clinical outcomes or serious adverse events, regardless of statin potency. Four randomized trials (1341 participants) assessed surrogate lipid outcomes among different potency comparisons, but provided insufficient evidence to draw conclusions.

### Combination Therapy With Niacin and Statin Compared to Intensification of Statin Monotherapy

Five randomized trials (612 participants) were identified. There is insufficient evidence to compare the benefits of combined lipid-modifying therapy with niacin and statin to intensification of statin monotherapy, regardless of statin potency, on long-term clinical outcomes or adverse events, because these endpoints were not reported or the event rates were too low.

Three trials (247 participants) provide insufficient evidence regarding LDL-c,but moderate evidence that combination therapy with niacin and low potency statin raises HDL-c up to 27 percent more than mid potency statin monotherapy (SOE: moderate).

### Combination Therapy With Omega-3 Fatty Acid and Statin Compared to Intensification of Statin Monotherapy

No trials were identified that compared a combination of Omega-3 fatty acid with statin to intensification of statin monotherapy; therefore, the strength of evidence is insufficient for all outcomes.

## Important Unanswered Questions

### Which of the Key Questions Remain Unanswered?

We sought to identify evidence assessing the long-term benefits and serious harms between combination therapy and intensification of statin monotherapy. Unfortunately, we identified only a few studies that reported mortality and serious adverse events with ezetimibe combined with statin as compared to higher potency statin monotherapy. These trials all lasted less than 12 weeks and very few events were reported. We found very limited evidence regarding these long-term benefits and serious harms among other combination therapy comparisons (bile acid sequestrants, fibrates, niacin, and omega-3 fatty acids). Overall, we are unable to conclude whether there are any long-term advantages or serious disadvantages to combination therapy with any agent as compared to intensification of statin monotherapy.

Few studies specifically evaluated high-risk subgroups of interest, which included patients with prior cardiovascular disease or patients with diabetes mellitus. Only comparisons of mid potency statin in combination with ezetimibe to high potency statin monotherapy had sufficient number of trials for evaluation. Among these trials, the strength of evidence is moderate in favor of combination therapy with ezetimibe for lowering LDL-c as compared to statin monotherapy, although we found insufficient evidence with respect to long-term clinical outcomes. Providers could consider combination therapy with ezetimibe as an alternative in diabetic patients who cannot tolerate high or moderate dose statin monotherapy, as recommended by the 2013 cholesterol treatment guidelines.130 Given that these guidelines have prioritized patient subgroups including those with preexisting atherosclerotic CVD or diabetes aged 40-75, future studies should consider comparing combination therapy (bile acid sequestrants, fibrates, niacin, omega-3 fatty acids) to intensification of statin monotherapy in these high-risk populations.

Very few studies included only elderly individuals (age>75), females, blacks, Asians or Hispanics. No studies included only Native Americans. Given the cardiovascular disease disparities identified among Black and Native American populations,4 future studies should consider targeting these populations comparing combination therapy to intensification of statin monotherapy as these populations may be more likely to require an aggressive lipid-modifying regimen.

### Add-On Combination Lipid-Modifying Therapy Versus Statin Monotherapy

A related question, which this review does not address, is whether adding on another lipid-modifying agent to same the potency statin therapy improves clinical outcomes. Since 2008, several large studies (ACCORD, AIM-HIGH, HSP-2 THRIVE, ENHANCE) have examined this question. The ACCORD trial was designed to detect differences in non-fatal MI, non-fatal stroke, and CVD death among patients treated with statin alone vs. statin with fenofibrate, and found no reduction in events with combination therapy.51 Similarly, AIM-HIGH compared CHD death, non-fatal MI, ischemic stroke, hospitalization for ACS, and symptom-driven revascularization among patients treated with statin (+/- ezetimibe) vs. statin (+/- ezetimibe) with niacin.47 Again, there was no additional benefit of adding niacin therapy to the background regimen. HSP2-THRIVE, which tested statin alone vs. statin with niacin/laropiprant was stopped early due to increased side effects with niacin/laropiprant. There was no reduction in MI, stroke, or revascularization with combination therapy.131 A study of the effect of statin vs. statin + ezetimibe on carotid intima media thickness showed no difference between the treatment groups.53 The IMPROVE-IT trial, which has enrolled over 18,000 patients and is expected to be completed in September 2014, will examine the effect of statin vs. statin + ezetimibe on CVD events.52 ,132 The results of IMPROVE-IT may provide the definitive evidence clinicians seek regarding the clinical effects of ezetimibe. As soon as the results from IMPROVE-IT are released, a new systematic review would be warranted that specificially addresses the question of whether add-on combination therapy or statin monotherapy leads to improved clinical outcomes (Table 28).

Table 28 Summary of trials

Trial, Year | Population | Intervention | Clinical Outcomes | Surrogate Outcomes | Adverse Events
ACCORD, 2010^51^ | Type 2 DM +/- CVD | Fenofibrate + simvastatin 20-40 mg/d vs. simvastatin 20-40 mg/d | Primary outcome: Major CVD events, non fatal MI, non fatal stroke, CVD death Secondary outcome: Death from any cause, fatal or non fatal congestive heart failure | Total cholesterol, LDL, HDL, TG, | CK elevation, muscle symptoms
AIM-HIGH, 2011^47^ | CVD (34% diabetics) | Niacin + simvastatin 40-80 mg/d (+/- EZE 10 mg if needed) vs. simvastatin 40-80 mg/d (+/- EZE 10 mg if needed) | Primary outcome: Coronary heart disease death Nonfatal myocardial infarction Ischemic stroke Hospitalization for acute coronary syndrome Symptom-driven coronary or cerebral revascularization | LDL, HDL | Adherence, elevated LFL, Myalgia, rhabdomyolysis
ENHANCE, 2008^53^ | familial hypercholesterolemia | EZE 10 mg +Simvastatin 80 mg Vs. Simvastatin 80 mg | Primary outcomes: carotid-artery intima–media thickness Secondary outcomes: Regression in the mean carotid-artery intima–media thickness, new plaque formation, , mean maximum carotid artery intima-media thickness, mean measures of intima-media thickness of common carotid, carotid bulb, internal carotid artery and femoral artery | LDL, TG, HDL, total cholesterol | Withdrawal due to adverse events, , elevated LFT, CK,
HPS2-THRIVE, 2013^131^ | pre-existing occlusive arterial disease | ER niacin/ laropiprant + simvastatin 40 mg/d (+/- EZE 10 mg if needed) Vs. simvastatin 40 mg/d (+/- EZE 10 mg if needed) | Primary outcomes: major vascular event' (MVE: a composite of non-fatal MI, coronary death, stroke, or arterial revascularization)- Secondary outcome: serious adverse events | LDL, HDL, TGs | elevated LFT, CK, adherence
IMPROVE-IT (results not published yet) | stabilized high-risk acute coronary syndrome (ACS) | Ezetimibe/ Simvastatin combination (10/40) vs. Simvastatin 40 mg | Primary outcomes: CVD death, non fatal coronary events, unstable angina non fatal stroke, PCI or CABG, angina Secondary outcomes: death due to any cause, | Target LDL, | elevated LFT, CK,

CABG = coronary artery bypass graft; CK = creatinine kinase; CVD = cardiovascular disease; DM = diabetes mellitus; EZE = ezetimibe; HDL = high-density lipoprotein; LDL = low-density lipoprotein; LFT = liver function tests; PCI = percutaneous coronary intervention; TG = triglycerides

For the reader's reference, we have summarized systematic reviews on combination therapy versus same dose/potency statin that reported on long-term clinical outcomes and/or harms such as serious adverse events or other short-term harms (Table 29).

Table 29 Systematic reviews on combination therapy versus same dose/potency statin

Author, Year | Population | Intervention | Clinical Outcomes | Surrogate Outcomes | Adverse Events
Guo et al, 2012^133^ | Combined hyperlipidemia | Statin monotherapy vs. statin (same dose) + fenofibrate | Serious adverse events | NR | Withdrawal due to adverse events, any adverse event, AST/ALT>3×ULN, CK>5×ULN
Abramson et al, 2011^134^ | Hypercholesterolemia Subgroup: males, females | Statin monotherapy vs. statin + EZE (some studies have same dose statin, others have doubling in monotherapy) | Mortality, serious AE | LDL, non-HDL-c, TGs, HDL | any adverse event, AST/ALT>3×ULN, CK>5×uln, rhabdomyolysis
Mikhailidis et al, 2011^135^ | Hypercholesterolemia | Statin monotherapy vs. statin + EZE (some studies have same dose statin, others have doubling in monotherapy) | NR | LDL, non-HDL-c, HDL, LDL target, TC to HDL ratio, | Withdrawal due to AE
Sharma et al, 2009^55^ | Dyslipidemia | Statin monotherapy (high dose) Vs. combination (low dose statin) | Mortality, vascular death, serious AE, Cancer | LDL target, LDL, HDL, carotid intima media thickness | Treatment adherence and harm.
Kashani et al, 2008^136^ | Hyperlipidemia | Statin monotherapy vs. statin + EZE (some studies have same dose statin, others have doubling in monotherapy) | NR | LDL, HDL, TGs | Myalgia, CK, AST/ALT elevations, rhabdomyolysis, Discontinuations due to adverse events
Mikhailidis et al, 2007^137^ | Hypercholesterolemia, Subgroup: CHD | Statin monotherapy vs. statin (same dose) + EZE | NR | LDL, non-HDL-c, HDL, TG | CK, AST/ALT elevations

AE = Adverse events; AST = aspartate transaminase; ALT = alanine transaminase; CK = creatinine kinase; CHD = cardiovascular heat disease; DM EZE = ezetimibe; HDL = high-density lipoprotein; LDL = low-density lipoprotein; NR = not reported; TG = triglycerides

## Findings in Relationship to What Is Already Known

This report is an update of a 2009 AHRQ Effective Healthcare Program comparative effectiveness review. The prior review found a paucity of evidence to address these same key questions, and the authors concluded that there was insufficient evidence to determine whether any combination therapy held benefit over monotherapy.55 ,56 We based this update on the prior review; however, a few key differences should be noted. We included only studies with patients of moderate or greater CHD risk who may benefit most from combination therapy or intensification of statin monotherapy, while the prior review included all studies regardless of patient CHD risk. We also categorized statin combination therapy and monotherapy according to individual agents LDL-c lowering potency (low, mid, and high), while the prior review dichotomized agents into low-dose and high-dose. We also required there to be a difference in potency category between the combination therapy and monotherapy arms to reflect a real intensification of statin dose in the monotherapy as compared to the combination arm. These three differences influenced the populations that we included, as well as enabled us to standardize the comparisons of therapeutic regimens across different statin agents. As a result, we excluded many trials from this update that were included in the prior review.

We were able to make conclusions regarding several surrogate clinical markers. Many high profile clinical trials comparing combination therapy agents to statin monotherapy have shown that combination therapy can achieve better lipid outcomes. For example, ezetimibe + high potency simvastatin is more effective at lowering LDL-c than high potency simvastatin monotherapy (ENHANCE) and niacin + high potency simvastatin is more effective at raising HDL-c than high potency simvastatin monotherapy (AIM-HIGH).47 ,53 These trials were not included in this review, as they did not meet our potency comparison requirements. In this review, we found moderate strength evidence supporting low potency statin in combination with either bile acid sequestrant or ezetimibe for lowering LDL-c as compared to mid potency statin monotherapy. There is also low strength evidence supporting mid potency statin in combination with ezetimibe for lowering LDL-c as compared to high potency statin monotherapy. Combination therapy with ezetimibe or niacin raised HDL-c, while combination therapy with bile acid sequestrant had no differential effect on HDL-c as compared to statin monotherapy. We could make no conclusions on combination therapy with fibrates or omega-3 fatty acids on these surrogate makers given the few included trials that used these agents.

## Applicability

Many trials that met our inclusion criteria were implemented in populations of hyperlipidemic patients, and most were designed to evaluate effects on lipid measures and short-term harms. The results of most trials generalize to patients with hyperlipidemia uncomplicated by other major co-morbid conditions. Interestingly, we identified fewer trials that were conducted among high CHD risk patients such as those with diabetes or preexisting cardiovascular disease. These patients could benefit from improvement in their lipid profiles and are the most likely to be receiving more aggressive lipid-modifying regimens in clinical practice. We only identified adequate numbers of trials comparing mid potency statin in combination with ezetimibe to high potency statin monotherapy in these high-risk populations.

Interventions were similar across studies. It is important to note that many trials employed a medication titration regimen to specify how the doses of each medication should be increased to reach their target. This was especially common among trials with niacin, in order to minimize the medication side effects (flushing). These schedules may have improved the tolerability of the medications in the trial, and clinicians should be aware that a similar approach might need to be taken in clinical practice.

## Implications for Clinical and Policy Decisionmaking

These results may help aid individual decision-making and patient management. Our findings may be most applicable to patients who cannot tolerate high-dose statin therapy. The ACC has already released lipid treatment guidelines for patients with stable ischemic heart disease that recommend fibrate or niacin for patients who cannot tolerate statin therapy. Although the studies in our report did not include statin-intolerant patients, perhaps some patients that can tolerate a lower-dose statin with the addition of either bile acid sequestrant or ezetimibe could better achieve additional LDL-lowering. It is unclear whether fibrates, niacin, or omega-3 fatty acids can also have a beneficial LDL-lowering effect in such patients. As noted, we did not include the results from several large trials of an add-on lipid-modifying agent to same potency statin with clinical outcomes, as these studies did not address our key questions. However, these trials showed no clinical benefit of adding an additional agent and our results should be considered within that context when patients and clinicians are considering different lipid-modifying regimens. Clinicians struggle against non-adherence to lipid-modifying therapy, which is common among patients taking these agents.138 We had insufficient data to assess whether adherence differed between lower-potency combination therapy and higher-dose statin monotherapy, which will be an important aspect to address in future trials. Clinicians would also have to consider tolerability and cost issues with their patients. We did not compare tolerability of the individual add-on agents against each other. Adherence data would potentially serve as a proxy measure of tolerability, however, was not consistently reported. Clinicians would also have to consider the cost of the add-on agents with their patients based on drug formularies, as the cost of these agents vary widely.

These results may also help provide an evidence base for future clinical practice guidelines and policy decisions. However, we suspect that the strength of evidence for most comparisons is too low to support guidelines or policy changes at this time.

## Limitations of the Comparative Effectiveness Review Process

This review focused narrowly on combination therapy compared with statin intensification. As a result, many studies of add on combination therapy versus the same statin dose or non-statin monotherapy were excluded, because they did not address the key questions. Given several previous reviews on dietary modification and reduction of lipids and CVD risk, we did not include these therapies in this review.139,140 Further, we did not examine differences in statin response based on genetic variations.141,142 We also excluded non-English language publications, although we do not believe this introduced significant bias. While we were able to standardize the potency of different doses of various statins, we were unable to classify the potency of the other lipid-modifying agents used in the combination therapy arms. We noted differential effects on lipid outcomes in some trials where the same potency statin was used in the combination arm, but different doses of the other agent were used.

This report focuses primarily on LDL-c and HDL-c outcomes due to the available evidence and strategy recommended by the clinical practice guideline at the time this review was conducted. The 2013 cholesterol treatment guidelines had yet to be released and clinical practice relied on recommendations of ATP III, which also emphasized these lipid surrogates. Due to this timing issue, we were also unable to specify the four “statin benefit groups” as our primary populations of interest in this review, although we do believe that we have captured the majority of populations in this report. Additionally, our potency categorizations differ slightly from those in the guidelines.

## Strengths and Limitations of the Evidence Base

The strength of evidence was insufficient for many comparisons and outcomes due to a paucity of studies and poor quality of exisiting studies. Trials were frequently downgraded in risk of bias assessment for lack of blinding by participant and study personnel (performance bias), for not reporting the blinding of outcome assessors (detection bias), or for not accounting for losses to followup or handling of incomplete data (attrition bias). Few studies reported variance estimates for the between group differences in any outcomes over time. In some instances, the studies did not report a mean difference or point estimate stating only that there was no significant difference between the groups. In addition, some studies did not report an intention-to-treat analysis and others did not specify the number analyzed in each arm. All of these factors limited our ability to conduct meta-analyses. Where we conducted meta-analysis, substantial heterogeneity was present in most cases.

The evidence base was also limited due to the short duration of most studies. Most trials we identified were of relatively short duration, despite the fact that these medications are currently used in clinical practice as chronic, long-term medications. Many studies either did not evaluate or were of insufficient duration to adequately assess long-term clinical outcomes including mortality, acute coronary events, and revascularization procedures or tolerability of or persistence to the medication regimen. Studies often pooled results on adverse effects across arms, which limited our ability to determine whether different doses and potencies of combination and monotherapy led to different rates of these events. Ultimately, clinicians hope to reduce the likelihood of negative clinical events for their patients by achieving their lipid goals with medications while minimizing the risk for side effects and harms. Providing evidence that compares combination therapy and intensification of statin monotherapy with respect to these important clinical outcomes, tolerability, and harms would aid decision-making for clinicians and highlight for patients the health benefits of adhering to these regimens.

## Future Research Needs

We suggest that most comparisons and outcomes that have low or insufficient evidence are future research needs. In order to answer whether there are long-term benefits with respect to mortality, acute coronary events, and revascularization procedures, future investigators need to make these endpoints the primary outcomes of their trials and ensure that trials are of sufficient duration to actually capture these events (at least 12 months or preferably longer). Recent trials such as ENHANCE, ACCORD, and AIM-HIGH have failed to show any additional clinical benefit of combination therapy as compared to statin monotherapy.47,51,53 While the forthcoming IMPROVE-IT trial may be able to clarify whether ezetimibe + simvastatin is superior to simvastatin alone with respect to cardiovascular deaths, MI or strokes, this trial uses equivalent doses of simvastatin in the combination and monotherapy arms.52 This trial will not provide information to make decisions about the effectiveness of intensification of statin monotherapy compared to combination therapy. Therefore, additional trials to answer this specific question that are of sufficient duration to capture these outcomes are needed. Trials of longer duration would also better reflect how these medications are currently used in clinical practice, where they are considered chronic use medications. These trials could evaluate outcomes relevant to medication persistence such as tolerability, side effects, and serious adverse events.

We further suggest that future studies focus on high-risk CHD populations and populations with greater burden of cardiovascular disease to determine which strategy provides better short-term improvements in lipid profile and long-term clinical benefits. These populations would include patients with diabetes and preexisting cardiovascular disease, as well as Black and Native American populations.4 It may be worthwhile to explore differences between men and women, as the ACCORD trial showed benefit of combination therapy with fibrate in men and potential harms with this combination therapy in women.51 These studies would have tremendous impact on clinical practice, as these patients are the most likely to need a more aggressive lipid-modifying regimen.

The current head-to-head comparisons of a combination regimen to intensification of statin therapy cannot help clinicians decide between different combination therapy options. The next step to inform clinical decisionmaking would be to help clinicians in selecting the most appropriate lipid-modifying regimen from all available options. We suggest that future studies conduct head-to-head comparisons of multiple combination regimens against each other as well as intensification of statin monotherapy to address this need. Studies are needed that examine whether patients who are unable to tolerate high-potency statin monotherapy could achieve LDL-c and CVD reductions with combination therapy that are consistent with potent statins (50-60%). Furthermore, it would be useful to deteremine if LDL-c lowering of 50% achieved with a statin and a bile acid sequestrant is as efficacious as a statin and ezetimibe, and whether both are as efficacious as a potent statin alone. Finally, alternative study designs such as observational studies using registry data from electronic medical records could provide useful data on long-term or rare clinical outcomes. A number of trials have shown that non-statin lipid modifying medications may not improve or even potentially worsen some clinical outcomes. Future studies may need to consider including non-statin monotherapy as another comparison group with respect to clinical outcomes and harms. Such information would be informative to clinicians who may be considering non-statin monotherapy as a treatment option.

There are design and reporting considerations that should be considered for future studies. Intervention trials should be of sufficient duration to assess the efficacy of interventions on long-term clinical outcomes like mortality, acute coronary events, and revascularization procedures. We suggest that one-year should be a minimum duration of followup for these interventions. We would also encourage future studies to report variance estimates for all outcomes, as well as account for losses to followup by arm and report the number analyzed in each arm. Finally, we would also encourage studies to report adverse event outcomes by individual arm, rather than reporting only pooled results. Different doses and potencies of therapeutic regimens result in differential side effects and harms and this would be important to capture.

## Conclusions

Although many studies looked at intermediate outcomes, few studies addressed the question of which approach produces better clinical outcomes. Combination of statin with ezetimibe or bile acid sequestrant lowered LDL-c better than intensification of statin monotherapy, but evidence for clinical outcomes (mortality, acute coronary events, and revasculartization procedures) was insufficient across all potency comparisons for all combination therapy regimens. Additional studies evaluating long-term clinical benefits and harms are needed to better inform clinical decisionmaking, patient choice, and clinical practice guidelines.