# Evidence Tables

Evidence Table E1 Study characteristics – bile acid sequestrants

Evidence Table E2 Baseline population characteristics – bile acid sequestrants

Evidence Table E3 LDL outcome – bile acid sequestrants

Evidence Table E4 HDL outcome – bile acid sequestrants

Evidence Table E5 Treatment adherence – bile acid sequestrants

Evidence Table E6 Withdrawal due to adverse events – bile acid sequestrants

Evidence Table E7 Elevated AST or ALT – bile acid sequestrants

Evidence Table E8 Study quality assessment – bile acid sequestrants

Evidence Table E9 Study characteristics – ezetimibe

Evidence Table E10 Baseline characteristics – ezetimibe

Evidence Table E11 Mortality – general population

Evidence Table E12 Acute coronary events – general population

Evidence Table E13 Serious adverse events – general population

Evidence Table E14 LDLc outcome – general population

Evidence Table E15 HDL-c – general population

Evidence Table E16 Total cholesterol:HDL – general population

Evidence Table E17 Adherence – general population

Evidence Table E18 Withdrawal due to adverse events – general population

Evidence Table E19 Elevated liver transaminases – general population

Evidence Table E20 Musculoskeletal adverse events – general population

Evidence Table E21 Myalgia – general population

Evidence Table E22 Mortality – patients with CHD

Evidence Table E23 Acute coronary events – patients with CHD

Evidence Table E24 Cerebrovascular event – patients with CHD

Evidence Table E25 Serious adverse event – patients with CHD

Evidence Table E26 LDL – patients with CHD

Evidence Table E27 HDL-c – patients with CHD

Evidence Table E28 Total cholesterol:HDL-c – patients with CHD

Evidence Table E29 Adherence – patients with CHD

Evidence Table E30 Any adverse event – patients with CHD

Evidence Table E31 Withdrawal due to adverse events – patients with CHD

Evidence Table E32 Elevated liver transaminases – patients with CHD

Evidence Table E33 Musculoskeletal adverse events – patients with CHD

Evidence Table E34 Myalgia – patients with CHD

Evidence Table E35 Mortality – patients with diabetes mellitus

Evidence Table E36 Serious adverse events – patients with diabetes mellitus

Evidence Table E37 LDL – patients with diabetes mellitus

Evidence Table E38 HDL-c – patients with diabetes mellitus

Evidence Table E39 Total cholesterol:HDL-c – patients with diabetes mellitus

Evidence Table E40 Non-HDL-c – patients with diabetes mellitus

Evidence Table E41 Triglycerides – patients with diabetes mellitus

Evidence Table E42 Adherence – patients with diabetes mellitus

Evidence Table E43 Musculoskeletal adverse events – patients with diabetes mellitus

Evidence Table E44 Myalgia – patients with diabetes mellitus

Evidence Table E45 Withdrawal due to adverse events – patients with diabetes mellitus

Evidence Table E46 Any adverse event – patients with diabetes mellitus

Evidence Table E47 Mortality elderly – elderly patients (> 75 years old)

Evidence Table E48 SAE elderly – elderly patients (> 75 years old)

Evidence Table E49 LDL elderly patients (> 75 years old)

Evidence Table E50 HDL-c – elderly

Evidence Table E51 Total cholesterol:HDL – elderly patients

Evidence Table E52 Any adverse event – elderly patients

Evidence Table E53 Withdrawal due to adverse events – elderly patients

Evidence Table E54 Elevated liver transaminases – elderly patients

Evidence Table E55 Musculoskeletal adverse events – elderly

Evidence Table E56 LDL-c – female patients

Evidence Table E57 LDL – Asian patients

Evidence Table E58 LDL – Black patients

Evidence Table E59 LDL – Hispanic patients

Evidence Table E60 Summary of evidence available for subgroups comparing combination therapy with ezetimibe and statin to intensification of statin monotherapy

Evidence Table E61 Study quality assessment – ezetimibe

Evidence Table E62 Study characteristics – fibrates

Evidence Table E63 Baseline population characteristics – fibrates

Evidence Table E64 Mortality – fibrates

Evidence Table E65 Unspecified myocardial infarction (MI) – fibrates

Evidence Table E66 Transient ischemic attack (TIA) – fibrates

Evidence Table E67 Serious adverse events (SAE) – fibrates

Evidence Table E68 LDL (mg/dL) outcome – fibrates

Evidence Table E69 LDL goal attainment – fibrates

Evidence Table E70 HDL (mg/dL) outcome – fibrates

Evidence Table E71 Total cholesterol:HDL ratio – fibrates

Evidence Table E72 Triglycerides and non-HDL-c among diabetes subgroup – fibrates

Evidence Table E73 Treatment adherence – fibrates

Evidence Table E74 Occurrence of at least one adverse event – fibrates

Evidence Table E75 Elevated liver transaminases – fibrates

Evidence Table E76 Elevated creatinine phosphokinase (CPK) – fibrates

Evidence Table E77 Rhabdomyolysis – fibrates

Evidence Table E78 Myalgia – fibrates

Evidence Table E79 Acute kidney injury (AKI) – fibrates

Evidence Table E80 Study quality assessment – fibrates

Evidence Table E81 Study characteristics – niacin

Evidence Table E82 Baseline population characteristics – niacin

Evidence Table E83 All cause mortality – niacin

Evidence Table E84 Vascular deaths – niacin

Evidence Table E85 Acute coronary syndrome – niacin

Evidence Table E86 LDL outcome – niacin

Evidence Table E87 HDL outcome – niacin

Evidence Table E88 Experiencing any adverse event – niacin

Evidence Table E89 Withdrawal due to adverse events – niacin

Evidence Table E90 Elevated AST or ALT – niacin

Evidence Table E91 Myalgia – niacin

Evidence Table E92 Elevated creatine phosphokinase – niacin

Evidence Table E93 New onset diabetes mellitus – niacin

Evidence Table E94 Treatment adherence – niacin

Evidence Table E95 Study quality assessment – niacin

## Reference List

1 Barbi G, et al. Effect of Pravastatin and Cholestyramine on Triglycerids-Rich Lipoprotein Particles and Lp(a) in Patients With Type II Hypercholesterolemia. 1992;27:297-306. PMID:.
2 Ismail F, Corder CN, Epstein S, Barbi G, Thomas S. Effects of pravastatin and cholestyramine on circulating levels of parathyroid hormone and vitamin D metabolites. Clin Ther. 1990;12(5):427-30. [pmid: 2125243].
3 Hunninghake D, Insull W Jr, Toth P, Davidson D, Donovan JM, Burke SK. Coadministration of colesevelam hydrochloride with atorvastatin lowers LDL cholesterol additively. Atherosclerosis. 2001;158(2):407-16. [pmid: 11583720].
4 Johansson J. Low-dose combination therapy with colestipol and simvastatin in patients with moderate to severe hypercholesterolaemia. 1995;5:39-44. PMID:.
5 Knapp HH, Schrott H, Ma P, et al. Efficacy and safety of combination simvastatin and colesevelam in patients with primary hypercholesterolemia. Am J Med. 2001;110(5):352-60. [pmid: 11286949].
6 Comparative efficacy and safety of pravastatin and cholestyramine alone and combined in patients with hypercholesterolemia. Pravastatin Multicenter Study Group II. Arch Intern Med. 1993;153(11):1321-9. [pmid: 8507122].
7 Schrott HG, Stein EA, Dujovne CA, et al. Enhanced low-density lipoprotein cholesterol reduction and cost-effectiveness by low-dose colestipol plus lovastatin combination therapy. Am J Cardiol. 1995;75(1):34-9. [pmid: 7801861].
8 Ahmed S, Ullah E, Ahmed M, Abbas R, Khan MA, Iqbal J. Efficacy of combination of ezetimibe and simvastatin versus atorvastatin in reducing low density lipoprotein-cholesterol in male patients of hypercholesterolemia, at Bahawalpur. Medical Forum Monthly. 2008;19(5):3-9.
9 Araujo DB, Bertolami MC, Ferreira WP, et al. Pleiotropic effects with equivalent low-density lipoprotein cholesterol reduction: comparative study between simvastatin and simvastatin/ezetimibe coadministration. J Cardiovasc Pharmacol. 2010;55(1):1-5. [pmid: 19770669].
10 Averna M, Zaninelli A, Le Grazie C, Gensini GF. Ezetimibe/simvastatin 10/20 mg versus simvastatin 40 mg in coronary heart disease patients. J Clin Lipidol. 2010;4(4):272-8. [pmid: 21122660].
11 Ballantyne CM, Houri J, Notarbartolo A, et al. Effect of ezetimibe coadministered with atorvastatin in 628 patients with primary hypercholesterolemia: a prospective, randomized, double-blind trial. Circulation. 2003;107(19):2409-15. [pmid: 12719279].
12 Ballantyne CM, Abate N, Yuan Z, King TR, Palmisano J. Dose-comparison study of the combination of ezetimibe and simvastatin (Vytorin) versus atorvastatin in patients with hypercholesterolemia: the Vytorin Versus Atorvastatin (VYVA) study. Am Heart J. 2005;149(3):464-73. [pmid: 15864235].
13 Bardini G, Giorda CB, Pontiroli AE, Le Grazie C, Rotella CM. Ezetimibe + simvastatin versus doubling the dose of simvastatin in high cardiovascular risk diabetics: a multicenter, randomized trial (the LEAD study). Cardiovasc Diabetol. 2010;9:20. [pmid: 20492655].
14 Barrios V, Amabile N, Paganelli F, et al. Lipid-altering efficacy of switching from atorvastatin 10 mg/day to ezetimibe/simvastatin 10/20 mg/day compared to doubling the dose of atorvastatin in hypercholesterolaemic patients with atherosclerosis or coronary heart disease. Int J Clin Pract. 2005;59(12):1377-86. [pmid: 16351668].
15 Catapano AL, Davidson MH, Ballantyne CM, et al. Lipid-altering efficacy of the ezetimibe/simvastatin single tablet versus rosuvastatin in hypercholesterolemic patients. Curr Med Res Opin. 2006;22(10):2041-53. [pmid: 17022864].
16 Cho YK, Hur SH, Han CD, et al. Comparison of Ezetimibe/Simvastatin 10/20 mg Versus Atorvastatin 20 mg in Achieving a Target Low Density Lipoprotein-Cholesterol Goal for Patients With Very High Risk. Korean Circ J. 2011;41(3):149-53. [pmid: 21519514].
17 Constance C, Westphal S, Chung N, et al. Efficacy of ezetimibe/simvastatin 10/20 and 10/40 mg compared with atorvastatin 20 mg in patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2007;9(4):575-84. [pmid: 17451425].
18 Davidson MH, McGarry T, Bettis R, et al. Ezetimibe coadministered with simvastatin in patients with primary hypercholesterolemia. J Am Coll Cardiol. 2002;40(12):2125-34. [pmid: 12505224].
19 Feldman T, Koren M, Insull W Jr, et al. Treatment of high-risk patients with ezetimibe plus simvastatin co-administration versus simvastatin alone to attain National Cholesterol Education Program Adult Treatment Panel III low-density lipoprotein cholesterol goals. Am J Cardiol. 2004;93(12):1481-6. [pmid: 15194017].
20 Florentin M, Liberopoulos EN, Moutzouri E, Rizos CV, Tselepis AD, Elisaf MS. The effect of simvastatin alone versus simvastatin plus ezetimibe on the concentration of small dense low-density lipoprotein cholesterol in subjects with primary hypercholesterolemia. Curr Med Res Opin. 2011;27(3):685-92. [pmid: 21271793].
21 Foody JM, Brown WV, Zieve F, et al. Safety and efficacy of ezetimibe/simvastatin combination versus atorvastatin alone in adults >/=65 years of age with hypercholesterolemia and with or at moderately high/high risk for coronary heart disease (the VYTELD study). Am J Cardiol. 2010;106(9):1255-63. [pmid: 21029821].
22 Gaudiani LM, Lewin A, Meneghini L, et al. Efficacy and safety of ezetimibe co-administered with simvastatin in thiazolidinedione-treated type 2 diabetic patients. Diabetes Obes Metab. 2005;7(1):88-97. [pmid: 15642080].
23 Goldberg AC, Sapre A, Liu J, Capece R, Mitchel YB. Efficacy and safety of ezetimibe coadministered with simvastatin in patients with primary hypercholesterolemia: a randomized, double-blind, placebo-controlled trial. Mayo Clin Proc. 2004;79(5):620-9. [pmid: 15132403].
24 Goldberg RB, Guyton JR, Mazzone T, et al. Ezetimibe/simvastatin vs atorvastatin in patients with type 2 diabetes mellitus and hypercholesterolemia: the VYTAL study. Mayo Clin Proc. 2006;81(12):1579-88. [pmid: 17165637].
25 Tomassini JE, Mazzone T, Goldberg RB, et al. Effect of ezetimibe/simvastatin compared with atorvastatin on lipoprotein subclasses in patients with type 2 diabetes and hypercholesterolaemia. Diabetes Obes Metab. 2009;11(9):855-64. [pmid: 19508464].
26 Guyton JR, Goldberg RB, Mazzone T, et al. Lipoprotein and apolipoprotein ratios in the VYTAL trial of ezetimibe/simvastatin compared with atorvastatin in type 2 diabetes. J Clin Lipidol. 2008;2(1):19-24. [pmid: 21291711].
27 Hamdan R, Hajj F, Kadry Z, et al. Benefit and tolerability of the coadministration of ezetimibe and atorvastatin in acute coronary syndrome patients. J Med Liban. 2011;59(2):65-9. [pmid: 21834489].
28 Her AY, Kim JY, Kang SM, et al. Effects of atorvastatin 20 mg, rosuvastatin 10 mg, and atorvastatin/ezetimibe 5 mg/5 mg on lipoproteins and glucose metabolism. J Cardiovasc Pharmacol Ther. 2010;15(2):167-74. [pmid: 20147603].
29 Kawagoe Y, Hattori Y, Nakano A, et al. Comparative study between high-dose fluvastatin and low-dose fluvastatin and ezetimibe with regard to the effect on endothelial function in diabetic patients. Endocr J. 2011;58(3):171-5. [pmid: 21304215].
30 Kerzner B, Corbelli J, Sharp S, et al. Efficacy and safety of ezetimibe coadministered with lovastatin in primary hypercholesterolemia. Am J Cardiol. 2003;91(4):418-24. [pmid: 12586255].
31 Lee SH, Kang SM, Park S, Jang Y, Chung N, Choi D. The effects of statin monotherapy and low-dose statin/ezetimibe on lipoprotein-associated phospholipase A(2). Clin Cardiol. 2011;34(2):108-12. [pmid: 21298654].
32 Lee SH, Park S, Kang SM, Jang Y, Chung N, Choi D. Effect of atorvastatin monotherapy and low-dose atorvastatin/ezetimibe combination on fasting and postprandial triglycerides in combined hyperlipedemia. J Cardiovasc Pharmacol Ther. 2012;17(1):65-71. [pmid: 21386036].
33 Lee JH, Kang HJ, Kim HS, Sohn DW, Oh BH, Park YB. Effects of Ezetimibe/Simvastatin 10/20 mg vs. Atorvastatin 20 mg on Apolipoprotein B/Apolipoprotein A1 in Korean Patients with Type 2 Diabetes Mellitus: Results of a Randomized Controlled Trial. Am J Cardiovasc Drugs. 2013. [pmid: 23728830].
34 Liberopoulos EN, Makariou SE, Moutzouri E, Kostapanos MS, Challa A, Elisaf M. Effect of Simvastatin/Ezetimibe 10/10 mg Versus Simvastatin 40 mg on Serum Vitamin D Levels. J Cardiovasc Pharmacol Ther. 2013. [pmid: 23288870].
35 Matsue Y, Matsumura A, Suzuki M, Hashimoto Y, Yoshida M. Differences in action of atorvastatin and ezetimibe in lowering low-density lipoprotein cholesterol and effect on endothelial function. Circ J. 2013;77(7):1791-8. [pmid: 23603824].
36 McKenney JM, Jones PH, Bays HE, et al. Comparative effects on lipid levels of combination therapy with a statin and extended-release niacin or ezetimibe versus a statin alone (the COMPELL study). Atherosclerosis. 2007;192(2):432-7. [pmid: 17239888].
37 Moutzouri E, Liberopoulos E, Mikhailidis DP, et al. Comparison of the effects of simvastatin vs. rosuvastatin vs. simvastatin/ezetimibe on parameters of insulin resistance. Int J Clin Pract. 2011;65(11):1141-8. [pmid: 21995692].
38 Moutzouri E, Tellis CC, Rousouli K, et al. Effect of simvastatin or its combination with ezetimibe on Toll-like receptor expression and lipopolysaccharide - induced cytokine production in monocytes of hypercholesterolemic patients. Atherosclerosis. 2012;225(2):381-7. [pmid: 23062767].
39 Okada K, Kimura K, Iwahashi N, et al. Clinical usefulness of additional treatment with ezetimibe in patients with coronary artery disease on statin therapy. - From the viewpoint of cholesterol metabolism.-. Circ J. 2011;75(10):2496-504. [pmid: 21817821].
40 Ostad MA, Eggeling S, Tschentscher P, et al. Flow-mediated dilation in patients with coronary artery disease is enhanced by high dose atorvastatin compared to combined low dose atorvastatin and ezetimibe: results of the CEZAR study. Atherosclerosis. 2009;205(1):227-32. [pmid: 19150064].
41 Pesaro AE, Serrano CV Jr, Fernandes JL, et al. Pleiotropic effects of ezetimibe/simvastatin vs. high dose simvastatin. Int J Cardiol. 2012;158(3):400-4. [pmid: 21334753].
42 Piorkowski M, Fischer S, Stellbaum C, et al. Treatment with ezetimibe plus low-dose atorvastatin compared with higher-dose atorvastatin alone: is sufficient cholesterol-lowering enough to inhibit platelets?. J Am Coll Cardiol. 2007;49(10):1035-42. [pmid: 17349882].
43 Robinson JG, Ballantyne CM, Grundy SM, et al. Lipid-altering efficacy and safety of ezetimibe/simvastatin versus atorvastatin in patients with hypercholesterolemia and the metabolic syndrome (from the VYMET study). Am J Cardiol. 2009;103(12):1694-702. [pmid: 19539078].
44 Roeters van Lennep HW, Liem AH, Dunselman PH, Dallinga-Thie GM, Zwinderman AH, Jukema JW. The efficacy of statin monotherapy uptitration versus switching to ezetimibe/simvastatin: results of the EASEGO study. Curr Med Res Opin. 2008;24(3):685-94. [pmid: 18226326].
45 Rudofsky G, Reismann P, Groener JB, et al. Identical LDL-cholesterol lowering but non-identical effects on NF-kappaB activity: High dose simvastatin vs combination therapy with ezetimibe. Atherosclerosis. 2012;223(1):190-6. [pmid: 22633472].
46 Stein E, Stender S, Mata P, et al. Achieving lipoprotein goals in patients at high risk with severe hypercholesterolemia: efficacy and safety of ezetimibe co-administered with atorvastatin. Am Heart J. 2004;148(3):447-55. [pmid: 15389231].
47 Yamazaki D, Ishida M, Watanabe H, et al. Comparison of anti-inflammatory effects and high-density lipoprotein cholesterol levels between therapy with quadruple-dose rosuvastatin and rosuvastatin combined with ezetimibe. Lipids Health Dis. 2013;12(1):9. [pmid: 23374898].
48 Zieve F, Wenger NK, Ben-Yehuda O, et al. Safety and efficacy of ezetimibe added to atorvastatin versus up titration of atorvastatin to 40 mg in Patients > or = 65 years of age (from the ZETia in the ELDerly. Am J Cardiol. 2010;105(5):656-63. [pmid: 20185012].
49 Ben-Yehuda O, Wenger NK, Constance C, et al. The comparative efficacy of ezetimibe added to atorvastatin 10 mg versus uptitration to atorvastatin 40 mg in subgroups of patients aged 65 to 74 years or greater than or equal to 75 years. J Geriatr Cardiol. 2011;8(1):1-11. [pmid: 22783278].
50 Bays HE, Ose L, Fraser N, et al. A multicenter, randomized, double-blind, placebo-controlled, factorial design study to evaluate the lipid-altering efficacy and safety profile of the ezetimibe/simvastatin tablet compared with ezetimibe and simvastatin monotherapy in patients with primary hypercholesterolemia. Clin Ther. 2004;26(11):1758-73. [pmid: 15639688].
51 Athyros VG, Papageorgiou AA, Athyrou VV, Demitriadis DS, Pehlivanidis AN, Kontopoulos AG. Atorvastatin versus four statin-fibrate combinations in patients with familial combined hyperlipidaemia. J Cardiovasc Risk. 2002;9(1):33-9. [pmid: 11984215].
52 Farnier M, Steinmetz A, Retterstol K, Csaszar A. Fixed-dose combination fenofibrate/pravastatin 160/40 mg versus simvastatin 20 mg monotherapy in adults with type 2 diabetes and mixed hyperlipidemia uncontrolled with simvastatin 20 mg: a double-blind, randomized comparative study. Clin Ther. 2011;33(1):1-12. [pmid: 21397769].
53 Mohiuddin SM, Pepine CJ, Kelly MT, et al. Efficacy and safety of ABT-335 (fenofibric acid) in combination with simvastatin in patients with mixed dyslipidemia: a phase 3, randomized, controlled study. Am Heart J. 2009;157(1):195-203. [pmid: 19081418].
54 Shah HD, Parikh KH, Chag MC, et al. Beneficial effects of addition of fenofibrate to statin therapy in patients with acute coronary syndrome after percutaneous coronary interventions. World Heart Journal. 2008;1(1):69-77.
55 Airan-Javia SL, Wolf RL, Wolfe ML, Tadesse M, Mohler E, Reilly MP. Atheroprotective lipoprotein effects of a niacin-simvastatin combination compared to low- and high-dose simvastatin monotherapy. Am Heart J. 2009;157(4):687.e1-8. [pmid: 19332196].
56 Bays HE, McGovern ME. Once-daily niacin extended release/lovastatin combination tablet has more favorable effects on lipoprotein particle size and subclass distribution than atorvastatin and simvastatin. Prev Cardiol. 2003;6(4):179-88. [pmid: 14605511].
57 Gardner SF, Schneider EF, Granberry MC, Carter IR. Combination therapy with low-dose lovastatin and niacin is as effective as higher-dose lovastatin. Pharmacotherapy. 1996;16(3):419-23. [pmid: 8726600].
58 Hunninghake DB, McGovern ME, Koren M, et al. A dose-ranging study of a new, once-daily, dual-component drug product containing niacin extended-release and lovastatin. Clin Cardiol. 2003;26(3):112-8. [pmid: 12685616].
59 Insull W Jr, McGovern ME, Schrott H, et al. Efficacy of extended-release niacin with lovastatin for hypercholesterolemia: assessing all reasonable doses with innovative surface graph analysis. Arch Intern Med. 2004;164(10):1121-7. [pmid: 15159270].