# Screening and Data Abstraction Forms

Title-Abstract Screening Form

Appendix C consists of the screening and data abstraction forms. Abstracts were screened independently by two trained reviewers, and were excluded if both reviewers agreed that the article met one or more of the exclusion criteria. Citations promoted on the basis of abstract screen underwent independent paired-reviewer screen using the full-text article. Differences regarding article inclusion were resolved through consensus. At this level, the authors also screened all studies included in the prior review to ensure that they met the current eligibility criteria.

Article Screening Form – Exclusion

Appendix C consists of the screening and data abstraction forms. Abstracts were screened independently by two trained reviewers, and were excluded if both reviewers agreed that the article met one or more of the exclusion criteria. Citations promoted on the basis of abstract screen underwent independent paired-reviewer screen using the full-text article. Differences regarding article inclusion were resolved through consensus. At this level, the authors also screened all studies included in the prior review to ensure that they met the current eligibility criteria.

Article Screening Form – Inclusion

Appendix C consists of the screening and data abstraction forms. Abstracts were screened independently by two trained reviewers, and were excluded if both reviewers agreed that the article met one or more of the exclusion criteria. Citations promoted on the basis of abstract screen underwent independent paired-reviewer screen using the full-text article. Differences regarding article inclusion were resolved through consensus. At this level, the authors also screened all studies included in the prior review to ensure that they met the current eligibility criteria.

## SRDR – Data Abstraction Forms

Design Form

Appendix C consists of the screening and data abstraction forms. Abstracts were screened independently by two trained reviewers, and were excluded if both reviewers agreed that the article met one or more of the exclusion criteria. Citations promoted on the basis of abstract screen underwent independent paired-reviewer screen using the full-text article. Differences regarding article inclusion were resolved through consensus. At this level, the authors also screened all studies included in the prior review to ensure that they met the current eligibility criteria.

Arms

Appendix C consists of the screening and data abstraction forms. Abstracts were screened independently by two trained reviewers, and were excluded if both reviewers agreed that the article met one or more of the exclusion criteria. Citations promoted on the basis of abstract screen underwent independent paired-reviewer screen using the full-text article. Differences regarding article inclusion were resolved through consensus. At this level, the authors also screened all studies included in the prior review to ensure that they met the current eligibility criteria.

Arm Details

Appendix C consists of the screening and data abstraction forms. Abstracts were screened independently by two trained reviewers, and were excluded if both reviewers agreed that the article met one or more of the exclusion criteria. Citations promoted on the basis of abstract screen underwent independent paired-reviewer screen using the full-text article. Differences regarding article inclusion were resolved through consensus. At this level, the authors also screened all studies included in the prior review to ensure that they met the current eligibility criteria.

Baseline Data Characteristics

Appendix C consists of the screening and data abstraction forms. Abstracts were screened independently by two trained reviewers, and were excluded if both reviewers agreed that the article met one or more of the exclusion criteria. Citations promoted on the basis of abstract screen underwent independent paired-reviewer screen using the full-text article. Differences regarding article inclusion were resolved through consensus. At this level, the authors also screened all studies included in the prior review to ensure that they met the current eligibility criteria.

Results

Appendix C consists of the screening and data abstraction forms. Abstracts were screened independently by two trained reviewers, and were excluded if both reviewers agreed that the article met one or more of the exclusion criteria. Citations promoted on the basis of abstract screen underwent independent paired-reviewer screen using the full-text article. Differences regarding article inclusion were resolved through consensus. At this level, the authors also screened all studies included in the prior review to ensure that they met the current eligibility criteria.