# Detailed Search Strategies

## PubMed

“Hydroxymethylglutaryl-CoA Reductase Inhibitors” [mh] OR “Heptanoic Acids” [mh] OR “Heptanoic Acids” [tiab] OR statin*[tiab] OR “reductase inhibitor”[tiab] OR Simvastatin [mh] OR Simvastatin [tiab] OR Atorvastatin [nm] OR Atorvastatin [tiab] OR Rosuvastatin [nm] OR Rosuvastatin [tiab] OR Pravastatin [mh] OR Pravastatin [tiab] OR Lovastatin [mh] OR Lovastatin [tiab] OR Fluvastatin [nm] OR Fluvastatin [tiab] OR Pitavastatin[nm] OR Pitavastatin[tiab]

AND

(“fatty acids, omega-3”[MeSH Terms] OR “omega 3” [tiab] OR “fatty acids” [tiab] OR “fatty acids, essential”[MeSH Terms] OR “dietary fats, unsaturated”[MeSH Terms] OR linolenic acids [tiab] OR “fish oils”[MeSH Terms] OR “fish oils” [tiab] OR “alpha linolenic acid” [tiab] OR linolenate[tiab] OR “nervonic acid”[nm]OR “nervonic acid”[tiab] OR timnodonic acid[tiab] OR “diet, mediterranean”[MeSH Terms] OR (Mediterranean[tiab] AND diet[tiab]) OR “flax”[MeSH Terms] OR “brassica rapa”[MeSH Terms] OR “soybeans”[MeSH Terms] OR “juglans”[MeSH Terms] OR ((Flax[tiab] OR flaxseed [tiab] OR linseed [tiab] OR rapeseed [tiab] OR canola [tiab] OR soybean [tiab] OR walnut [tiab]) AND Oil[tiab]) OR “cod liver oil”[MeSH Terms] OR “cod liver oil”[tiab] OR salmon[MH] OR salmon[tiab]OR “perciformes”[MeSH Terms] OR mackerel[tiab] or “tuna”[MeSH Terms] or tuna[tiab] or “flounder”[MeSH Terms] or halibut[tiab] or “seals, earless”[MeSH Terms] or seal[tiab] or “seaweed”[MeSH Terms] or seaweed [tiab] OR “anticholesteremic agents”[MeSH Terms] OR anticholesteremics [tiab] OR “bile acids and salts”[MeSH Terms] OR “bile acids”[tiab] OR (bile[tiab] AND resin*[tiab]) OR “bile acid sequestrant”[tiab] OR “cholestyramine resin”[MeSH Terms] OR cholestyramine [tiab] OR colestyramin [tiab] OR “colesevelam”[Supplementary Concept] OR colesevelam[tiab] OR “colestipol”[MeSH Terms] OR Colestipol [tiab] OR colestilan[tiab] OR “ezetimibe”[Supplementary Concept] OR ezetimibe[tiab] OR (cholesterol*[tiab] AND inhibitors*[tiab]) OR “fibric acids”[MeSH Terms] OR fibrates [tiab] OR fibric acid [tiab] OR Gemfibrozil [tiab] OR fenofibrate [tiab] OR niacin [MH] OR niacin [tiab] OR nicotinic acid[MH] OR nicotinic acid[tiab] OR “drug therapy, combination”[MeSH Terms] OR (combination[tiab] AND therapy[tiab]) OR“add-on therapy” [ti] )

AND

“cardiovascular diseases”[MeSH Terms]OR “cardiovascular disease” [tiab] OR “cardiovascular diseases”[tiab] OR “myocardial infarction” [tiab] OR strokes [tiab] OR “heart failure”[tiab] OR “arrhythmia”[tiab] OR “heart valve disease”[tiab] OR hypertension [tiab] or coronary [tiab] OR angina [tiab] OR “cerebrovascular accident” [tiab] OR “Hypercholesterolemia” [mh] OR “Hypercholesterolemia” [tiab] OR hypercholesterolaemia [tiab] OR “Hyperlipidemias”[mh] OR “Hyperlipidemias”[tiab] OR hyperlipidaemia [tiab] OR “transient ischemic attack” [tiab] OR “transient ischaemic attack” [tiab] OR “TIA”[tiab] OR Dyslipidemias[mh] OR Dyslipidemias[tiab] OR Dyslipidemia[tiab]

AND

(randomized controlled trial[pt] OR controlled clinical trial [pt] or randomized controlled trials[mh] or random allocation[mh] or double-blind method[mh] or single-blind method[mh] OR clinical trial[pt] or clinical trials[mh] or (“clinical trial”[tw]) OR ((singl*[tw] OR doubl*[tw] OR trebl*[tw] OR tripl*[tw]) AND (mask*[tw] OR blind* [tw])) OR (“latin square”[tw]) OR placebos[mh] OR placebo*[tw] OR rando*[tw] OR research design[mh:noexp]) Not (animal[mh] Not human[mh])