# Acronyms and Abbreviations

ACC: American College of Cardiology
ACCF: American College of Cardiology Foundation
ACCORD: Action to Control Cardiovascular Risk in Diabetes
ACS: Acute coronary syndrome
ADA: American Diabetes Association
AE: Adverse events
AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
AIM-HIGH: Atherothrombosis Intervention in Metabolic Syndrome with Low HDL Cholesterol/High Triglyceride and Impact on Global Health Outcomes
AKI: Acute kidney injury
ALT: Alanine transaminase
ARBITER-6 HALTS: Arterial Biology for the Investigation of the Treatment Effects of Reducing Cholesterol 6–HDL and LDL Treatment Strategies in Atherosclerosis
AST: Aspartate transaminase
ATP: Adult Treatment Panel
ATV: Atorvastatin
BAS: Bile acid sequestrants
CAD: Coronary artery disease
CENTRAL: Cochrane Central Register of Controlled Trials
CHD: Coronary heart disease
CI: Confidence interval
CIMT: Carotid intima-media thickness
CPK: Creatinine phospokinase
CVD: Cardiovascular disease
DHA: Docosahexaenoic acid
DM: Diabetes mellitus
ENHANCE: The Ezetimibe and Simvastatin in Hypercholesterolemia Enhances Atherosclerosis Regression
EPA: Eicosapentaenoic acid
FDA: U.S. Food and Drug Administration
FH: Familial hypercholesterolemia
HDL-c: High-density lipoprotein
HMG-CoA: 3-hydroxy-3-methylglutaryl coenzyme A
HSP-2 THRIVE: Heart Protection Study 2 Treatment of HDL to Reduce the Incidence of Vascular Events
IMPROVE-IT: Improved Reduction of Outcomes: Vytorin Efficacy International
LDL-c: Low-density lipoprotein
LOV: Lovastatin
LS: Least square
MI: Myocardial infarction
NA: Not applicable
NHBLI: The National Heart, Lung, and Blood Institute
NCEP: National Cholesterol Education Program
N-ER: Niacin- extended release
NPC1L1: Niemann-Pick C1-like protein
NR: Not reported
NRS: Non-randomized studies
NS: Not significant
OIS: optimal information size
PICOS: Population intervention comparison outcome setting
PMSG II: Pravastatin Multicenter Study Group II.
RCT: Randomized controlled study
RSV: Rosuvasttain
SAE: Serious adverse events
SD: Standard deviation
SE: Standard error
SIP: Scientific information packet
SMV: Simvastatin
SOE: Strength of evidence
SRDR: Systematic Review Data Repository
TC: Total cholesterol
TIA: Transient ischemic attack
UA: Unstable angina
ULN: Upper normal limit