# Results

## Search Results

From our searches, we retrieved 17,745 articles after removing duplicates (Figure 4). After title and abstract review, we decided 1,138 articles were potentially relevant to review, and we retrieved the full articles. We included a total of 136 studies in this review (see Appendix C for list of articles excluded at the full text level).

Figure 4 Summary of the literature search (number of articles)

CENTRAL = Central Register of Controlled Trials; KQ = Key Question; OS = observational study; RCT = randomized controlled trial

^*^ The total may exceed number in corresponding box, as articles could be excluded for more than one reason at this level.

Figure 4 is the summary of the literature search. A total of 24958 citations were retrieved, and 17745 were title reviewed. We reviewed 5278 abstracts, and then 1138 articles. We included 202 publications, which represented 136 studies. Forty-four studies were included for KQ1, 36 for KQ2, 47 RCTs and 61 observational studies for KQ3, 1 RCT and 1 observational study for KQ4, and 5 RCTs and 5 observational studies for pediatrics.

We reported the results of our systematic review according to Key Question, and separated adults from children. For the efficacy results, we organized the results for each Key Question by medication class--natalizumab, TNF-alpha inhibitor, thiopurines, methotrexate, corticosteroids, or aminosalicylates. When a study compared multiple medication classes, we began with the first medication in our list of medication classes, which we organized according to the top-down approach in the treatment pyramid (Figure 2).

Within each medication class, we reported the study design, population characteristics, key points, strength of evidence (SOE) grading, and the outcomes results. We created key points for each comparison that had at least moderate SOE or a clinically meaningful difference. In the key points we presented the conclusion, the pooled relative risk or the range of risk differences, the placebo rates, and the SOE. We also presented the relative risk and risk differences in the SOE tables. We arranged the outcomes results by comparison. We presented the monotherapy placebo-controlled trials first, followed by monotherapy head-to-head comparisons, combination therapy placebo-controlled trials, combination therapy versus monotherapy comparisons, and combination therapy head-to-head comparisons. We reported the results of those meta-analyses for which we were able to combine clinically homogenous studies. When we were unable to pool the results, we presented the data in tables.

We organized the safety results by outcome then by medication class. We reported the subgroup analyses at the end of each Key Question. Detailed evidence tables are found in Appendix D.

## Key Question 1 Effectiveness of Therapies To Induce Remission in Adults

In order for trials to qualify for KQ1, patients had to have active disease at the time of randomization so that we could identify the effect of treatments to induce remission. In the Methods we describe induction of remission as occurring within 16 weeks of treatment for active disease. From a clinical perspective, later time points are better measures of maintenance of remission after induction. Regardless, the trials that reported on outcomes after 16 weeks are included in this section rather than in KQ2 because we distinguished KQ1 from KQ2 based on the disease activity at randomization.

Table 6 summarizes the evidence grades and specific conclusions for each comparison. Details of the evidence grades are included in the Results and in Appendix D, Table 1.

Table 6 Key findings and strength of evidence comparing pharmacologic therapies for the management of Crohn's disease to induce remission^*^

Comparison Maximum Trial Duration | Disease Activity Measure Weeks 2-4 | Disease Activity Measure Weeks 12-16 | Disease Activity Measure After 16 Weeks | Mucosal Healing | Hospitalizations and Surgeries | Reduction of Steroids | Fistula Response | Inflammatory Bowel Disease Questionnaire^†^
Natalizumab vs. placebo 12 weeks | Favors natalizumab; Moderate SOE | Favors natalizumab; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 12 Favors neither; Moderate SOE
Natalizumab + infliximab vs. infliximab 10 weeks | Favors neither; Low SOE | Favors neither; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 10 Favors neither; Low SOE
Adalimumab vs. placebo 4 weeks | >160 mg sc dose Favors adalimumab; High SOE ≤80 mg sc dose Favors neither; Moderate SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 4 Favors neither; Low SOE | Week 4 Favors neither; High SOE
CP vs. placebo 26 weeks | Favors neither; Low SOE | Favors neither; Low SOE | Week 26 Favors CP; Low SOE | Insufficient | Insufficient | Insufficient | Week 26 Favors neither; Low SOE | Week 12 and Week 26 Favors neither; Low SOE
Infliximab vs. placebo 12 weeks | Favors infliximab; Moderate SOE | Favors infliximab; Low SOE | Insufficient | Week 4 Favors infliximab; Low SOE | Insufficient | Insufficient | Week 6 Favors infliximab; High SOE | Week 4 Favors infliximab; Moderate SOE
Infliximab vs. azathioprine 26 weeks | Insufficient | Favors infliximab; Moderate SOE | Week 26 Favors infliximab; Moderate SOE | Week 26 Favors infliximab; Low SOE | Insufficient | Insufficient | Insufficient | Week 26 Favors neither; Moderate SOE
Infliximab + azathioprine vs. infliximab 26 weeks | Insufficient | Favors infliximab + azathioprine; Moderate SOE | Week 26 Favors infliximab + azathioprine; Moderate SOE | Week 26 Favors infliximab + azathioprine; Low SOE | Insufficient | Insufficient | Insufficient | Week 26 Favors neither; Moderate SOE
Infliximab + azathioprine vs. azathioprine 26 weeks | Insufficient | Favors infliximab + azathioprine; Moderate SOE | Week 26 Favors infliximab + azathioprine; Moderate SOE | Week 26 Favors infliximab + azathioprine; Low SOE | Insufficient | Insufficient | Insufficient | Week 26 Favors neither; Moderate SOE
Infliximab + azathioprine vs. steroids 104 weeks | Insufficient | Insufficient | Week 104 Favors neither; Low SOE | Week 104 Favors infliximab + azathioprine; Low SOE | Insufficient | Insufficient | Insufficient | Week 10 Favors infliximab + azathioprine; Low SOE
Infliximab + methotrexate vs. infliximab 48 weeks | Favors infliximab + methotrexate; Low SOE | Favors infliximab + methotrexate; Low SOE | Week 48 Favors infliximab + methotrexate; Low SOE | Insufficient | Insufficient | Week 48 Favors infliximab + methotrexate; Low SOE | Insufficient | Week 4 and Week 8 Favors infliximab + methotrexate; Low SOE
Thiopurines vs. placebo 104 weeks | Favors neither; Low SOE | Insufficient | Week 17-38 Favors neither; Low SOE Week 104 Favors 6-MP; Low SOE | Insufficient | Insufficient | Week 16 Favors neither; Low SOE | Week 17 Favors neither; Low SOE Week 104 Favors 6-MP; Low SOE | Week 16 Favors neither; Low SOE^‡^
Thiopurines vs. oral methotrexate 38 weeks | Favors neither; Low SOE | Favors neither; Low SOE | Week 38 Favors neither; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Thiopurines vs. steroids 17 weeks | Favors steroids; Low SOE | Favors steroids; Low SOE | Week 17 Favors steroids; Low SOE | Insufficient | Insufficient | Insufficient | Week 17 Favors steroids; Low SOE | Insufficient
Thiopurines vs. ASA 30 weeks | Favors ASA; Low SOE | Favors neither; Low SOE | Week 17 Favors neither; Low SOE Week 30 Favors 6-MP; Low SOE | Insufficient | Insufficient | Insufficient | Week 17 Favors neither; Low SOE | Insufficient
Thiopurines (IV + oral) vs. thiopurines (oral) 16 weeks | Insufficient | Favors neither; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Thiopurines + steroids vs. steroids 28 weeks | Insufficient | Favors thiopurines + steroids; Low SOE | Week 28 Favors thiopurines + steroids; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Thiopurines + steroids vs. methotrexate (IV, oral) + steroids 26 weeks | Insufficient | Favors neither; Low SOE | Week 26 Favors neither; Low SOE | Insufficient | Insufficient | Insufficient | Week 26 Favors methotrexate + steroids; Low SOE | Insufficient
Methotrexate (oral) vs. placebo 38 weeks | Favors neither; Low SOE | Favors neither; Low SOE | Week 38 Favors neither; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Methotrexate (oral) vs. ASA 30 weeks | Insufficient | Insufficient | Week 30 Favors methotrexate; Moderate SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Methotrexate (IM) + prednisone vs. prednisone 16 weeks | Insufficient | Favors methotrexate; Moderate SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 16 Favors neither; Moderate SOE
Budesonide vs. placebo 16 weeks | ≥9 mg daily Favors budesonide; Moderate SOE <9 mg daily Favors neither; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 8 No difference; Low
6-methyl-prednisolone or prednisone vs. placebo 104 weeks | 6-methyl-prednisolone Favors 6-methylprednisolone; Low SOE Prednisone Favors neither; Low SOE | Favors steroids; Low SOE | Week 104 Favors steroids; Low SOE | Insufficient | Insufficient | Insufficient | Week 17 Favors steroids; Low SOE | Insufficient
Budesonide vs. other steroids 10 weeks | Favors neither; Moderate SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 8 Favors neither; Moderate SOE
Steroids vs. ASA 104 weeks | Favors steroids; Low SOE | Favors steroids; Low SOE | Week 104 Favors steroids; Low SOE | Insufficient | Insufficient | Insufficient | Week 17 Favors neither; Low SOE | Week 2 Favors steroids; High SOE^§^ Week 12 Favors neither; Moderate SOE^§^
6-methyl-prednisolone + sulfasalazine vs. placebo 104 weeks | Favors 6-methyl-prednisolone + sulfasalazine; Low SOE | Favors 6-methyl-prednisolone + sulfasalazine; Low SOE | Week 104 Favors 6-methyl-prednisolone + sulfasalazine; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Steroids + sulfasalazine vs. steroids 104 weeks | Favors neither; Low SOE | Favors neither; Low SOE | Week 104 Favors neither; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Steroids + sulfasalazine vs. sulfasalazine 104 weeks | Favors steroids + sulfasalazine; Low SOE | Favors steroids + sulfasalazine; Low SOE | Week 104 Favors steroids + sulfasalazine; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Mesalamine vs. placebo 17 weeks | Favors neither; Low SOE | ≥3.2 g daily Favors mesalamine; Low SOE <3.2 g daily Favors neither; Low SOE | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Sulfasalazine vs. placebo 104 weeks | Favors neither; Low SOE | Favors sulfasalazine; Low SOE | Week 104 Favors sulfasalazine; Low SOE | Insufficient | Insufficient | Insufficient | Week 17 Favors sulfasalazine; Low SOE | Insufficient

6-MP = 6-mercaptopurine; ASA = aminosalicylates; CP = certolizumab pegol; g = grams; IM = intramuscular; IV = intravenous; mg = milligrams; SC = subcutaneous; SOE = strength of evidence; Steroid = corticosteroids; vs = versus

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

* All other potential comparisons of therapies and outcomes were graded as insufficient because there were no eligible trials. The evidence for the last reported measure is provided for disease activity after 16 weeks, mucosal healing, hospitalizations and surgeries, reduction of steroids, fistula response and patient-reported outcomes.

† Patient-reported outcomes were measured by the Inflammatory Bowel Disease Questionnaire except where indicated by a footnote.

‡ Outcome based upon “feeling better” in 2 trials

§ Used McMaster University Quality of Life scale

### Natalizumab

Four trials randomized 1,523 participants to compare the efficacy of natalizumab with placebo to induce remission among patients with active Crohn's disease at randomization. Three trials32-34 evaluated natalizumab versus placebo, while one trial35 evaluated the combination of natalizumab and infliximab versus infliximab and placebo.

#### Study Design

The trials defined active disease as a CDAI greater than 150 or 220 (Appendix D, Evidence Table 2).32-35 All trials used randomized double-blind designs. The treatment group received 300 mg natalizumab administered intravenously three times at baseline, 4 and 8 weeks in three trials,32,33,35 whereas one trial34 evaluated a single 3 mg/kg baseline dose of intravenous natalizumab. One trial took place at multiple centers in the United States,35 another occurred in two centers in the United Kingdom,34 and the others were multinational.32,33 All trials except one34 reported the starting year of enrollment, with the first year of enrollment ranging from 2001 to 2004.^32,33,35^ The outcome definition was consistent in all trials; CDAI less than 150 was the definition of remission. Inclusion criteria were generally consistent including the exclusion of patients with abscesses and obstructive symptoms consistent with strictures in three trials.32,33,35 Medication exclusions included previous treatment with a TNF-alpha inhibitor within three months32,33 and treatment with methotrexate, cyclosporine, or tacrolimus within 3 to 4 months of enrollment.34 Elevated C-reactive protein ([CRP] > 2.7 mg/L) was an inclusion criteria in one trial32 based on subgroup analysis findings from a previous trial.33 All trials permitted patients to use aminosalicylates, antibiotics, corticosteroids, and thiopurines during the trial if they had been on a stable dose of the medication prior to baseline.

#### Population Characteristics

The populations tended to be similar across trials with the exception of sex, disease location, and concomitant medication use (Appendix D, Evidence Table 3). The proportion of male participants in each trial group ranged from 3 to 63 percent. Three trials reported on race32,34,35 with white patients comprising between 85 and 95 percent of participants. Two trials32,33 reported smoking status, with smokers comprising 19 and 24 percent of participants. Mean age at enrollment was between 34 and 39 years. The mean duration of disease was between 8.5 and 12.5 years. All trials32-35 reported disease location including ileal location (ranging between 15 and 40 percent), ileocolonic location (ranging between 28 and 56 percent), and colonic location (ranging between 22 and 30 percent). One trial34 also reported that 30 percent of patients had perianal disease at baseline. All trials reported baseline CDAI, with mean CDAI ranging from 244 to 330 points. Concurrent medication use during the trial was as follows: aminosalicylates use ranged between 37 and 75 percent,32-35 antibiotic use ranged from 5 to 19 percent,32,33,35 corticosteroids use ranged between 27 and 75 percent, methotrexate use ranged from 3 to 4 percent,33,35 and thiopurine use ranged between 17 and 33 percent.33-35 Two trials32,33 reported prior use of TNF-alpha inhibitors in 38 and 50 percent of participants. In the trial of combination therapy, all patients were unresponsive to infliximab as part of the inclusion criteria.35

#### Key Points

Table 7 summarizes the strength of evidence for the trials evaluating natalizumab in terms of remission induction. We found at least moderate strength of evidence or a clinically meaningful difference for the following comparisons and outcomes:

- Natalizumab was more effective than placebo in inducing a remission at weeks 2 to 4 (pooled relative risk [RR], 1.5; 95% confidence interval [CI], 1.1 to 2.0; placebo rate, 8 to 16 percent). (Strength of evidence [SOE]: Moderate)
- Natalizumab was more effective than placebo in inducing a remission at week 12 (absolute risk difference [RD], 9 to 13 percent; placebo rate, 0 to 31 percent). (SOE: Low)
- Natalizumab (300 mg intravenous every 4 weeks) and placebo did not differ in improving patient-reported outcomes at week 12 (absolute between-group difference in change in mean Inflammatory Bowel Disease Questionnaire [IBDQ] from baseline, 12 points; placebo change in IBDQ, 15 points). (SOE: Moderate)

Table 7 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating natalizumab to induce remission among patients with active Crohn's disease at randomization

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
Comparison | Outcome | Number of Trials (Participants) | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect Strength of Evidence
Natalizumab vs. placebo – wks 2-4 | Disease activity measures | 3 (1444)32-34 | Medium | Consistent | Direct | Precise | Favors natalizumab Pooled RR, 1.5; 95% CI 1.1 to 2.0; placebo rate, 8% to 16% SOE: Moderate
Natalizumab vs. placebo–wk 12 | Disease activity measures | 3 (1444)32-34 | Medium | Consistent | Direct | Imprecise | Favors natalizumab RD range, 9% to 13%; placebo rate, 0% to 31% SOE: Low
Natalizumab vs. placebo–wk 12 | Patient-reported outcomes | 2 (539)32 34 | Medium | Consistent | Direct | Precise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline, 12 pts; placebo change in IBDQ, 15 pts SOE: Moderate
Natalizumab + infliximab vs. infliximab–wks 2 and 10 | Disease activity measures | 1 (79)35 | Low | Unknown (single trial) | Indirect Combination no longer used in clinical practice | Imprecise | Favors neither RD across time points, 7% to 8%; infliximab rate, 7% to 30% SOE: Low
Natalizumab + infliximab vs. infliximab–wk 10 | Patient-reported outcomes | 1 (79)35 | Low | Unknown (single trial) | Indirect Combination no longer used in clinical practice | Imprecise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline, 2 pts; infliximab change in IBDQ, 17 pts SOE: Low

CI = confidence interval; IBDQ = Inflammatory Bowel Disease Questionnaire; pts = points; RD = absolute risk difference; RR = relative risk; SOE = strength of evidence; vs. = versus; wk = week

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

Scores for the Inflammatory Bowel Disease Questionnaire range from 32 to 224, with higher scores indicating better quality of life.36

#### Monotherapy Versus Placebo

Three trials randomized 1,444 participants and compared the efficacy of natalizumab with placebo to induce remission among patients with active Crohn's disease at randomization.32-34

##### Natalizumab Versus Placebo

###### Disease Activity Measures

Table 8 summarizes the efficacy of each treatment in inducing remission for the 2- to 4-week and 12- to 16-week time periods of interest (see also Appendix D, Table 4).

Table 8 Randomized controlled trials comparing the efficacy of natalizumab with placebo or another treatment to induce remission among patients with active Crohn's disease at randomization

Author, Year | Followup (Weeks) | Main Intervention (Dose), n | Comparison (Dose), n | Remission Rate (%) (CDAI<150)
Gordon, 2001^34^ | 2 | Natalizumab (3 mg/kg IV once), 18 | Placebo, 12 | 39% vs. 8%
Gordon, 2001^34^ | 12 | Natalizumab (3 mg/kg IV once), 18 | Placebo, 12 | 11% vs. 0%
Sandborn, 2005^33^ | 2 | Natalizumab (300 mg IV every 4 wks until wk 8), 724 | Placebo, 181 | 14% vs. 10%
Sandborn, 2005^33^ | 12 | Natalizumab (300 mg IV every 4 wks until wk 8), 724 | Placebo, 181 | 40% vs. 31%
Targan, 2007^32^ | 4 | Natalizumab (300 mg IV every 4 wks until wk 8), 259 | Placebo, 250 | 24% vs. 16%^*^
Targan, 2007^32^ | 12 | Natalizumab (300 mg IV every 4 wks until wk 8), 259 | Placebo, 250 | 38% vs. 25%^*^
Sands, 2007^35^ | 2 | Natalizumab (300 mg IV at wks 0, 4, 8) + infliximab (5 mg/kg IV at wk -2 and 6), 52 | Infliximab (5 mg/kg IV at wk -2 and 6), 27 | 15% vs. 7%
Sands, 2007^35^ | 10 | Natalizumab (300 mg IV at wks 0, 4, 8) + infliximab (5 mg/kg IV at wk -2 and 6), 52 | Infliximab (5 mg/kg IV at wk -2 and 6), 27 | 37% vs. 30%

CDAI = Crohn's Disease Activity Index; IV = intravenous; mg = milligrams; mg/kg = milligrams per kilogram; vs. = versus; wk = week

* Trial reported P < 0.01.

When we pooled the week 2 to 4 data, natalizumab was more likely to induce remission compared with placebo (pooled RR, 1.5; 95% CI, 1.1 to 2.0) (Figure 5). The RDs ranged from 4 percent to 31 percent. The small trial was the only trial to meet our clinically meaningful threshold when examined alone.34 The largest trial was the only trial to be statistically significant, but did not meet the clinically meaningful threshold when examined alone.32 There was no statistical heterogeneity across the three trials (I-squared, 0) and no trial significantly influenced results. At week 12, natalizumab was more likely to induce remission than placebo according to our clinically meaningful threshold in two of the three trials,32,34 and one of these trials reported a statistically significant result.32 A meta-analysis was not performed for week 12 because the dose was 3 mg/kg delivered at baseline only in one trial,34 compared with 300 mg delivered 3 times in 8 weeks in the other two trials.32,33

Figure 5 Pooled relative risk of inducing remission as measured by a Crohn's Disease Activity Index less than 150 at weeks 2 to 4 comparing natalizumab with placebo

CI = confidence interval; NAT = natalizumab; RR = relative risk

Note: Boxes indicate individual trial point estimates. The box size denotes the weight of the trial, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each trial. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.

Test for heterogeneity: Q=1.36 with 2 degrees of freedom (p=0.51)

I-squared statistic = 0%

Figure 5 is a forest plot depicting the pooled relative risk, with 95% confidence interval, of inducing remission at weeks two to four comparing natalizumab with placebo. Three trials are included, which are Gordon, 2001, Sandborn, 2005, and Targan 2007. The information presented in the plot shows the relative risk, number of people with events of remission with natalizumab, total number on natalizumab presented in the study, then number of events on placebo and total number on placebo in the study. All trials had relative risk over one, thus suggesting that natalizumab is more effective at inducing remission than placebo. The pooled relative risk is 1.5, with a 95% confidence interval of 1.13 to 1.99.

###### Patient-Reported Outcomes

Two of the trials32,34 reported the IBDQ score for 539 participants. In one trial of 509 participants, mean IBDQ rose from 124 to 151 points in the natalizumab group and from 123 to 138 points in the placebo group at week 12 (P < 0.001); which did not meet our clinically meaningful threshold of a 17-point difference between groups.32 The other trial reported a 19-point change from baseline to week 4 in the natalizumab group, but did not report the corresponding difference in the placebo patients other than to say that the placebo group did not have a statistically significant change over time.34

#### Combination Therapy Versus Monotherapy

##### Natalizumab and Infliximab Versus Infliximab Alone

###### Disease Activity Measures

One trial of 79 participants compared a combination of natalizumab and infliximab with infliximab and placebo among patients who had an elevated CDAI (greater than 150) despite initial infliximab.35 There was not a clinically meaningful added benefit of the combination of intravenous natalizumab with infliximab compared with infliximab alone to induce remission at 2 or 10 weeks. Table 8 summarizes the efficacy of each treatment in inducing remission for the time periods of interest (see also Appendix D, Table 4).

###### Patient-Reported Outcomes

At 10 weeks, the mean IBDQ rose from 138 to 157 points in the group receiving a combination of infliximab and natalizumab, and from 133 to 150 points in the group receiving infliximab and placebo.35 The 2-point difference between groups did not meet the clinically meaningful threshold.

### TNF-Alpha Inhibitors

Twelve trials evaluated the effectiveness of a TNF-alpha inhibitor as monotherapy or in combination with another drug to induce remission. Seven trials compared TNF-alpha inhibitor monotherapy with placebo: two evaluated adalimumab,37,38 four evaluated certolizumab pegol,39-42 and two evaluated infliximab.43,44 One trial compared infliximab with azathioprine.45 Four trials compared TNF-alpha inhibitor combination therapy with another therapy: two trials45,46 compared a combination of infliximab and a thiopurine with thiopurine alone, while one trial45 compared a combination of infliximab and azathioprine with infliximab alone. Schroder et al. studied the combination of infliximab and methotrexate versus infliximab alone.47 Another trial compared the combination of infliximab and azathioprine with corticosteroids.48 One trial compared a TNF-alpha inhibitor as an early treatment prior to using a thiopurine with TNF-alpha inhibitor treatment after the use of a thiopurine and corticosteroids, which is often called a top-down versus step-up approach.48

#### Study Design

All 12 trials were RCTs, although two did not blind investigators or patients (Appendix D, Evidence Table 2).47,48 The design characteristics and inclusion criteria were not homogeneous, with the exception of the trial locations. Ten trials were multinational, one was a multicenter European trial46 and one took place at a single center in Europe.47 Enrollment started between 1995 and 2008. The median time under trial per participant was 12 weeks (range, 4 weeks to 104 weeks). All trials included adults, although one trial enrolled patients as young as 16^48^ rather than 18 years of age. Disease activity inclusion criteria included a minimum CDAI of 150 to 220 and no greater than 450,^37-43,45,46,48^ steroid dependency,46,47 thiopurine resistance or intolerance,47 or at least one active abdominal or perianal fistula.44 Other common disease activity related exclusions included abscess,39,40,42,44-46 symptomatic strictures,37-46,48 and previous surgery within 6 months.37,38,42,45 Remission was defined as a CDAI less than 150, with three trials using an even more stringent definition of remission including a CDAI less than 150 combined with the absence of corticosteroids.45,46,48

Medication inclusion criteria were common. One trial aimed to enroll recently diagnosed patients by restricting the population to people with a disease duration of 4 years or less who had not been treated with corticosteroids, thiopurines, or biologics.48 Another trial allowed prior corticosteroid use but excluded patients with prior thiopurine or biologic use.45 Six trials allowed prior corticosteroid and thiopurine use but excluded previous users of biologics.37,42-44,46,47 Lack of response or dependency on corticosteroids was required in two trials46,47 while failure to respond to thiopurines was required in at least some of the patients in these trials.46,47 Previous response followed by loss of response or intolerance to infliximab was required in one trial.38 Patients who had an adverse reaction or no response to TNF-alpha inhibitor were excluded in two trials.39,40 All trials that did not restrict patients based on the following medications permitted patients to use aminosalicylates, antibiotics, corticosteroids, and thiopurines during the trial if they had been on a stable dose of the medication prior to baseline.

#### Population Characteristics

The trials randomized 2,932 patients (Appendix D, Evidence Table 3). The participants of trials were demographically similar except for the disease duration at randomization, disease location, and use of other medications during the trial. By trial group, males comprised 0^41^ to 63^35^ percent of the participants. Only two trials45,48 commented on race; the percentage of whites ranged from 84 to 99 percent. Smoking was reported in five trials37-39,45,48 and ranged from 31 to 43 percent. Mean age at enrollment ranged from 29 to 40 years. Mean or median duration of disease ranged between 2 weeks and 13.6 years. In terms of disease location, ileal only location ranged between 7 and 68 percent, ileocolonic location between 5 and 68 percent, and colonic location between 9 and 36 percent. All but one trial40 reported baseline CDAI. Mean CDAI ranged from 251 to 330 points. Among trials that did not exclude or require prior use of the medications or randomize patients to the medication, concomitant medication use included the following ranges, as recorded at baseline in at least one group of a trial: aminosalicylate use between 0^41^ and 75^34^ percent, antibiotic use between 5^32^ and 19^44^ percent, budesonide or corticosteroid use between 11^45^ and 88^47^ percent, and methotrexate or thiopurine between 0^41^ and 56^38^ percent.

#### Key Points

Table 9 summarizes the strength of evidence for the trials evaluating TNF-alpha inhibitors to induce remission. We found at least moderate strength of evidence or a clinically meaningful difference for the following areas:

- TNF-alpha inhibitors (infliximab, adalimumab, and certolizumab pegol) were more effective than placebo in inducing a remission at week 2 (pooled RR, 1.8; 95% CI, 1.4 to 2.4; placebo rate, 4 to 16 percent). (SOE: Moderate)
- One dose of adalimumab (at 160 mg) was more effective than placebo in inducing a remission at week 2 (absolute RD, 10 to 15 percent; placebo rate, 6 to 14 percent). (SOE: High)
- One dose of adalimumab (at 80 mg or less) did not differ from placebo in inducing a remission at week 2 (absolute RD, 0 to 6 percent; placebo rate, 14 percent). (SOE: High)
- Adalimumab and placebo did not differ in improving patient-reported outcomes at week 4 (absolute between-group difference in change in mean IBDQ from baseline, 2 to 15 points; placebo change in IBDQ, 15 points). (SOE: High)
- Certolizumab pegol was more effective than placebo in inducing a remission at week 26 (absolute RD, 11 percent; placebo rate, 18 percent). (SOE: Low)
- One dose of infliximab was more effective than placebo in inducing a remission at week 2 (absolute RD, 16 to 34 percent; placebo rate, 4 percent). (SOE: Moderate)
- One dose of infliximab was more effective than placebo in inducing a remission at week 12 (absolute RD, 10 to 22 percent; placebo rate, 8 percent). (SOE: Low)
- Infliximab was more effective than placebo in achieving mucosal healing at week 4 (absolute between-group difference in the change from baseline in Crohn's Disease Endoscopic Index of Severity [CDEIS] score, 7.7; placebo difference, 0.9). (SOE: Low)
- Infliximab was more effective than placebo in healing fistulas at week 6 in patients with actively draining fistulas (absolute RD in fistula closure, 25 to 42 percent; placebo rate, 13 percent). (SOE: High)
- Infliximab was more effective than placebo in improving patient-reported outcomes at week 4 (absolute between-group difference in change in mean IBDQ from baseline, 31 points; placebo change in IBDQ, 5 points). (SOE: Moderate)
- Infliximab (5 mg/kg induction and maintenance) was more effective than azathioprine (2.5 mg/kg/day) in inducing a steroid-free remission at weeks 10 and 26 (absolute RD across time points, 13 to 14 percent; azathioprine rate, 24 to 30 percent). (SOE: Moderate)
- Infliximab (5 mg/kg induction and maintenance) was more effective than azathioprine (2.5 mg/kg daily) in achieving mucosal healing at week 26 (absolute RD in percentage of patients who achieved absence of mucosal ulcers, 13 percent; azathioprine rate, 17 percent). (SOE: Low)
- Infliximab (5 mg/kg induction and maintenance) and azathioprine (2.5 mg/kg/day) did not differ in improving patient-reported outcomes at 26 weeks (absolute between-group difference in change in mean IBDQ from baseline, 9 points; azathioprine change in IBDQ, 31 points). (SOE: Moderate)
- A combination of infliximab (5 mg/kg induction and maintenance) and azathioprine (2.5 mg/kg/day) was more effective than infliximab (5 mg/kg induction and maintenance) alone in inducing a steroid-free remission at weeks 10 and 26 (absolute RD across time points, 10 to 13 percent; infliximab alone rate, 37 to 44 percent). (SOE: Moderate)
- A combination of infliximab (5 mg/kg induction and maintenance) and azathioprine (2.5 mg/kg daily) was more effective than infliximab (5 mg/kg induction and maintenance) and placebo in achieving mucosal healing at week 26 (absolute RD in percentage of patients who achieved absence of mucosal ulcers, 14 percent; infliximab and placebo rate, 30 percent). (SOE: Low)
- The combination of infliximab (5 mg/kg induction and maintenance) and azathioprine (2.5 mg/kg/day) and the combination of infliximab (5 mg/kg induction and maintenance) and placebo did not differ in improving patient-reported outcomes at 26 weeks (absolute between-group difference in change in mean IBDQ from baseline, 5 points; infliximab change in IBDQ, 40 points). (SOE: Moderate)
- A combination of infliximab (5 mg/kg induction and maintenance) and a thiopurine (azathioprine or 6-mercaptopurine) was more effective than a thiopurine alone in inducing a steroid-free remission at weeks 10 to 12 and weeks 24 to 26 (absolute RD across time points, 12 to 30 percent; azathioprine rate, 24 to 44 percent). (SOE: Moderate)
- A combination of infliximab (5 mg/kg induction and maintenance) and azathioprine (2.5 mg/kg daily) was more effective than azathioprine (2.5 mg/kg daily) and placebo in achieving mucosal healing at week 26 (absolute RD in percentage of patients who achieved absence of mucosal ulcers, 27 percent; azathioprine and placebo rate, 17 percent). (SOE: Low)
- The combination of infliximab (5 mg/kg induction and maintenance) and azathioprine (2.5 mg/kg/day) and the combination of azathioprine (2.5 mg/kg/day) and placebo did not differ in improving patient-reported outcomes at 26 weeks (absolute between-group difference in change in mean IBDQ from baseline, 14 points; azathioprine change in IBDQ, 31 points). (SOE: Moderate)
- A combination of infliximab (5 mg/kg induction only) and azathioprine (2-2.5 mg/kg/day) was more effective than corticosteroids alone in achieving mucosal healing at week 104 (absolute RD in percentage of patients with no ulcers, 43 percent; corticosteroid rate, 30 percent). (SOE: Low)
- A combination of infliximab (5 mg/kg induction only) and azathioprine (2-2.5 mg/kg/day) was more effective than corticosteroids alone in improving patient-reported outcomes at week 10 (absolute between-group difference in change in mean IBDQ from baseline, 22 points; corticosteroid change in IBDQ, 37 points). (SOE: Low)
- A combination of infliximab (5 mg/kg at weeks 0 and 2) and methotrexate (intravenous weekly to week 5, then oral) was more effective than infliximab (5 mg/kg at weeks 0 and 2) alone in inducing a remission at weeks 2, 12, and 48 (absolute RD across time points, 17 to 39 percent; infliximab rate, 25 to 50 percent). (SOE: Low)
- A combination of infliximab (5 mg/kg at weeks 0 and 2) and methotrexate (intravenous weekly to week 5, then oral) was more effective than infliximab (5 mg/kg at weeks 0 and 2) alone in being able to discontinue steroids (reduction in prednisolone dose from baseline, 17 mg vs. 6 mg). (SOE: Low)
- A combination of infliximab (5 mg/kg at weeks 0 and 2) and methotrexate (intravenous weekly to week 5, then oral) was more effective than infliximab (5 mg/kg at weeks 0 and 2) alone in improving patient-reported outcomes at 4 and 8 weeks (absolute between-group difference in change in mean IBDQ from baseline, 22 points; infliximab alone change in IBDQ, 28 points). (SOE: Low)

Table 9 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating TNF-alpha inhibitors to induce remission among patients with active Crohn's disease at randomization

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
Comparison | Outcome | Number of Trials (Participants) | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect Strength of Evidence
TNF vs. placebo–wk 2 | Disease activity measures | 7 (2208)37-43 | Medium | Consistent | Direct | Precise | Favors TNF Pooled RR, 1.8; 95% CI, 1.4 to 2.4; placebo rate, 4 to 16% SOE: Moderate
Adalimumab vs. placebo (160 mg × 1) –wk 2 | Disease activity measures | 2 (475)37 38 | Low | Consistent | Direct | Precise | Favors adalimumab RD, 10% to 15%; placebo rate, 6% to 14% SOE: High
Adalimumab vs. placebo (≦ 80 mg × 1) –wk 2 | Disease activity measures | 2 (223)37 | Low | Unknown (single trial) | Direct | Imprecise | Favors neither RD, 0% to 6%; placebo rate, 14% SOE: Moderate
Adalimumab vs. placebo–wk 4 | Fistula response | 1 (32)37 | High | Unknown (single trial) | Direct | Imprecise | Favors neither RD, -17% to 58%; placebo rate, 17% SOE: Low
Adalimumab vs. placebo–wk 4 | Patient-reported outcomes | 2 (624)37 38 | Low | Consistent | Direct | Precise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline, 2 to 15 pts; placebo change in IBDQ, 15 pts SOE: High
Certolizumab pegol vs. placebo–wk 2, 12-16 | Disease activity measures | 4 (1478)39-42 | Medium | Inconsistent | Indirect IV formulation not presently approved41 | Imprecise | Favors neither RD, -19% to 31%; placebo rate, 8% to 32% SOE: Low
Certolizumab pegol vs. placebo–wk 26 | Disease activity measures | 1 (331)39 | High | Unknown (single trial) | Direct | Precise | Favors certolizumab pegol RD, 11%; placebo rate, 18% SOE: Low
Certolizumab pegol vs. placebo–wk 26 | Fistula response | 1 (107)39 | High | Unknown (single trial) | Direct | Imprecise | Favors neither RD, -1%; placebo rate, 31% SOE: Low
Certolizumab pegol vs. placebo–wks 12, 26 | Patient-reported outcomes | 2 (954)39 40 | High | Consistent | Indirect Single dose for induction not presently used in practice40 | Precise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline across time points, 5 to 11 pts; placebo change in IBDQ, 18 to 21 pts SOE: Low
Infliximab vs. placebo–wk 2 | Disease activity measures | 1 (106)43 | Medium | Unknown (single trial) | Direct | Precise | Favors infliximab RD, 16% to 34%; placebo rate, 4% SOE: Moderate
Infliximab vs. placebo–wk 12 | Disease activity measures | 1 (106)43 | High | Unknown (single trial) | Indirect Single dose for induction not presently used in practice | Imprecise | Favors infliximab RD, 10% to 22%; placebo rate, 8% SOE: Low
Infliximab vs. placebo–wk 4 | Mucosal healing | 1 (30)49 | High | Unknown (single trial) | Direct | Precise | Favors infliximab Absolute between-group difference in the change from baseline in CDEIS, 7.7; placebo difference, 0.9 SOE: Low
Infliximab vs. placebo–wk 6 | Fistula response | 1 (94)44 | Low | Unknown (single trial) | Direct | Precise | Favors infliximab RD, 25% to 42%; placebo rate, 13% SOE: High
Infliximab vs. placebo–wk 4 | Patient-reported outcomes | 1 (83)43 | Medium | Unknown (single trial) | Direct | Precise | Favors infliximab Absolute between-group difference in change in mean IBDQ from baseline, 31 pts; placebo change in IBDQ, 5 pts SOE: Moderate
Infliximab vs. azathioprine–wks 10, 26 | Disease activity measures | 1 (339)45 | Medium | Unknown (single trial) | Direct | Precise | Favors infliximab RD across time points, 13% to 14%; azathioprine rate, 24% to 30% SOE: Moderate
Infliximab vs. azathioprine–wk 26 | Mucosal healing | 1 (202)45 | High | Unknown (single trial) | Direct | Precise | Favors infliximab RD in percentage of patients who achieved absence of mucosal ulcers, 13%; azathioprine rate, 17% SOE: Low
Infliximab vs. azathioprine–wk 26 | Patient-reported outcomes | 1 (339)45 | Medium | Unknown (single trial) | Direct | Precise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline, 9 pts; azathioprine change in IBDQ, 31 pts SOE: Moderate
Infliximab + azathioprine vs. infliximab–wks 10, 26 | Disease activity measures | 1 (338)45 | Medium | Unknown (single trial) | Direct | Precise | Favors infliximab + azathioprine RD across time points, 10% to 13%; infliximab alone rate, 37% to 44% SOE: Moderate
Infliximab + azathioprine vs. infliximab–wk 26 | Mucosal healing | 1 (200)45 | High | Unknown (single trial) | Direct | Precise | Favors infliximab + azathioprine RD in percentage of patients who achieved absence of mucosal ulcers, 14%; infliximab rate, 30% SOE: Low
Infliximab + azathioprine vs. infliximab–wk 26 | Patient-reported outcomes | 1 (338)45 | Medium | Unknown (single trial) | Direct | Precise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline, 5 pts; infliximab change in IBDQ, 40 pts SOE: Moderate
Infliximab + azathioprine vs. azathioprine–wks 10-12, 24-26 | Disease activity measures | 2 (393)45 46 | Medium | Consistent | Direct | Precise | Favors infliximab + azathioprine RD across time points, 12% to 30%; azathioprine rate, 24% to 44% SOE: Moderate
Infliximab + azathioprine vs. azathioprine–wk 26 | Mucosal healing | 1 (216)45 | High | Unknown (single trial) | Direct | Precise | Favors infliximab + azathioprine RD in percentage of patients who achieved absence of mucosal ulcers, 27%; azathioprine rate, 17% SOE: Low
Infliximab + azathioprine vs. azathioprine–wk 26 | Patient-reported outcomes | 1 (508)45 | Medium | Unknown (single trial) | Direct | Precise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline, 14 pts; azathioprine change in IBDQ, 31 pts SOE: Moderate
Infliximab + azathioprine vs. steroids–wk 104 | Disease activity measures | 1 (129)48 | High | Unknown (single trial) | Indirect Single dose for induction not presently used in practice | Imprecise | Favors neither RD, 6%; corticosteroid rate, 49% SOE: Low
Infliximab+ azathioprine vs. steroids–wk 104 | Mucosal healing | 1 (49)48 | High | Unknown (single trial) | Indirect Single dose for induction not presently used in practice | Precise | Favors infliximab + azathioprine RD in percentage of patients with no ulcers, 43%; steroid rate, 30% SOE: Low
Infliximab + azathioprine vs. steroids–wk 10 | Patient-reported outcomes | 1 (129)48 | High | Unknown (single trial) | Indirect Single dose for induction not presently used in practice | Precise | Favors infliximab + azathioprine Absolute between-group difference in change in mean IBDQ from baseline, 22 pts; steroids change in IBDQ, 37 pts SOE: Low
Infliximab + methotrexate vs. infliximab–wks 2, 12, 48 | Disease activity measures | 1 (19)47 | High | Unknown (single trial) | Direct | Imprecise | Favors infliximab + methotrexate RD across time points, 17% to 39%; infliximab rate, 25% to 50% SOE: Low
Infliximab + methotrexate vs. infliximab–wk 48 | Reduction of steroids | 1 (13)47 | High | Unknown (single trial) | Direct | Imprecise | Favors infliximab + methotrexate Reduction in prednisolone dose from baseline, 17 mg vs. 6 mg SOE: Low
Infliximab + methotrexate vs. infliximab–wk 4 and 8 | Patient-reported outcomes | 1 (19)47 | High | Unknown (single trial) | Direct | Imprecise | Favors infliximab + methotrexate Absolute between-group difference in change in mean IBDQ from baseline, 22 pts; infliximab change in IBDQ, 28 pts SOE: Low

CDEIS = Crohn's Disease Endoscopic Index of Severity; CI = confidence interval; IBDQ = Inflammatory Bowel Disease Questionnaire; IV = intravenous; pts = points; RD = absolute risk difference; RR = relative risk; SOE = strength of evidence; TNF = tumor necrosis factor-alpha inhibitor; TPMT = thiopurine methyltransferase; vs. = versus; wk = week

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

Scores for the Inflammatory Bowel Disease Questionnaire (IBDQ) range from 32 to 224, with higher scores indicating better quality of life.36 Scores for the Crohn's Disease Endoscopic Index of Severity (CDEIS) range from 0 to 44, with higher scores indicating more severe disease.

#### Monotherapy Versus Placebo

##### TNF-Alpha Inhibitor Versus Placebo

###### Disease Activity Measures

Seven RCTs compared a TNF-alpha inhibitor versus placebo and reported the percent of participants who achieved a CDAI less than 150 as the indicator of remission.37-43 Combining the week 2 results for infliximab, adalimumab, and certolizumab pegol in a meta-analysis, TNF-alpha inhibitor was favored over placebo (RR, 1.8; 95% CI, 1.4 to 2.4; P < 0.001) (Table 10 and Figure 6). The RD ranged from 0 to 34 percent. No one trial significantly influenced results and there was not substantial statistical heterogeneity (I-squared, 19 percent). Previous use or response to a TNF-alpha inhibitor may explain the wide range of observed RD and this possibility was examined in separate meta-analyses. Among the four trials that allowed prior TNF-alpha inhibitor use, the RR was 2.1 (95% CI, 1.5 to 3.0) (Appendix E). An elevated RR of 1.5 (95% CI, 1.1 to 2.2; P=0.03) was observed in the three trials that excluded patients who previously received TNF-alpha inhibitor, and the finding was statistically significant (Appendix E).37,42,43 The trial38 that included only patients with a previous response to infliximab, found that 21 percent of adalimumab patients were in remission at week 2 compared with 6 percent of controls (RR, 3.6; 95% CI, 1.8 to 6.9) (Figure 6).

Table 10 Randomized controlled trials comparing the efficacy of TNF-alpha inhibitor therapy with placebo or another treatment to induce remission at week 2 among patients with active Crohn's disease at randomization

Author, Year | Main Intervention (Dose), n | Comparison (Dose), n | Remission Rate (%) (CDAI<150)
Hanauer, 2006^37^ | Adalimumab (40 mg sc at week 0), 74 | Placebo, 74 | 14% vs. 14%
Hanauer, 2006^37^ | Adalimumab (80 mg sc at week 0), 75 | Placebo, 74 | 20% vs. 14%
Hanauer, 2006^37^ | Adalimumab (160 mg sc at week 0), 76 | Placebo, 74 | 24% vs. 14%
Sandborn, 2007^38^ | Adalimumab (160 mg sc at week 0), 159 | Placebo, 166 | 21% vs. 6%^*^
Winter, 2004^41^ | Certolizumab pegol (5 mg/kg IV once), 25 | Placebo, 25 | 35% vs. 16%
Winter, 2004^41^ | Certolizumab pegol (10 mg/kg IV once), 17 | Placebo, 25 | 47% vs. 16%^*^
Winter, 2004^41^ | Certolizumab pegol (20 mg/kg IV once), 23 | Placebo, 25 | 20% vs. 16%
Schreiber, 2005^40^ | Certolizumab pegol (100 mg sc at week 0), 74 | Placebo, 73 | 18% vs. 8%
Schreiber, 2005^40^ | Certolizumab pegol (200 mg sc at week 0), 72 | Placebo, 73 | 10% vs. 8%
Schreiber, 2005^40^ | Certolizumab pegol (400 mg sc at week 0), 72 | Placebo, 73 | 18% vs. 8%
Sandborn, 2007^39^ | Certolizumab pegol (400 mg sc at week 0), 331 | Placebo, 328 | 13% vs. 8%
Sandborn, 2011^42^ | Certolizumab pegol (400 mg sc at week 0), 223 | Placebo, 215 | 23% vs. 16%^*^
Targan, 1997^43^ | Infliximab (5 mg/kg IV once), 26 | Placebo, 24 | 38% vs. 4%
Targan, 1997^43^ | Infliximab (10 mg/kg IV once), 23 | Placebo, 24 | 20% vs. 4%
Targan, 1997^43^ | Infliximab (20 mg/kg IV once), 28 | Placebo, 24 | 20% vs. 4%
Schroder, 2006^47^ | Infliximab (5 mg/kg IV at week 0) + methotrexate (20 mg IV weekly for weeks 0-1), 11 | Infliximab (5 mg/kg IV week 0), 8 | 64% vs. 25%

CDAI = Crohn's Disease Activity Index; IV = intravenous infusion; mg = milligrams; mg/kg = milligrams per kilogram; sc = subcutaneous injections; vs. = versus

* Trial reported P < 0.05

Figure 6 Pooled relative risk of inducing remission^*^ * In all trials, remission was defined as a Crohn's Disease Activity Index less than 150. Boxes indicate individual trial point estimates. The box size denotes the weight of the trial, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each trial. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate. at week 2 comparing a TNF-alpha inhibitor with placebo

ADA = adalimumab; CI = confidence interval; CP = certolizumab pegol; IFX = infliximab; RR = relative risk; TNF-a = tumor necrosis factor-alpha inhibitor

Test for heterogeneity: Q=7.41 with 6 degrees of freedom (p=0.29)

I-squared statistic = 19%

Figure 6 is a forest plot type diagram depicting the pooled relative risk, with 95% confidence interval, of inducing remission at week 2 comparing a TNF-alpha inhibitor with placebo. Seven trials are included, which are Hanauer 2006 with adalimumab, Sandborn 2007 with adalimumab, Schreiber, 2005 with certolizumab pegol, Sandborn 2007 with certolizumab pegol, Winter 2004 with certolizumab pegol, Sandborn 2011 with certolizumab pegol, and Targan 1997 with infliximab. The information presented in the plot shows the relative risk, number of people with events of remission with the TNF-alpha inhibitor, total number on a TNF-alpha inhibitor presented in the study, then number of events on placebo and total number on placebo in the study. All trials had relative risk over one, thus suggesting that a TNF-alpha inhibitor is more effective at inducing remission than placebo. The pooled relative risk is 1.8, with a 95% confidence interval of 1.4 to 2.4.

The adalimumab trials did not report results beyond week 4. For the 12 to 16 week analysis, only certolizumab pegol and infliximab had available data (Table 11). The initial remission was not sustained at 12 weeks in these trials. Placebo met the threshold for having a clinically meaningful difference compared with certolizumab pegol in one trial,41 although the trial did not report that the difference was statistically significant. Infliximab met the standard for a clinically meaningful difference compared with placebo, but that finding was also not reported as statistically significant.43 One reason for the lack of sustained remission from that observed at 2 weeks may be that infliximab and certolizumab pegol were given only at baseline in three of the four trials. However, the single trial that gave doses of certolizumab pegol beyond baseline did not find a clinically meaningful difference between certolizumab pegol and placebo at week 12 (RD, 6 percent), but certolizumab pegol had a 11 percent higher remission rate at week 26 (Table 12).39

Table 11 Randomized controlled trials comparing the efficacy of TNF-alpha inhibitor therapy with placebo or another treatment to induce remission at weeks 12 to 16 (or closest time point) among patients with active Crohn's disease at randomization

Author, Year | Followup (Weeks) | Main Intervention (Dose), n | Comparison (Dose), n | Remission Rate (%) (CDAI<150)
Winter, 2004^41^ | 12 | Certolizumab pegol (5 mg/kg IV once), 25 | Placebo, 25 | 32% vs. 32%
Winter, 2004^41^ | 12 | Certolizumab pegol (10 mg/kg IV once), 17 | Placebo, 25 | 24% vs. 32%
Winter, 2004^41^ | 12 | Certolizumab pegol (20 mg/kg IV once), 23 | Placebo, 25 | 13% vs. 32%
Schreiber, 2005^40^ | 12 | Certolizumab pegol (100 mg sc once), 74 | Placebo, 73 | 27% vs. 23%
Schreiber, 2005^40^ | 12 | Certolizumab pegol (200 mg sc once), 72 | Placebo, 73 | 19% vs. 23%
Schreiber, 2005^40^ | 12 | Certolizumab pegol (400 mg sc once), 72 | Placebo, 73 | 26% vs. 23%
Sandborn, 2007^39^ | 16 | Certolizumab pegol (400 mg sc at 0, 2, 4 weeks, then every 4 weeks), 331 | Placebo, 328 | 26% vs. 20%
Targan, 1997^43^ | 12 | Infliximab (5 mg/kg IV once), 27 | Placebo, 24 | 30% vs. 8%
Targan, 1997^43^ | 12 | Infliximab (10 mg/kg IV once), 27 | Placebo, 24 | 18% vs. 8%
Targan, 1997^43^ | 12 | Infliximab (20 mg/kg IV once), 28 | Placebo, 24 | 25% vs. 8%
Colombel, 2010^45^ | 10 | Infliximab (5 mg/kg IV at 0, 2, and 6 weeks, then every 8 weeks), 169 | Azathioprine (2.5 mg/kg orally daily), 170 | 37% vs. 24%^*,†^
Colombel, 2010^45^ | 10 | Infliximab (5 mg/kg IV at 0, 2, and 6 weeks, then every 8 weeks) + azathioprine (2.5 mg/kg orally daily),169 | Azathioprine (2.5 mg/kg orally daily), 170 | 47% vs. 24%^*,†^
Lemann, 2006^46^ | 12 | Infliximab (5 mg/kg IV at 0, 2, and 6 weeks) + azathioprine (2-3 mg/kg/day orally) or 6-mercaptopurine (1-1.5 mg/kg/day orally), 25 | Azathioprine (2-3 mg/kg/day orally) or 6-mercaptopurine (1-1.5 mg/kg/day orally), 29 | 64% vs. 34%^*,†^
D'Haens, 2008^48^ | 14 | Infliximab (5 mg/kg IV at 0, 2, 6 weeks) + azathioprine (2–2.5 mg/kg orally daily), 65 | Methylprednisolone (32 mg orally daily with taper), or budesonide (9 mg orally daily with taper), 64 | 65% vs. 32%^*,†^
Colombel, 2010^45^ | 10 | Infliximab (5 mg/kg IV at 0, 2, and 6 weeks, then every 8 weeks) + azathioprine (2.5 mg/kg orally daily), 169 | Infliximab (5 mg/kg IV at 0, 2, and 6 weeks), 169 | 47% vs. 37%^*^
Schroder, 2006^47^ | 12 | Infliximab (5 mg/kg IV at 0 and 2 weeks) + methotrexate (20 mg IV weekly for weeks 0-5; then 20 mg orally weekly), 11 | Infliximab (5 mg/kg once), 8 | 82% vs. 50%

CDAI = Crohn's Disease Activity Index; IV = intravenous infusion; mg = milligrams; mg/kg = milligrams per kilogram; NR = not reported; pt = point; sc = subcutaneous injections; vs. = versus

* Steroid-free remission

† Trial reported P < 0.05

Table 12 Randomized controlled trials comparing the efficacy of TNF-alpha inhibitor therapy with placebo or another treatment to induce remission (last reported time point) among patients with active Crohn's disease at randomization

Author, Year | Followup (weeks) | Main Intervention (Dose), n | Comparison (Dose), n | Remission Rate (%) (CDAI<150)
Sandborn, 2007^39^ | 26 | Certolizumab pegol (400 mg sc at 0, 2, 4 wks, then every 4 wks), 331 | Placebo, 328 | 29% vs. 18%^*^
Colombel, 2010^45^ | 26 | Infliximab (5 mg/kg IV at 0, 2, 6 wks, then every 8 wks), 169 | Azathioprine (2.5 mg/kg orally daily), 170 | 44% vs. 30%^*,†^
Colombel, 2010^45^ | 26 | Infliximab (5 mg/kg IV at 0, 2, 6 wks, then every 8 wks) + azathioprine (2.5 mg/kg orally daily),169 | Azathioprine (2.5 mg/kg orally daily), 170 | 57% vs. 30%^*,†^
Lemann, 2006^46^ | 24 | Infliximab (5 mg/kg IV at 0, 2, 6 wks) + azathioprine (2-3 mg/kg/day orally) or 6-mercaptopurine (1-1.5 mg/kg/day orally), 24 | Azathioprine (2-3 mg/kg/day orally) or 6-mercaptopurine (1-1.5 mg/kg/day orally), 27 | 50% vs. 26%^†^
D'Haens, 2008^48^ | 104 | Infliximab (5 mg/kg IV at 0, 2, 6 wks) + azathioprine (2–2.5 mg/kg orally daily), 65 | Methylprednisolone (32 mg orally daily with taper), or budesonide (9 mg orally daily with taper), 64 | 55% vs. 49%
Colombel, 2010^45^ | 26 | Infliximab (5mg/kg IV at 0, 2, 6 wks, then every 8 wks) + azathioprine (2.5 mg/kg orally daily), 169 | Infliximab (5 mg/kg IV at 0, 2, 6 wks, then every 8 wks), 169 | 57% vs. 44%^*,†^
Schroder, 2006^47^ | 48 | Infliximab (5 mg/kg IV at 0, 2 wks) + methotrexate (20 mg IV weekly for weeks 0-5; then 20 mg orally weekly), 11 | Infliximab (5 mg/kg IV once), 8 | 45% vs. 25%

CDAI = Crohn's Disease Activity Index; IV = intravenous infusion; mg = milligrams; mg/kg = milligrams per kilogram; NR = not reported; pt = point; sc = subcutaneous injections; vs. = versus; wk = week

* Trial reported P < 0.05

† Steroid-free remission

###### Mucosal Healing

The infliximab trial43 reported on mucosal healing for a subset of 30 participants.49 The 4-week Crohn's Disease Endoscopic Index of Severity (CDEIS), which is measured on a scale of 0 to 44 with higher scores indicating more severe disease, decreased in all doses of infliximab compared with baseline indicating less severe disease (mean change of 7.7 compared with 13.0 at baseline; within group P < 0.001). The mean change in CDEIS for placebo was 0.9 compared with an 8.4 score at baseline (within group P=NS). Infliximab was favored over placebo according to the clinically meaningful threshold of a 5-point difference between groups. The trial did not report the statistical significance of the change from baseline in infliximab compared with placebo.

###### Fistula Response

Two trials reported on subsets of participants with draining fistulas at baseline37,39 and one trial required a draining fistula at baseline for inclusion with fistula healing the primary goal of the trial.44 The trials considered three different comparisons: adalimumab at three different doses versus placebo at 4 weeks (N=32),37 certolizumab pegol (400 mg subcutaneous every 4 weeks) versus placebo at 26 weeks (N=107),39 and infliximab (5 mg/kg or 10 mg/kg) versus placebo administered at 0, 2, and 6 weeks (N=94).44

We did not find a class effect of TNF-alpha inhibitor on fistula response. Three of 26 adalimumab patients had closure of all draining fistula at two consecutive visits at week 4 compared with one of six placebo patients.37 Similarly, no difference was seen in complete fistula closure for certolizumab pegol versus placebo at week 26 (30 versus 31 percent).39 However, infliximab decreased the number of draining fistulas over two consecutive visits according to the clinically meaningful and statistically significant thresholds for each dose of infliximab: with 55 percent of those receiving 5 mg/kg, 38 percent of 10 mg/kg having no draining fistulas compared with a 13 percent fistula closure rate by 18 weeks in placebo (P=0.001 and P=0.04 compared with placebo).44 The infliximab trial also reported the Perianal Disease Activity Index (PDAI), which is measured on a scale of 0 to 20 with higher scores indicating more severe disease. Although changes in the PDAI from baseline were not compared between infliximab and placebo, there was a 4- to 5-point decrease in PDAI score at 18 weeks in the infliximab groups compared with a 2-point decrease in placebo.44

###### Patient-Reported Outcomes

Six trials with 1,675 total participants reported the IBDQ.37-40,42,43 We did not see a class effect of TNF-alpha inhibitor on the IBDQ. Adalimumab and certolizumab pegol did not lead to increases in the IBDQ that met our clinically meaningful criterion of a 17-point between group change in the score from baseline. Two trials compared adalimumab with placebo and did not meet the clinically meaningful threshold compared with placebo at week 4.^37,38^ Three trials compared certolizumab pegol with placebo; certolizumab pegol did not meet the clinically meaningful threshold compared with placebo at week 6, 12, or 26.^39,40,42^ Infliximab was both clinically and statistically superior to placebo at week 4.^43^ Mean IBDQ rose from 118 to 154 in the infliximab groups and from 128 to 133 in the placebo group (P=0.001). The week 12 results were not reported for all randomized patients in the infliximab trial.

#### Monotherapy Versus Monotherapy

##### Infliximab Versus Azathioprine

###### Disease Activity Measures

One trial, of 338 patients with relatively short median disease duration of 2 years who had not received thiopurines or TNF-alpha inhibitors,45 found infliximab to be clinically and statistically superior to azathioprine for the induction of steroid-free remission at weeks 10 and 26 (Tables 10 and 11). The finding at 26 weeks is particularly meaningful because a response to azathioprine is not expected until at least 12 weeks based on its pharmacokinetics.50 The exclusion of homozygous mutant and heterozygous thiopurine methyltransferase phenotypes is also unlikely to explain the difference between infliximab and azathioprine at 26 weeks. Notably, patients were followed out to 52 weeks, but starting at week 30 patients were given the choice of continuing with the assigned therapy; this extension period did not meet our inclusion criteria.

###### Mucosal Healing

At baseline, 63 percent of patients (n=214) had mucosal lesions.45 At 26 weeks, 30 percent (28 out of 93) of the infliximab group had no mucosal ulcers compared with 17 percent (18 out of 109) of the azathioprine group (P=0.02). This finding is clinically meaningful and statistically significant. The patients who did not have ulcerations were excluded as well as the 12 patients with an unclear video or no colonoscopy at 26 weeks.

###### Patient-Reported Outcomes

The change in IBDQ score from baseline was not different for infliximab and azathioprine at 2, 10, or 26 weeks according to our between-group difference threshold of a 17-point change from baseline between groups (Appendix D, Evidence Table 4).

#### Combination Therapy Versus Monotherapy

##### Infliximab and Azathioprine Versus Infliximab Alone

###### Disease Activity Measures

One trial of 338 patients45 found a combination of infliximab and azathioprine was clinically superior to infliximab and placebo at weeks 10 and 26, although the results were only statistically significant at week 26. This is consistent with azathioprine generally taking 12 weeks to have an effect based on its pharmacokinetics (Tables 10 and 11).

###### Mucosal Healing

In the above trial,45 210 patients for this comparison had mucosal lesions. The trial evaluated these patients again after the primary endpoint. Rates of mucosal healing (no ulcers) at 26 weeks were 47 out of 107 (44 percent) for the combination of infliximab and azathioprine and 28 out of 93 (30 percent) for infliximab and placebo (P=0.06). Ten patients did not have a colonoscopy at week 26 or the quality of the video was insufficient for inclusion.

###### Patient-Reported Outcomes

The absolute difference in mean IBDQ change from baseline at week 26 was not clinically significant.45

##### Infliximab and Thiopurine Versus Thiopurine Alone

###### Disease Activity Measures

Two trials randomized 393 patients to a combination of infliximab and a thiopurine or thiopurine alone (with a placebo for infliximab).45,46 In the smaller study46 patients were divided into two strata – thiopurine naïve patients and those that had previously failed thiopurines. The thiopurine naïve stratum included a mix of patients with CDAI less than and greater than 150, while all patients in the thiopurine failure stratum had a CDAI greater than 150. By contrast, the larger study45 excluded any prior thiopurine use. The larger trial of 339 patients45 found the combination of infliximab and azathioprine clinically and statistically superior to azathioprine for the induction of steroid-free remission at weeks 10 and 26 (Tables 10 and 11). Among the thiopurine failure stratum of the smaller trial,46 the combination of infliximab and a thiopurine (azathioprine or 6-mercaptopurine) was clinically and statistically significant compared with a thiopurine alone at 12 weeks, but was clinically meaningful but not statistically significant at 24 weeks. Among all randomized patients in this trial, the findings were clinically meaningful and statistically significant at both time points.46

###### Mucosal Healing

Both trials reported on mucosal healing. In the larger trial,45 226 patients (67 percent) for this comparison had mucosal lesions at baseline. At 26 weeks, 47 out of 107 (44 percent) combination of infliximab and azathioprine patients had no ulcers compared with 18 out of 109 (17 percent) for azathioprine patients (P < 0.001). Of the 20 patients in the other trial46 who underwent colonoscopy at baseline and at 24 weeks, the number of patients with no ulcers at week 24 was neither clinically nor statistically significantly different between the two groups (27 versus 33 percent).

###### Patient-Reported Outcomes

The absolute difference in mean IBDQ change from baseline was not clinically significant at week 2, 10, or 26.^45^

##### Infliximab and Thiopurine Versus Corticosteroids in a Top-Down Versus Step-Up Trial

###### Disease Activity Measures

One trial48 sought to compare top-down therapy with step-up therapy. At entry, patients were newly diagnosed, and were naïve to corticosteroids, thiopurines, and TNF-alpha inhibitor therapy. The trial randomized patients to receive either the combination of infliximab (given at 0, 2, and 6 weeks) and azathioprine (top-down therapy), or a taper with corticosteroids (step-up therapy). The top-down group received corticosteroids if they did not respond to infliximab and azathioprine. The step-up group received azathioprine if they relapsed after a second course of corticosteroids, and infliximab if they continued to have active disease after receiving azathioprine. Thus, there was significant overlap between groups in terms of which therapies could be received. In this non-blinded trial, the primary outcome was steroid-free remission. The patients who started on infliximab and azathioprine at baseline were more likely to be in steroid-free remission at 14 weeks compared with the step-up group according to our clinically meaningful and statistically significant thresholds (Table 11). However, at the final measurement at week 104, there was no clinically or statistically significant difference between the groups (Table 12). At week 104, less than 20 percent of either group was still receiving corticosteroids or infliximab, but patients did continue to use azathioprine with 90 percent of the top-down group receiving azathioprine compared with 71 percent of the step-up group.

###### Mucosal Healing

In the above trial,48 49 out of 129 patients underwent colonoscopy at the end of the followup period. At 104 weeks, 73 percent of the top-down group had no ulcers compared with 30 percent of the step-up group (P=0.003). However, the percent of patients with ulcers at baseline was not reported.

###### Patient-Reported Outcomes

After 10 weeks of treatment, patients receiving top-down therapy had clinically and statistically greater increases in the mean IBDQ change from baseline than patients receiving step-up therapy (mean between-group difference in change from baseline IBDQ, 21.8 points; 95% CI, 8.4 to 34.9 points; P=0.0014).48 This trial did not report any long-term results for IBDQ, although IBDQ was assessed throughout the 104-week trial.

##### Infliximab and Methotrexate Versus Infliximab Alone

###### Disease Activity Measures

One small unblinded trial47 compared the effectiveness of a combination of infliximab and methotrexate with infliximab monotherapy at inducing remission at 2 and 12 weeks and maintaining remission at 48 weeks. Across time points, the trial showed a clinically but not statistically significant difference in remission rates (Tables 9, 10, and 11).

###### Reduction of Steroids

In the above trial,47 mean prednisolone dose decreased from 17 mg to 0 mg in the combination infliximab and methotrexate group compared to a decrease from 21 mg to 15 mg in the infliximab alone group at week 48. This was clinically (using a definition of a delta in steroid reduction of 10 mg or more of prednisone) and statistically significant (P=0.02).

###### Patient-Reported Outcomes

At 48 weeks, the mean IBDQ score rose from 113 to 163 points in the infliximab and methotrexate group and from 107 to 135 points in the infliximab alone group, meeting our threshold for clinical significance.47 The trial did not provide a P-value to assess statistical significance.

### Thiopurines

Twelve RCTs evaluated the effectiveness of thiopurines (azathioprine or 6-mercaptopurine) as monotherapy or in combination with other therapies to induce remission.51-62

#### Study Design

Ten of the 12 RCTs were double blind (Appendix D, Evidence Table 2). One trial stated that the investigators were blinded, but the patients were aware of the medication.58 Another did not mention blinding.52 The trials were heterogeneous in all aspects of design including the locations, years of recruitment, duration, minimum age of enrollment, definition of active disease, doses and administration of the trial medications, and definition of remission outcomes.

Two trials were multinational,51,59 three took place at multiple centers in Israel57 or the United States,56,60 and six at single centers in Germany,54 Italy,58 South Africa,53 Spain,52 the United Kingdom,61 and the United States.62 Enrollment started between 1971^56^ and 2004^51^ although trials published in 1971 and 1974 did not report the enrollment year.61,62 All but one trial51 was completed prior to the approval of TNF-alpha inhibitors. The average time under trial per participant was longer than the natalizumab and TNF-alpha inhibitor trials with a median of 26 weeks (range, 12 weeks to 106 weeks). The minimum eligibility age was 18 years in four trials,51,54,58,59 17 years in one trial,57 15 years in four trials,52,53,56,60 and not reported in two trials.61,62

Common disease activity inclusion criteria included a minimum CDAI of 150 to 220 and no greater than 450,^51-54,56,58,59^ Harvey-Bradshaw Index (HBI) of 7 or greater,57 and steroid dependency.51,58,59 One trial required gastroenterologist-assessed active disease that had not previously responded to sulfasalazine or corticosteroids.60 Two trials published during the 1970s required active disease based on weight loss, fistula, diarrhea, inflammation on sigmoidoscopy, failure to respond to other medications and need for surgery.61,62 Common disease activity related exclusions included abscess,54,57-59 symptomatic strictures,51,53,57-59 and previous surgery within 3 months.51 Remission was defined as a CDAI less than 150 in seven trials,51-54,56,58,59 with three trials using an even more stringent definition of remission including a CDAI less than 150 combined with the absence of corticosteroids.51,58,59 Another trial required an HBI less than 3 and no use of corticosteroids.57 One trial did not use the CDAI but the gastroenterologist assessed symptoms, steroid dose, and fistula healing to assign patients to “improvement” or not.60 Two trials published during the 1970s reported patient assessments of symptoms,61 62 with one also reporting reduction of steroids.62

In contrast with the TNF-alpha inhibitor trials, medication inclusion criteria were rare. Most trials allowed patients with previous use of the medications under trial.51,53,54,56-59 One trial specifically excluded patients with prior use of thiopurines or methotrexate.52 Six trials required that patients had not used medications within the previous 3 to 6 months.51,53,54,57-59 Two trials specifically mentioned that patients with previous use of a biologic agent in a trial or practice settling were eligible as long as they had not used the medication 3 to 6 months prior.51 59 In contrast with the TNF-alpha inhibitor trials that allowed patients to use other medications as long as the patient was receiving a stable dose, most of the thiopurine trials specifically mentioned that they did not allow patients to use medications other than those under trial.51-53,56,58,59

#### Population Characteristics

The 12 trials randomized a total of 786 patients with Crohn's disease (Appendix D, Evidence Table 3). One trial52 included patients with Crohn's disease and ulcerative colitis, but we only included information from those with Crohn's disease.

The population characteristics had wide variability across the trials. The proportion of male participants in a treatment group ranged from 21^53^ to 75^61^ percent, among the trials that reported patient sex. One trial reported on race56 with white patients comprising between 90 and 94 percent of participants across the four trial groups. Smoking status was reported in five trials51-53,57,59 and ranged between 24^57^ and 86 percent.52 Average age at enrollment ranged between 27^54^ to 38^57^ years (mean) and 32^53^ to 40^51^ years (median). Duration of disease ranged between 3.3^56^ to 8.4 years57 (mean) and 0.6^51^ to 7.1^59^ years (median).

Disease location and disease activity were also heterogeneous across trials. Disease location was variable across trials: ileal location ranged between 5^54^ and 83^51^ percent, ileocolonic location between 25^57^ and 67^54^ percent, colonic location between 7^62^ and 73^51^ percent, and perianal lesions ranged between 14^52^ and 25^52^ percent. Baseline CDAI was reported for all seven trials using this measure, with mean CDAI ranging from 191^52^ and 290^54^ and median CDAI ranging from 244^59^ and 301^53^ points. In the trial that used HBI,57 mean HBI scores ranged from 7.8 to 9 across the three trial groups.

#### Key Points

Table 13 summarizes the strength of evidence for the trials evaluating thiopurines in terms of induction of remission. We found at least moderate strength of evidence or a clinically meaningful difference for the following areas:

- 6-mercaptopurine (1.5 mg/kg/day) was more effective than placebo in inducing a remission at week 104 (absolute RD, 33 percent; placebo rate, 14 percent). (SOE: Low)
- 6-mercaptopurine (1.5 mg/kg/day) was more effective than placebo in healing fistulas between 54-104 weeks in patients with actively draining fistulas (absolute RD in fistula closure, 25 percent; placebo rate, 6 percent). (SOE: Low)
- Azathioprine (2.5 mg/kg/day) was less effective than prednisone in inducing a remission at week 17 (absolute RD, -24 percent; prednisone rate, 77 percent). (SOE: Low)
- Azathioprine (2.5 mg/kg/day) was less effective than prednisone in healing fistulas at week 17 (absolute RD, -17 percent; prednisone rate, 30 percent). (SOE: Low)
- Azathioprine (2.5 mg/kg/day) was less effective than sulfasalazine (1 g /15 kg) in inducing a remission at week 2 (absolute RD, -14 percent; sulfasalazine rate, 20 percent). (SOE: Low).
- 6-mercaptopurine (1.5 mg/kg/day) was more effective than aminosalicylates (3 g/day) in inducing a remission at week 30 (absolute RD, 80 percent; aminosalicylate rate, 14 percent). (SOE: Low)
- A combination of azathioprine (2.5 mg/kg/day) and corticosteroids was more effective than corticosteroids alone in inducing a remission at weeks 12 and 28 (absolute RD across time points, 10 percent; corticosteroid rate, 28 to 63 percent). (SOE: Low)
- A combination of azathioprine (2 mg/kg/day) and corticosteroids was less effective than a combination of methotrexate (25 mg intravenous/week) and corticosteroids in healing fistulas at 26 weeks in patients with actively draining fistulas (absolute RD in fistula closure, -42 percent; methotrexate and corticosteroids rate, 67 percent). (SOE: Low)

Table 13 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating thiopurines to induce remission among patients with active Crohn's disease at randomization

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
Comparison | Outcome | Number of Trials (Participants) | Risk of bias | Consistency | Directness | Precision | Magnitude of Effect Strength of Evidence
Thiopurine vs. placebo–wks 3-4, 17-38 | Disease activity measures | 2 (158)56 57 | High | Inconsistent | Indirect | Imprecise | Favors neither RD across time points, -5% to 13%; placebo rate, 5% to 48% SOE: Low
Thiopurine vs. placebo–wk 104 | Disease activity measures | 1 (33)60 | High | Unknown (single trial) | Indirect | Imprecise | Favors 6-MP RD, 33%; placebo rate, 14% SOE: Low
Thiopurines vs. placebo–wk 16 | Reduction of steroids | 1 (26)62 | Medium | Unknown (single trial) | Direct | Imprecise | Favors neither Reduction in steroid dose from baseline, 7 mg vs. 12 mg SOE: Low
Thiopurine vs. placebo–wk 17 | Fistula response | 1 (17)55 | High | Unknown (single trial) | Direct | Imprecise | Favors neither RD in perianal fistula closure, 2%; placebo rate, 11% SOE: Low
Thiopurine vs. placebo– wk 104 | Fistula response | 1 (46)60 | High | Unknown (single trial) | Direct | Imprecise | Favors 6-MP RD in perianal fistula closure, 25%; placebo rate, 6% SOE: Low
Thiopurines vs. placebo–wk 8 and 16 | Patient-reported outcomes | 3 (116)57 61 62 | Medium | Inconsistent | Direct | Imprecise | Favors neither Multiple measures; see text SOE: Low
Thiopurines vs. methotrexate (oral)–wks 4, 12, 30-38 | Disease activity measures | 2 (89)52 57 | Medium | Inconsistent | Indirect | Imprecise | Favors neither RD across time points, -1% to 21%; placebo rate, 9% to 80% SOE: Low
Azathioprine vs. prednisone–wks 2, 13, 17 | Disease activity measures | 1 (144)56 | High | Unknown (single trial) | Direct | Imprecise | Favors prednisone RD across time points, -24 to -12%; prednisone rate, 27-77% SOE: Low
Azathioprine vs. prednisone–wk 17 | Fistula response | 1 (18)55 | High | Unknown (single trial) | Direct | Imprecise | Favors prednisone RD, -17%; prednisone rate, 30% SOE: Low
Azathioprine vs. sulfasalazine–wk 2 | Disease activity measures | 1 (133)56 | High | Unknown (single trial) | Direct | Precise | Favors sulfasalazine RD, -14%; sulfasalazine rate, 20% SOE: Low
Azathioprine vs. sulfasalazine–wks 13, 17 | Disease activity measures | 1 (133)56 | High | Unknown (single trial) | Direct | Imprecise | Favors neither RD across time points, 0% to 6%; sulfasalazine rate, 32% to 53% SOE: Low
Azathioprine vs. sulfasalazine–wk 17 | Fistula response | 1 (17)55 | High | Unknown (single trial) | Direct | Imprecise | Favors neither RD, -9%; sulfasalazine rate, 22% SOE: Low
6-MP vs. ASA–wks 12, 30 | Disease activity measures | 1 (23)52 | High | Unknown (single trial) | Direct | Precise | Favors 6-MP RD across time points, 67% to 80%; ASA rate, 14% SOE: Low
Azathioprine (IV and oral) vs. thiopurine (oral)–wk 8, 16 | Disease activity measures | 1 (96)59 | Medium | Unknown (single trial) | Indirect IV AZA is not presently used as a treatment | Imprecise | Favors neither RD across time points, 1% to 4%; oral azathioprine alone rate, 24% to 27% SOE: Low
Azathioprine + steroid vs. steroid–wks 12, 28 | Disease activity measures | 3 (186)51 53 54 | Medium | Inconsistent | Direct | Imprecise | Favors azathioprine + steroid RD across time points, 10%; steroid rate, 28% to 63% SOE: Low
Azathioprine + prednisone vs. methotrexate (IV followed by oral) + prednisone–wk 13, 26 | Disease activity measures | 1 (54)58 | Medium | Unknown (single trial) | Direct | Imprecise | Favors neither RD across time points, -11% to 7%; methotrexate + prednisone rate, 44% to 56% SOE: Low
Azathioprine + prednisone vs. methotrexate (IV followed by oral) + prednisone–wk 26 | Fistula response | 1 (10)58 | High | Unknown (single trial) | Direct | Imprecise | Favors methotrexate + prednisone RD in fistula closure, -42%; methotrexate + prednisone rate, 67% SOE: Low

6-MP = 6-mercaptopurine; ASA = aminosalicylates; IV = intravenous; mg = milligrams; RD = risk difference; SOE = strength of evidence; steroid = corticosteroids; vs. = versus; wk = weeks

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

#### Monotherapy Versus Placebo

##### Thiopurines Versus Placebo

###### Disease Activity Measures

Three trials, comprising 227 participants, compared thiopurines with placebo in inducing remission in those with active disease (Table 14; Appendix D, Table 4).56,57,60 Two trials had neither clinically nor statistically significant difference in remission rates between thiopurines and placebo groups at 17 and 38 weeks, the first time disease activity was reported.57,60 The trial that used physician assessment of disease activity did find a difference between groups.60 This trial employed a crossover design and we included the information reported for those patients that did not cross over (N=33). 6-mercaptopurine was clinically and statistically favored over placebo at 104 weeks according to the physician assessment. Because the CDAI had not been developed as part of the initial design steps of another trial,56 this measure was not used for inclusion or for outcome assessment. Because patients had to have no symptoms, fistula closure, or not use corticosteroids, the physician assessment could be considered a more difficult outcome to achieve than the CDAI less than 150 threshold which allows symptoms and does not assess corticosteroid use or fistula activity.

Table 14 Randomized controlled trials comparing the effectiveness of thiopurines with placebo or another treatment to induce remission among patients with active Crohn's disease at randomization

Author, Year | Followup (Weeks) | Main Intervention (Dose), n | Comparison (Dose), n | Remission Definition | Remission Rate (%)
Summers, 1979^56^ | 3 | Azathioprine (2.5 mg/kg/day), 59 | Placebo, 77 | CDAI<150 | 6 vs. 10%
Summers, 1979^56^ | 13 | Azathioprine (2.5 mg/kg/day), 59 | Placebo, 77 | CDAI<150 | 38 vs. 25%
Summers, 1979^56^ | 17 | Azathioprine (2.5 mg/kg/day), 59 | Placebo, 77 | CDAI<150 | 53 vs. 48%
Present, 1980^60^ | 104 | 6-mercaptopurine (1.5mg/kg/day), 19 | Placebo, 14 | “Excellent improvement”^†^ | 47 vs. 14%^‡^
Oren, 1997^57^ | 4 | 6-mercaptopurine (50 mg/day), 32 | Placebo, 26 | HBI 3 and steroid-free | 8 vs. 5%
Oren, 1997^57^ | 12 | 6-mercaptopurine (50 mg/day), 32 | Placebo, 26 | HBI 3 and steroid-free | 30 vs. 27%
Oren, 1997^57^ | 38 | 6-mercaptopurine (50 mg/day), 32 | Placebo, 26 | HBI 3 and steroid-free | 41 vs. 46%
Oren, 1997^57^ | 4 | 6-mercaptopurine (50 mg/day), 32 | Methotrexate (12.5 mg/wk oral), 26 | HBI 3 and steroid-free | 8 vs. 9%
Oren, 1997^57^ | 12 | 6-mercaptopurine (50 mg/day), 32 | Methotrexate (12.5 mg/wk oral), 26 | HBI 3 and steroid-free | 30 vs. 30%
Oren, 1997^57^ | 38 | 6-mercaptopurine (50 mg/day), 32 | Methotrexate (12.5 mg/wk oral), 26 | HBI 3 and steroid-free | 41 vs. 38%
Mate-Jimenez, 2000^52^ | 12 | 6-mercaptopurine (1.5 mg/kg/day), 16 | Methotrexate (15 mg/wk oral), 15 | CDAI<150, steroid-free, normal serum orosomucoid concentrations | 81 vs. 60%
Mate-Jimenez, 2000^52^ | 30 | 6-mercaptopurine (1.5 mg/kg/day), 16 | Methotrexate (15 mg/wk oral), 15 | CDAI<150, steroid-free, normal serum orosomucoid concentrations | 94 vs. 80%
Summers, 1979^56^ | 2 | Azathioprine (2.5 mg/kg/day), 59 | Prednisone (0.25-0.75 mg/kg/day), 85 | CDAI<150 | 6 vs. 27%
Summers, 1979^56^ | 13 | Azathioprine (2.5 mg/kg/day), 59 | Prednisone (0.25-0.75 mg/kg/day), 85 | CDAI<150 | 38 vs. 50%
Summers, 1979^56^ | 17 | Azathioprine (2.5 mg/kg/day), 59 | Prednisone (0.25-0.75 mg/kg/day), 85 | CDAI<150 | 53 vs. 77%
Summers, 1979^56^ | 2 | Azathioprine (2.5 mg/kg/day), 59 | Sulfasalazine (1 g/15 kg/day), 74 | CDAI<150 | 6 vs. 20%
Summers, 1979^56^ | 13 | Azathioprine (2.5 mg/kg/day), 59 | Sulfasalazine (1 g/15 kg/day), 74 | CDAI<150 | 38 vs. 32%
Summers, 1979^56^ | 17 | Azathioprine (2.5 mg/kg/day), 59 | Sulfasalazine (1 g/15 kg/day), 74 | CDAI<150 | 53 vs. 53%
Mate-Jimenez, 2000^52^ | 12 | 6-mercaptopurine (1.5 mg/kg/day), 16 | Aminosalicylates (3 g/day), 7 | CDAI<150, steroid-free, normal serum orosomucoid concentrations | 81 vs. 14%
Mate-Jimenez, 2000^52^ | 30 | 6-mercaptopurine (1.5 mg/kg/day), 16 | Aminosalicylates (3 g/day), 7 | CDAI<150, steroid-free, normal serum orosomucoid concentrations | 94 vs. 14%^‡^
Sandborn, 1999^59^ | 8 | Azathioprine (IV 40 mg/kg loading dose then oral 2 mg/kg/day), 51 | Azathioprine (oral 2 mg/kg/day), 45 | CDAI<150 and steroid-free | 25 vs. 24%
Sandborn, 1999^59^ | 16 | Azathioprine (IV 40 mg/kg loading dose then oral 2 mg/kg/day), 51 | Azathioprine (oral 2 mg/kg/day), 45 | CDAI<150 and steroid-free | 31 vs. 27%
Ewe, 1993^54^ | 16 | Azathioprine (2.5 mg/kg/day) + prednisolone (60 mg/day then taper), 21 | Prednisolone (60 mg/day then taper), 21 | CDAI<150 and 60-pt drop in CDAI | 76 vs. 38%^‡^
Candy, 1995^53^ | 12 | Azathioprine (2.5 mg/kg/day) + prednisolone (1 mg/kg/day then taper), 33 | Prednisolone (1 mg/kg/day then taper), 30 | CDAI<150 and steroid-free | 73 vs. 63%
Reinisch, 2008^51^ | 28 | Azathioprine (2.5 mg/kg/day) + prednisone (1 mg/kg/day or ≥ 40 mg/day then taper after response), 50 | Prednisone (1 mg/kg/day or ≥ 40 mg/day then taper after response), 28 | Treatment success^§^ | 38 vs. 28%
Ardizzone, 2003^58^ | 13 | Azathioprine (2 mg/kg/day) + prednisone (40 mg/day), 27 | Methotrexate (25 mg/wk)║ + prednisone (40 mg/day), 27 | CDAI≤150 and steroid-free | 33 vs. 44%
Ardizzone, 2003^58^ | 26 | Azathioprine (2 mg/kg/day) + prednisone (40 mg/day), 27 | Methotrexate (25 mg/wk)║ + prednisone (40 mg/day), 27 | CDAI≤150 and steroid-free | 63 vs. 56%

CDAI = Crohn's Disease Activity Index; HBI = Harvey-Bradshaw Index; IV = intravenous, kg = kilogram; mg = milligram; pt = point; wk = week

† “Excellent improvement” – disappearance of symptoms, complete closure of fistula, total withdrawal from steroids

‡ Trial reported P < 0.05

§ Treatment success was defined as absence of treatment failure, which encompassed patients: who prematurely discontinued the trial drug due to unsatisfactory therapeutic effect; who failed to achieve steroid-free remission (i.e., CDAI ≥150) by the end of month 3; who used steroids after the end of month 3; who used any prohibited efficacy-related treatment; and with a relapse (i.e., any CDAI ≥150 points and a minimum increase in CDAI ≥70 compared with the score at beginning of remission) recorded after end of month 3.

║ Methotrexate was given intravenously for 12 weeks then orally.

###### Reduction of Steroids

One trial with 26 participants showed reduction in the average daily dose of corticosteroid use in azathioprine (from 13.3 mg to 6.3 mg) and placebo (from 19.8 mg to 7.8 mg) during 4 months of followup prior to crossover (Appendix D, Evidence Table 4).62 Although the trial did not calculate statistical significance, the percent reduction in steroids between groups is not clinically significant (defined as delta reduction between groups as 10 mg of prednisone or more), especially in light of the much higher initial dose in the placebo group.

###### Fistula Response

Among a subset of 17 patients with draining perianal fistulas at the time of randomization,56 fistula response at 17 weeks was no different between azathioprine at 2.5 mg/kg daily with placebo (13 vs. 11 percent).55 However, 6-mercaptopurine resulted in greater fistula closer by 104 weeks, although statistical significance was not assessed.60 Nine out of 29 (31 percent) fistulas in the 6-mercaptopurine group compared with one of 17 (6 percent) in the placebo group healed completely. However, some of the placebo patients eventually took 6-mercaptopurine and some 6-mercaptopurine patients discontinued use as part of the crossover design.

###### Patient-Reported Outcomes

Three trials with 116 participants compared azathioprine with placebo and included patient-reported outcomes.57 61 62 Azathioprine did not improve patient reported outcomes in any trial. One trial,57 using the Treatment Goal Score for Wellbeing where everyone starts out with a score of 0 at week 0 and is graded as having better (+3 maximum score) or worse (-3 minimum score) based on general well-being, Crohn's disease-related symptoms, steroids, and extraintestinal manifestations, reported a statistically significant difference after 16 weeks on the well-being and abdominal pain components but did not find a statistically significant difference on the overall score at any time point through 36 weeks.57 A crossover trial showed no improvement in patient-reported quality of life (“feeling better”) with azathioprine compared with placebo; in both groups, six patients reported symptomatic improvement after crossover at 16 weeks, while five reported no change.62 In one trial61 after 8 weeks, no patients reported subjective improvement in their symptoms with azathioprine or placebo. More patients reported that their symptoms were worse with azathioprine versus placebo and fewer patients reported that their symptoms were unchanged with azathioprine versus placebo. The lack of response at 8 weeks with azathioprine is not unexpected because azathioprine may take up to 16 weeks to become clinically effective based on its pharmacokinetics.50 Pharmacokinetics cannot explain the lack of difference between azathioprine and placebo at 16 weeks.

#### Monotherapy Versus Monotherapy

##### Thiopurine Versus Methotrexate

###### Disease Activity Measures

Two trials including 89 participants compared thiopurine with methotrexate therapy (Table 14).52,57 One trial of 58 participants57 compared 6-mercaptopurine and placebo with oral methotrexate and placebo in steroid-dependent patients with active Crohn's disease defined by an HBI of 7 or greater. At 4, 12, and 38 weeks, there was no statistically significant difference in remission rates between the two groups. In a trial with unclear allocation concealment52 of 31 steroid-dependent patients, the group randomized to 6-mercaptopurine 1.5 mg/kg/day had higher remission rates than those randomized to oral methotrexate 15 mg/week at 30 weeks (94 versus 80 percent), although the trial did not report on statistical significance (Table 14).

##### Thiopurines Versus Corticosteroids

###### Disease Activity Measures

A trial of 144 participants compared azathioprine with prednisone (Table 14).56 At 2, 12, and 17 weeks, patients on azathioprine had a clinically meaningful lower rate of remission than patients on prednisone (week 17: 53 versus 77 percent), although the trial did not report statistical significance beyond showing that the standard errors did not overlap at any time point.

###### Fistula Response

Among a subset of 18 patients with draining perianal fistulas at the time of randomization,56 fistula response at 17 weeks was lower in patients receiving azathioprine at 2.5 mg/kg daily versus patients receiving prednisone (13 vs. 30 percent).55

##### Thiopurine Versus Aminosalicylates

###### Disease Activity Measures

Two trials including 156 participants compared thiopurine with aminosalicylate therapy (Table 14).52 56 One larger trial, comprising 133 participants, compared azathioprine with sulfasalazine therapy in inducing remission in those with active disease (CDAI greater than 150).56 There was no clinically or statistically significant difference in remission rates between the groups at 13 or 17 weeks, although at week 2 sulfasalazine had a higher remission rate (16 percent versus 2 percent) and the standard errors did not overlap. In the other trial of 23 steroid-dependent participants,52 the group receiving 6-mercaptopurine 1.5 mg/kg/day had clinically higher remission rates than the group receiving aminosalicylate 3 g/day at 12 and 30 weeks (statistically significant at 30 weeks).

###### Fistula Response

Among a subset of 17 patients with draining perianal fistulas at the time of randomization,56 there was no difference in fistula response at 17 weeks between those receiving azathioprine at 2.5 mg/kg daily versus those receiving sulfasalazine (13 vs. 22 percent).55

#### Combination Therapy Versus Monotherapy

##### Intravenous and Oral Thiopurines Versus Oral Thiopurines Alone

###### Disease Activity Measures

One trial of 96 steroid-dependent participants with active Crohn's disease assessed whether a loading dose of intravenous azathioprine combined with an oral regimen of daily azathioprine would yield higher remission rates compared with an oral regimen alone (Table 14).59 The trial standardized prednisone therapy in all participants to 20 mg per day during a 2-week period prior to randomization. There were no clinically or statistically significant differences in steroid-free remission rates between the two groups at 8 or 16 weeks.

##### Thiopurines and Corticosteroids Versus Corticosteroids Alone

###### Disease Activity Measures

Three trials51,53,54 comprising 186 participants compared azathioprine and prednisolone taper with prednisolone taper and placebo to induce remission (Table 14). One trial,54 which tapered prednisolone but continued it at a maintenance dose of 10 mg daily throughout the 16-week trial, found that the addition of azathioprine was favored to prednisolone alone according to the clinically meaningful and statistically significant thresholds. The other trials51,53 which evaluated steroid-free remission, found that more patients on azathioprine had lower CDAI scores and were free of steroids at 12 and 28 weeks that met the clinically meaningful threshold, although the results were not statistically significant.

#### Combination Therapy Versus Combination Therapy

##### Thiopurines and Corticosteroids Versus Methotrexate and Corticosteroids

###### Disease Activity Measures

One trial blinded investigators but not patients and compared a combination of azathioprine and prednisone with a combination of methotrexate (intravenous route for 12 weeks followed by oral route) and prednisone in 54 patients (Table 14).58 At 12 weeks, more methotrexate patients were in steroid-free remission, but at 26 weeks more azathioprine patients were in steroid-free remission, according to the clinically meaningful threshold. There were no statistically significant differences in remission rates between the two groups at 12 or 26 weeks.

###### Fistula Response

In the above trial,58 10 patients had active perianal fistulizing disease.58 At week 26, one out of four patients in the azathioprine group and four out of six patients in the methotrexate group had fistula closure, but this finding was not statistically significant.

### Methotrexate

Two trials evaluated the effectiveness of methotrexate as monotherapy to induce remission.52,57 Both of these trials also included comparisons with azathioprine and are described above. An additional trial63 compared methotrexate in combination with prednisone with placebo with prednisone. Two trials52,57 used oral methotrexate between 12.5 mg and 15 mg weekly, while one trial63 used intramuscular methotrexate at 25 mg a week.

#### Study Design

One of the three RCTs did not mention blinding (Appendix D, Evidence Table 2).52 Two trials used the CDAI for inclusion and to define the outcome, while one used the HBI.57 One trial took place in North America,63 one took place in Europe,52 and the last took place in Israel.57 Two of the trials were multicenter in design.57 63 All trials reported the starting year of enrollment, ranging between 1992 and 1994. The median trial duration was 39 weeks (ranging between 16 and 106 weeks). All trials included only steroid-dependent patients, except one57 which required prior steroid use for at least 4 of the prior 12 months. In one trial,63 patients who had a baseline prednisone dose under 20 mg daily raised their prednisone up to 20 mg daily for 2 weeks following randomization. One trial included adults ages 17 or older,57 one included those 15 and older,52 and one did not specify an age range.63

#### Population Characteristics

Three trials randomized a total of 215 Crohn's disease patients (Appendix D, Evidence Table 3). The proportion of male participants in each trial group ranged from 46 to 60 percent. No trials reported on race. Smoking status was reported in all trials, ranging between 24 and 86 percent across all trial groups. All but one trial reported mean age at enrollment,52 ranging between 33 and 39 years. All trials reported mean duration of disease, ranging between 4 and 8 years. All trials reported disease location: ileal location ranged between 17 and 50 percent, ileocolonic location between 25 and 86 percent, colonic location between 14 and 40 percent, and perianal location between 14 and 20 percent. Two trials reported baseline CDAI52,63 with mean CDAI ranging from 181 and 215 points. In the trial that used HBI,57 mean baseline HBI scores was 7.8 and 9 in the relevant trial groups.

#### Key Points

Table 15 summarizes the strength of evidence for the trials evaluating methotrexate in terms of induction of remission. We found at least moderate strength of evidence or a clinically meaningful difference for the following comparisons:

- Oral methotrexate (15 mg a week) was more effective than aminosalicylates in inducing a remission at weeks 12, 30 (absolute RD across time points, 46 to 66 percent; aminosalicylates rate, 14 percent). (SOE: Moderate)
- Intramuscular methotrexate (25 mg per week) with prednisone was more effective than prednisone plus placebo in inducing a steroid-free remission at week 16 (absolute RD, 20 percent; prednisone plus placebo rate, 19 percent). (SOE: Moderate)
- Intramuscular methotrexate (25 mg per week) with prednisone did not differ from prednisone plus placebo in improving patient-reported outcomes at 16 weeks (absolute between-group difference in change in mean IBDQ from baseline, 15 points; prednisone plus placebo change in IBDQ, -8 points). (SOE: Moderate)

Table 15 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating methotrexate to induce remission among patients with active Crohn's disease at randomization

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
Comparison | Outcome | Number of Trials (Participants) | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect Strength of Evidence
Methotrexate (oral) vs. placebo–wks 4, 12, 38 | Disease activity measures | 1 (52)57 | Medium | Unknown (single trial) | Direct | Imprecise | Favors neither RD across time points, -8% to 3%; placebo rate, 5% to 46% SOE: Low
Methotrexate (oral) vs. ASA–wks 12, 30 | Disease activity measures | 1 (22)52 | Medium | Unknown (single trial) | Direct | Precise | Favors methotrexate RD, 46% to 66%; ASA rate, 14% SOE: Moderate
Methotrexate (IM) + prednisone vs. placebo + prednisone–wk 16 | Disease activity measures | 1 (141)63 | Medium | Unknown (single trial) | Direct | Precise | Favors methotrexate + prednisone RD, 20%; prednisone only rate, 19% SOE: Moderate
Methotrexate (IM) + prednisone vs. placebo + prednisone–wk 16 | Patient-reported outcomes | 1 (141)63 | Medium | Unknown (single trial) | Direct | Precise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline, 15; prednisone only change in IBDQ, -8 SOE: Moderate

ASA = aminosalicylates; IBDQ = Inflammatory Bowel Disease Questionnaire; IM = intramuscular; RD = risk difference; SOE = strength of evidence; vs. = versus; wk = week

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

Scores for the Inflammatory Bowel Disease Questionnaire range from 32 to 224, with higher scores indicating better quality of life.36 Treatment Score for Wellbeing starts at 0 and improvement and worsening are graded from +3 to -3.^60^

#### Monotherapy Versus Placebo

##### Methotrexate Versus Placebo

###### Disease Activity Measures

One trial included 52 steroid-dependent patients who had used at least 4 months of corticosteroids in the year prior to randomization.57 There was no clinically meaningful or statistically significant difference in remission rates between 12.5 mg of oral methotrexate weekly compared with placebo (Table 16; see also Appendix D, Evidence Table 4).

Table 16 Randomized controlled trials comparing the efficacy of methotrexate with placebo or another treatment to induce remission among patients with active Crohn's disease at randomization

Author, Year | Followup (Weeks) | Main Intervention (Dose), n | Comparison (Dose), n | Remission Definition | Remission Rate, %
Oren, 1997^57^ | 4 | Methotrexate (12.5 mg oral/week), 26 | Placebo, 26 | HBI of 3 and steroid-free at any time during trial | 8% vs. 5%
Oren, 1997^57^ | 12 | Methotrexate (12.5 mg oral/week), 26 | Placebo, 26 | HBI of 3 and steroid-free at any time during trial | 20% vs. 22%
Oren, 1997^57^ | 38 | Methotrexate (12.5 mg oral/week), 26 | Placebo, 26 | HBI of 3 and steroid-free at any time during trial | 38% vs. 46%
Mate-Jimenez, 2000^†,52^ | 30 | Methotrexate (15 mg oral/week), 15 | Aminosalicylates (3 g/day), 7 | CDAI<150 and steroid-free and normal serum orosomucoid concentrations | 80% vs. 14%^*^
Feagan, 1995^63^ | 16 | Methotrexate (25 mg IM/week) + prednisone, 94 | Placebo + prednisone, 47 | CDAI<150 and steroid-free | 39% vs. 19%^*^

CDAI = Crohn's Disease Activity Index; g = grams; HBI = Harvey-Bradshaw Index; IM = intramuscular; mg = milligrams; NS = not significant; vs. = versus

* Trial reported P < 0.05

† Trial also randomized ulcerative colitis patients, but only Crohn's disease results included.

#### Monotherapy Versus Monotherapy

##### Methotrexate Versus Aminosalicylates

###### Disease Activity Measures

One trial52 of only 22 total patients compared methotrexate with aminosalicylates in steroid-dependent patients. A substantially higher proportion of Crohn's disease patients receiving oral methotrexate 15 mg per week achieved steroid-free remission (defined as CDAI < 150 and normal serum orosomucoid concentrations) than patients receiving 3 g per day of aminosalicylates therapy (80 vs.14 percent; P < 0.01). However, given the small sample size, and the fact that this was a subgroup analysis, the results should be interpreted with caution.

#### Combination Therapy Versus Monotherapy

##### Methotrexate and Corticosteroids Versus Corticosteroids Alone

###### Disease Activity Measures

We analyzed one RCT involving 141 patients.63 Table 16 summarizes the effects of methotrexate therapy in terms of inducing remission.

A trial of 141 patients found 25 mg intramuscular methotrexate weekly and prednisone taper was superior to placebo plus prednisone taper in inducing steroid-free remission at 16 weeks (Table 16; see also Appendix D, Evidence Table 4).63

###### Patient-Reported Outcomes

At 16 weeks, there was no clinically meaningful difference in the IBDQ between the methotrexate and placebo groups.63

### Corticosteroids

Thirteen RCTs compared corticosteroids therapy (alone or in combination with other medications) with placebo or other therapies to induce remission. One trial64 included participants with both active (CDAI > 150) and inactive (CDAI < 150) disease at randomization and we included results for those with active disease only in this section. Three trials56,65,66 evaluated corticosteroids (budesonide, prednisone) versus placebo. Three trials67-69 evaluated budesonide versus prednisone or prednisolone. Six trials56,70-74 evaluated corticosteroids (budesonide, prednisone, 6-methylprednisolone) versus aminosalicylates. One trial75 evaluated a combination of prednisone and sulfasalazine versus prednisone alone. One trial also randomized patients to thiopurine and the results of thiopurine compared with corticosteroids are reported in the thiopurine section of the report.56

#### Study Design

The 13 RCTs were double blind (Appendix D, Evidence Table 2).56 64-75 The trials were heterogeneous in all aspects of design including the locations, years of recruitment, and doses and administration of the trial medications.

The trials took place at multiple centers in the United States,56,65,75 Canada,66,73 Europe,64,69,71,72 and Israel.67 Three trials were multinational.68,70,74 Enrollment started between 1971 and 2004. All but one trial was completed prior to the approval of TNF-alpha inhibitors.74 Trial duration ranged from 6^64^ to 17 weeks.56 The minimum eligibility age was 18 years in ten trials, 15 years in one trial,56 and two did not report the minimum eligibility age.72,75

Common disease activity inclusion criteria included a minimum CDAI of 150 or 200 with no upper limit or the use of a range of minimum (150 to 200) and maximum criteria (350 to 450). Common disease activity related exclusions included abscess,64,68-70,74 fistula, obstructive symptoms or strictures,67-71,74 and previous extensive surgery (more than 50 to 100 cm of resection).66,68-71,73,74 Six of the seven trials of budesonide included patients with disease in the ileum or ascending colon only where budesonide is released.65-70 Remission was defined as a CDAI less than 150 in all trials.

Most trials prohibited patients from taking therapies that were not assigned as part of the trial. No trial specifically excluded patients with prior use of any medication, although exclusion of patients taking immunomodulators within 3 months of randomization,65,67-74 aminosalicylates within 1 day to 30 days prior to randomization,66-70,72-74 and corticosteroids within 1 week to 3 months of randomization65-72,74 were common. The trial conducted after the approval of biologics74 excluded patients who had used a TNF-alpha inhibitor within 6 months of randomization.

#### Population Characteristics

The trial that included patients with active and inactive disease did not report the population characteristics separately and is excluded from the description of population characteristics.64 The other 12 trials randomized a total of 2,089 patients (Appendix D, Evidence Table 3). The proportion of male participants in each trial group ranged from 23 to 66 percent. Three trials reported on race56,74,75 with Caucasian patients comprising between 86 and 99 percent of all participants across the five trial groups. Four trials66,67,71,74 reported smoking status, ranging between 25 and 58 percent. All trials reported age at enrollment, ranging between 26 to 41 years (mean) and 30 to 38 years (median). All trials except two75,76 reported duration of disease, ranging between 2.4 to 11.9 years (mean) and 4.6 to 9.2 years (median). All but four trials65,68,69,74 reported disease location: ileal location ranged between 23 and 100 percent, ileocolonic location between 12 and 66 percent, and colonic location between 0 and 94 percent. All trials reported baseline CDAI, with mean CDAI ranging from 236 and 305 points and median CDAI ranging between 220 and 293 points. Prior medication use was as follows: aminosalicylates use ranged from 31 to 81 percent of participants in five trials,56,67,70,71,75 antibiotic use ranged from 28 to 35 percent across two groups of one trial,67 and corticosteroids use ranged from 25 to 52 percent across five trials.56,66,67,73,75

#### Key Points

Table 17 summarizes the strength of evidence for the trials evaluating corticosteroids in terms of remission induction. We found at least moderate strength of evidence or a clinically meaningful difference for the following comparisons:

- Budesonide (at least 9 mg daily) was more effective than placebo in inducing a remission at week 2 (absolute RD, 17 to 27 percent; placebo rate, 11 to 13 percent). (SOE: Moderate)
- Budesonide was more effective than placebo in inducing a remission at week 8 (absolute RD, 13 to 31 percent; placebo rate, 20 to 33 percent). (SOE: Moderate)
- 6-methylprednisolone was more effective than placebo in inducing a remission at week 3 (absolute RD, 14 percent; placebo rate, 79 percent). (SOE: Low)
- Corticosteroids (including prednisone, 6-methylprednisolone) were more effective than placebo in inducing a remission at weeks 16-17, and 104 (absolute RD across time points, 25 to 47 percent; placebo rate, 8 to 42 percent). (SOE: Low)
- Prednisone was more effective than placebo in healing fistulas at 17 weeks in patients with actively draining fistulas (absolute RD in fistula closure, 19 percent; placebo rate, 11 percent). (SOE: Low)
- Budesonide (9 mg a day) and corticosteroids (prednisone, prednisolone at 40 mg/day) did not differ in inducing a remission at weeks 2 and 8 (pooled RR at week 8, 0.9; 95% CI, 0.8 to 1.0; corticosteroid rate, 55 to 65 percent). (SOE: Moderate)
- Budesonide (9 mg daily) and prednisone (taper starting with 40 mg daily) did not differ in improving patient-reported outcomes at 8 weeks (absolute between-group difference in change in mean IBDQ from baseline, -8 points; prednisone change in IBDQ, 34 points). (SOE: Moderate)
- Corticosteroids (budesonide, prednisone, 6-methylprednisolone) were more effective than aminosalicylates in inducing a remission at weeks 2 to 3, 12 to 17, 54, and 104 (absolute RD across time points, -18 to 30 percent; aminosalicylates rate, 6 to 87 percent). (SOE: Low)
- Prednisone (taper starting at 40 mg daily) was more effective than aminosalicylates (Salofalk® 1 g, 3 times daily) in improving patient-reported outcomes at 2 weeks (absolute between-group difference in improvement in Quality of Life Index from baseline, 16 percent; Salofalk® improvement in Quality of Life Index, 7 percent). (SOE: High)
- Prednisone (taper starting at 40 mg daily) and aminosalicylates (Salofalk® 1 g, 3 times daily) did not differ in improving patient-reported outcomes at 12 weeks (absolute between-group difference in improvement in Quality of Life Index from baseline, 4 percent; Salofalk® improvement in Quality of Life Index, 33 percent). (SOE: Moderate)
- A combination of 6-methylprednisolone (48 mg/day) and sulfasalazine (3 g/day) was more effective than placebo in inducing a remission at weeks 3, 16, and 104 (absolute RD across time points, 19 to 47 percent; placebo rate, 8 to 79 percent). (SOE: Low)
- A combination of corticosteroids (prednisone, 6-methylprednisolone) and sulfasalazine was more effective than sulfasalazine alone in inducing a remission at weeks 3, 16, and 104 (absolute RD across time points, 11 to 26 percent; sulfasalazine rate, 22 to 87 percent). (SOE: Low)

Table 17 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating corticosteroids to induce remission among patients with active Crohn's disease at randomization

Comparison | Outcome | Number of trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
Comparison | Outcome | Number of trials (Participants) | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect Strength of Evidence
Budesonide (≥ 9 mg) vs. placebo–wk 2 | Disease activity measures | 2 (391)65 66 | Medium | Consistent | Direct | Precise | Favors budesonide RD, 17% to 27%; placebo rate, 11% to 13% SOE: Moderate
Budesonide (< 9 mg) vs. placebo–wk 2 | Disease activity measures | 1 (128)66 | Medium | Unknown (single trial) | Direct | Imprecise | Favors neither RD, -1%; placebo rate, 11% SOE: Low
Budesonide vs. placebo–wk 8 | Disease activity measures | 2 (458)65 66 | Medium | Consistent | Direct | Precise | Favors budesonide RD across time points, 13% to 31%; placebo rate, 20% to 33% SOE: Moderate
Budesonide vs. placebo–wk 8 | Patient-reported outcomes | 2 (458)65 66 | High | Consistent | Direct | Imprecise | Favors neither Absolute between-group difference in change in IBDQ from baseline, 7 to 30; placebo change in IBDQ, 10 to 29 SOE: Low
Prednisone vs. placebo – wk 2 | Disease activity measures | 1 (162)56 | High | Unknown (single study) | Direct | Imprecise | Favors neither RD, 5%; placebo rate, 15% SOE: Low
6-methyl-prednisolone vs. placebo–wk 3 | Disease activity measures | 1 (105)64 | High | Unknown (single study) | Direct | Precise | Favors 6-methylprednisolone RD, 14%; placebo rate, 79% SOE: Low
Steroid (6-methyl-prednisolone, prednisone) vs. placebo–wks 16-17, 104 | Disease activity measures | 2 (267)56 64 | High | Consistent | Direct | Precise | Favors steroids RD across time points, 25% to 47%; placebo rate, 8% to 42% SOE: Low
Prednisone vs. placebo–wk 17 | Fistula response | 1 (19)55 | High | Unknown (single trial) | Direct | Imprecise | Favors prednisone RD in fistula closure, 19%; placebo rate, 11% SOE: Low
Budesonide vs. other steroid (prednisolone, prednisone)–wks 2, 8 | Disease activity measures | 3 (557)67-69 | Medium | Consistent | Direct | Precise | Favors neither Pooled RR at wk 8, 0.9; CI, 0.8 to 1.0; steroid rate, 55% to 65% SOE: Moderate
Budesonide vs. prednisone–wk 8 | Patient-reported outcomes | 1 (201)67 | Low | Unknown (single trial) | Direct | Imprecise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline, -8; prednisone change in IBDQ, 34 SOE: Moderate
Steroid vs. ASA–wks 2-3, 12-17, 54-104 | Disease activity measures | 7 (919)56 64 70-74 | Medium | Inconsistent | Direct | Imprecise | Favors steroids RD across time points, -18% to 30%; ASA rate, 6% to 87% SOE: Low
Prednisone vs. sulfasalazine | Fistula healing | 2 (19)55 | High | Unknown (single trial) | Direct | Imprecise | Favors neither RD in fistula closure, 9%; sulfasalazine rate, 22% SOE: Low
Prednisone vs. ASA – wk 2 | Patient-reported outcomes | 1 (50)73 | Low | Unknown (single trial) | Direct | Precise | Favors prednisone Absolute between-group difference in Quality of Life Index from baseline, 16%; ASA improvement in Quality of Life Index, 7% SOE: High
Prednisone vs. ASA – wk 12 | Patient-reported outcomes | 1 (50)73 | Low | Unknown (single trial) | Direct | Imprecise | Favors neither Absolute between-group difference in Quality of Life Index from baseline, 4%; ASA improvement in Quality of Life Index, 33% SOE: Moderate
Prednisolone + sulfasalazine vs. placebo–wks 3,16, 104 | Disease activity measures | 1 (114)64 | High | Unknown (single trial) | Direct | Precise | Favors prednisolone + sulfasalazine RD across time points, 19% to 47%; placebo rate, 8% to 79% SOE: Low
Steroid + sulfasalazine vs. steroid–wks 3, 8-16, 104 | Disease activity measures | 2 (192)64 75 | Medium | Consistent | Direct | Imprecise | Favors neither RD across time points, 2% to 19%; steroid rate, 33% to 93% SOE: Low
Steroid + sulfasalazine vs. sulfasalazine–wks 3, 16, 104 | Disease activity measures | 1 (110)64 | High | Consistent | Direct | Precise | Favors steroids + sulfasalazine RD across time points, 11% to 26%; sulfasalazine rate, 22% to 87% SOE: Low

ASA = aminosalicylates; CI = 95% confidence interval; IBDQ = Inflammatory Bowel Disease Questionnaire; mg = milligrams; RD = absolute risk difference; RR = relative risk; SOE = strength of evidence; steroid = corticosteroids; vs. = versus; wk = week

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

Scores for the Inflammatory Bowel Disease Questionnaire and the Quality of Life Index range from 32 to 224, with higher scores indicating better quality of life.36

#### Monotherapy Versus Placebo

##### Corticosteroids Versus Placebo

Table 18 summarizes the effects of corticosteroids to induce remission compared with placebo (see also Appendix D, Evidence Table 4).

Table 18 Randomized controlled trials comparing the efficacy of corticosteroids with placebo or another treatment to induce remission among patients with active Crohn's disease at randomization

Author, Year | Followup (Weeks) | Main Intervention (Dose), n | Comparison (Dose), n | Remission Definition | Remission Rate (%)
Greenberg, 1994^66^ | 2 | Budesonide (1.5 mg twice daily), 67 | Placebo, 66 | CDAI<150 | 10% vs. 11%
Greenberg, 1994^66^ | 2 | Budesonide (4.5 mg twice daily), 61 | Placebo, 66 | CDAI<150 | 32% vs. 11%
Greenberg, 1994^66^ | 2 | Budesonide (7.5 mg twice daily), 64 | Placebo, 66 | CDAI<150 | 28% vs. 11%
Greenberg, 1994^66^ | 8 | Budesonide (1.5 mg twice daily), 67 | Placebo, 66 | CDAI<150 | 33% vs. 20%
Greenberg, 1994^66^ | 8 | Budesonide (4.5 mg twice daily), 61 | Placebo, 66 | CDAI<150 | 51% vs. 20%^*^
Greenberg, 1994^66^ | 8 | Budesonide (7.5 mg twice daily), 64 | Placebo, 66 | CDAI<150 | 43% vs. 20%^*^
Tremaine, 2002^65^ | 2 | Budesonide (9 mg/day), 80 | Placebo, 41 | CDAI<150 | 31% vs. 13%^*^
Tremaine, 2002^65^ | 2 | Budesonide (4.5 mg twice daily), 79 | Placebo, 41 | CDAI<150 | 40% vs. 13%^*^
Tremaine, 2002^65^ | 8 | Budesonide (9 mg/day), 80 | Placebo, 41 | CDAI<150 | 48% vs. 33%
Tremaine, 2002^65^ | 8 | Budesonide (4.5 mg twice daily), 79 | Placebo, 41 | CDAI<150 | 53% vs. 33%
Summers, 1979^56^ | 2 | Prednisone (0.5-0.75 mg/kg), 85 | Placebo, 77 | CDAI<150^†^ | 20% vs. 15%
Summers, 1979^56^ | 17 | Prednisone (0.5-0.75 mg/kg), 85 | Placebo, 77 | CDAI<150^†^ | 59% vs. 42%^*^
Malchow, 1984^64^ | 3 | 6-methylprednisolone (48 mg/day with taper), 47 | Placebo, 58 | CDAI<150^‡^ | 93% vs. 79%^*^
Malchow, 1984^64^ | 16 | 6-methylprednisolone (48 mg/day with taper), 47 | Placebo, 58 | CDAI<150^‡^ | 83% vs. 36%^*^
Malchow, 1984^64^ | 104 | 6-methylprednisolone (48 mg/day with taper), 47 | Placebo, 58 | CDAI<150^‡^ | 33% vs. 8%^*^
Rutgeerts, 1994^69^ | 2 | Budesonide (9 mg/day), 86 | Prednisolone (40 mg/day), 86 | CDAI≤150 | 45% vs. 56%
Rutgeerts, 1994^69^ | 10 | Budesonide (9 mg/day), 86 | Prednisolone (40 mg/day), 86 | CDAI≤150 | 53% vs. 66%
Bar-Meir, 1998^67^ | 8 | Budesonide (9 mg/day), 100 | Prednisone (40 mg/day), 101 | CDAI<150 | 51% vs. 53%
Campieri, 1997^68^ | 2 | Budesonide (4.5 mg twice daily), 58 | Prednisolone (40 mg/day), 61 | CDAI≤150 | 27% vs. 37%
Campieri, 1997^68^ | 2 | Budesonide (9 mg/day), 61 | Prednisolone (40 mg/day), 61 | CDAI≤150 | 48% vs. 37%
Campieri, 1997^68^ | 8 | Budesonide (4.5 mg twice daily), 58 | Prednisolone (40 mg/day), 61 | CDAI≤150 | 48% vs. 60%
Campieri, 1997^68^ | 8 | Budesonide (9 mg/day), 61 | Prednisolone (40 mg/day), 61 | CDAI≤150 | 60% vs. 60%
Thomsen, 1998^70^ | 8 | Budesonide (9 mg/day), 93 | Mesalamine (4 g/day), 89 | CDAI<150 | 69% vs. 45%^*^
Thomsen, 1998^70^ | 16 | Budesonide (9 mg/day), 93 | Mesalamine (4 g/day), 89 | CDAI<150 | 62% vs. 36%^*^
Tromm 2011^74^ | 8 | Budesonide (9mg/day), 154 | Mesalamine (4.5 g/day), 153 | CDAI<150 | 69% vs. 62%
Summers, 1979^56^ | 3 | Prednisone (0.5-0.75 mg/kg/day), 85 | Sulfasalazine (1.5 mg/15 kg/day), 74 | CDAI<150^†^ | 25% vs. 6%
Summers, 1979^56^ | 17 | Prednisone (0.5-0.75 mg/kg/day), 85 | Sulfasalazine (1.5 mg/15 kg/day), 74 | CDAI<150^†^ | 59% vs. 29%
Malchow, 1984^64^ | 3 | 6-methylprednisolone (48 mg/day with taper), 47 | Sulfasalazine (3g/day), 54 | CDAI<150^‡^ | 93% vs. 87%
Malchow, 1984^64^ | 16 | 6-methylprednisolone (48 mg/day with taper), 47 | Sulfasalazine (3g/day), 54 | CDAI<150^‡^ | 83% vs. 57%
Malchow, 1984^64^ | 104 | 6-methylprednisolone (48 mg/day with taper), 47 | Sulfasalazine (3g/day), 54 | CDAI<150^‡^ | 33% vs. 22%
Gross, 1995^72^ | 8 | 6-methylprednisolone (48 mg/day), 16 | Aminosalicylates (4.5 g/day), 15 | CDAI<150, 60-pt decrease in CDAI | 56% vs. 40%
Prantera, 1999^71^ | 3 | 6-methylprednisolone (40 mg/day), 31 | Aminosalicylate tablets (4 g/day), 35 | CDAI<150 | 61% vs. 46%
Prantera, 1999^71^ | 3 | 6-methylprednisolone (40 mg/day), 31 | Aminosalicylate granules (4 g/day), 28 | CDAI<150 | 61% vs. 61%
Prantera, 1999^71^ | 12 | 6-methylprednisolone (40 mg/day), 31 | Aminosalicylate tablets (4 g/day), 35 | CDAI<150 | 61% vs. 60%
Prantera, 1999^71^ | 12 | 6-methylprednisolone (40 mg/day), 31 | Aminosalicylate granules (4 g/day), 28 | CDAI<150 | 61% vs. 79%
Martin, 1990^73^ | 12 | Prednisone (40 mg/day), 26 | Mesalamine (750 mg/day), 19 | CDAI < 150 | 46% vs. 47%
Malchow, 1984^64^ | 3 | 6-methylprednisolone (48 mg/day with taper) + sulfasalazine (3g/day), 56 | Placebo, 58 | CDAI<150^‡^ | 98% vs. 79%^*^
Malchow, 1984^64^ | 16 | 6-methylprednisolone (48 mg/day with taper) + sulfasalazine (3g/day), 56 | Placebo, 58 | CDAI<150^‡^ | 83% vs. 36%^*^
Malchow, 1984^64^ | 104 | 6-methylprednisolone (48 mg/day with taper) + sulfasalazine (3g/day), 56 | Placebo, 58 | CDAI<150^‡^ | 35% vs. 8%^*^
Singleton, 1979^75^ | 8 | Prednisone (0.25-0.75 mg/kg/day) + sulfasalazine (1 g/15 kg/day), 46 | Prednisone (0.25-0.75 mg/kg/day), 43 | CDAI<150 | 76% vs. 57%
Malchow, 1984^64^ | 3 | 6-methylprednisolone (48 mg/day with taper) + sulfasalazine (3g/day), 56 | 6-methylprednisolone (48 mg/day with taper), 47 | CDAI<150^‡^ | 98% vs. 93%
Malchow, 1984^64^ | 16 | 6-methylprednisolone (48 mg/day with taper) + sulfasalazine (3g/day), 56 | 6-methylprednisolone (48 mg/day with taper), 47 | CDAI<150^‡^ | 83% vs. 75%
Malchow, 1984^64^ | 104 | 6-methylprednisolone (48 mg/day with taper) + sulfasalazine (3g/day), 56 | 6-methylprednisolone (48 mg/day with taper), 47 | CDAI<150^‡^ | 35% vs. 33%
Malchow, 1984^64^ | 3 | 6-methylprednisolone (48 mg/day with taper) + sulfasalazine (3g/day), 56 | Sulfasalazine (3g/day), 54 | CDAI<150^‡^ | 98% vs. 87%
Malchow, 1984^64^ | 16 | 6-methylprednisolone (48 mg/day with taper) + sulfasalazine (3g/day), 56 | Sulfasalazine (3g/day), 54 | CDAI<150^‡^ | 83% vs. 57%
Malchow, 1984^64^ | 104 | 6-methylprednisolone (48 mg/day with taper) + sulfasalazine (3g/day), 56 | Sulfasalazine (3g/day), 54 | CDAI<150^‡^ | 35% vs. 22%

CDAI = Crohn's Disease Activity Index; g = grams; kg = kilograms; mg = milligrams; pt = point; vs. = versus

* Study reported significance at the 0.05 alpha level. For Malchow 1984,^64^ significance level does not specify time point in the 104 week trial – thus all time points are marked as significant for a given comparison where appropriate

† One component of a composite outcome

‡ One component of a composite outcome including CDAI criteria (decrease or less than 100 points increase during first treatment, no increase during second treatment, and score less than 150 or 60 point decrease after third treatment), no need to repeat induction therapy, absence of clinical criteria (death due to Crohn's disease, fever for more than 2 weeks, need for Crohn's disease surgery, development of new fistulas or abscesses, or disease worsening by endoscopy or radiography) and not withdrawn from the trial

###### Disease Activity Measures

Four trials, comprising 725 participants, compared corticosteroids with placebo to induce remission.56,64-66

Budesonide 9 mg had higher remission rates at 2 and 8 weeks compared with placebo in two trials,65,66 but the finding was statistically significant in only one of the trials at 2^65^ and 8 weeks.66 Budesonide 15 mg was clinically favored at 2 and 8 weeks and was statistically significant at 8 weeks.66 Prednisone was clinically and statistically favored over placebo at 17 weeks, but not 2 weeks.56 Methylprednisolone (48 mg/day with taper) was clinically favored over placebo at 3 and 104 weeks, but was statistically significant only at 104 weeks.64 A meta-analysis of the four trials was not performed because the medications act in different portions of the intestines and the patient populations accordingly differed in location of disease.

###### Fistula Response

One trial reported in two publications compared prednisone with placebo.55,56 Nineteen patients had draining perianal disease at the time of randomization. Fistula response was higher in the prednisone group (30 vs.11 percent; study reported P > 0.05).

###### Patient-Reported Outcomes

Two trials with 458 participants compared budesonide with placebo.65,66 In the larger trial of 258 participants,66 at 8 weeks mean IBDQ rose from a baseline value of 131 to 138 points in the 3 mg/day group, 125 to 165 points in the 9 mg/day group, 130 to 155 points in the 15 mg/day group, and 130 to 140 points in the placebo group. Budesonide was only clinically and statistically significant compared with placebo at the 9 mg dosage.66 In a trial of 200 patients, there was no difference between groups.65 The change in IBDQ score from baseline (values not provided) was 36 points in the 9 mg/day group, 34 points in the 4.5 mg oral twice daily group, and 29 points in the placebo group at 8 weeks.65

#### Monotherapy Versus Monotherapy

##### Budesonide Versus Other Corticosteroids

###### Disease Activity Measures

Three trials, including 553 participants, compared budesonide with prednisone or prednisolone in the ability to induce remission at 2, 8, and 10 weeks after randomization.67-69 The daily doses were consistent across the trials. The daily dose of budesonide was 9 mg and 40 mg for prednisolone or prednisone. A meta-analysis was performed (Figure 7). We found no clinically meaningful or statistically significant difference in pooled remission rates at 8 weeks (RR of inducing remission, 0.88; 95% CI, 0.76 to 1.02). There was no significant heterogeneity (I-squared, 0 percent).

Figure 7 Pooled relative risk of inducing remission^*^ * In all trials, remission was defined as a Crohn's Disease Activity Index less than 150. Boxes indicate individual trial point estimates. The box size denotes the weight of the trial, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each trial. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate. of Crohn's disease at week 8 comparing budesonide with another corticosteroid

BUD = budesonide; CI = confidence interval; PRED = prednisone; PREDL = prednisolone; RR = relative risk; Steroid = corticosteroid

Test for heterogeneity: Q=0.65 with 2 degrees of freedom (p=0.72)

I-squared statistic = 0%

Figure 7 is a forest plot depicting the pooled relative risk, with 95% confidence interval, of inducing remission at week 8 comparing budesonide with another steroid. Three trials are included, which are Rutgeerts 1994 comparing budesonide to prednisolone, Campieri 1997 comparing to prednisolone, and Bar-Meir 1998 comparing to prednisone. The information presented in the plot shows the relative risk, number of people with events of remission with budesonide, total number on budesonide presented in the study, then number of events on the other corticosteroid and total number on the other corticosteroid in the study. The pooled relative risk is 0.88, with a 95% confidence interval of 0.76 to 1.02, which favors neither budesonide nor another steroid for inducing remission at week 8.

###### Patient-Reported Outcomes

One trial with 201 participants compared prednisone and placebo with budesonide and placebo.67 At 8 weeks, mean IBDQ rose from 130 to 164 in the prednisone group and 136 to 162 in the budesonide group, which did not meet the 17-point difference threshold for clinical significance. Additionally, there were no difference in the Short Form-36 (SF-36) mental score (increase from 42.2 to 60.9 points vs. 46.5 to 56.9 points, respectively) or physical score (increase from 40.8 to 62.3 points vs. 44.8 to 58.3 points, respectively).

##### Corticosteroids Versus Aminosalicylates

###### Disease Activity Measures

Seven trials, including 874 participants, compared corticosteroids with aminosalicylates to induce remission.56,64,70-74 Meta-analysis was not performed because of the disease location differences in the budesonide trials70,74 compared with the other trials and differences in time periods of the study and definition of remission in the methylprednisolone and prednisone trials.56,64,71-73

The budesonide trials had inconsistent findings.70,74 The 1998 trial found clinically meaningful and statistically significant results favoring budesonide 9 mg/day compared with mesalamine 4 mg/day at 8 and 16 weeks,70 but the 2011 budesonide trial found no difference using the same dose of budesonide and 0.5 mg/day more of mesalamine at 8 weeks.74

The prednisone trials also had inconsistent results.56,73 Prednisone 0.5 to 0.75 mg/kg/day was clinically favored over sulfasalazine 1.5 mg/15 kg/day at 3 and 17 weeks, although statistical significance was not reported in the trial.56 Prednisone 40 mg/day for 2 weeks followed by a decrease in the dose for an additional 10 weeks was no different than mesalamine 750 mg/d at 12 weeks at inducing remission.73

The three 6-methylprednisolone trials also had inconsistent results.64,71,72 The remission outcomes and formulations and doses of aminosalicylates were different between the trials prohibiting meta-analysis. 6-methylprednisolone 48 mg/day was clinically, but not statistically, favored over aminosalicylates 4.5 g/day at 8 weeks.72 The other two 6-methylprednisolone trials had inconsistent results based on the time of measure and formulation of the aminosalicylate.64 71

###### Fistula Response

Among a subset of 19 patients with draining perianal fistulas at the time of randomization,56 there was no difference in fistula response at 17 weeks between those receiving prednisone daily versus those receiving sulfasalazine (30 vs. 22 percent).55

###### Patient-Reported Outcomes

One trial with 50 participants compared prednisone with aminosalicylates using the McMaster University Quality of Life Index.73 At 2 weeks, improvement, not defined in the manuscript, in the Quality of Life Index was 23 percent in the prednisone group and 7 percent in the aminosalicylates group, which met our 10 percent between group difference threshold (P < 0.005). At 12 weeks, the improvement was 37 and 33 percent, respectively, and was not clinically meaningful nor statistically significant (P > 0.05).

#### Combination Therapy Versus Placebo

##### Corticosteroids and Aminosalicylates Versus Placebo

###### Disease Activity Measures

In the trial64 that randomized patients with active and inactive disease, the active disease patients that received combination therapy with methylprednisolone (48 mg/day with taper) and sulfasalazine (3 g/day) had clinically and statistically significantly higher rates of remission than the placebo group at 3, 16, and 104 weeks after randomization.

#### Combination Therapy Versus Monotherapy

##### Corticosteroids and Aminosalicylates Versus Corticosteroids Alone

###### Disease Activity Measures

Two trials64,75 including 192 participants compared a combination of corticosteroids and aminosalicylates versus corticosteroids alone.

One trial found a clinically meaningful difference, but the other trial did not. A trial of 89 participants75 compared a combination of prednisone and sulfasalazine with prednisone alone. The trial favored combination therapy over prednisone at week 8, but this finding was not statistically significant. The other trial,64 did not find a clinically meaningful difference between combination therapy with methylprednisolone (48 mg/day with taper) and sulfasalazine (3 g/day) and 6-methylprednisolone (48 mg/day with taper) alone.

##### Corticosteroids and Aminosalicylates Versus Aminosalicylates Alone

###### Disease Activity Measures

One trial,64 including 110 participants, compared a combination of corticosteroids and aminosalicylates with aminosalicylates alone. Combination therapy with 6-methylprednisolone (48 mg/day with taper) and sulfasalazine (3 g/day) resulted in higher rates of remission at 3, 16, and 104 weeks than sulfasalazine (3 g/day) alone. Statistical tests were not reported in the publication for this medication comparison.

### Aminosalicylates

Five trials evaluated the effectiveness of aminosalicylates as monotherapy to induce remission.56,64,77-79 Two trials evaluated sulfasalazine at doses between 1 g/15 kg and 6 g a day,56 64 two trials evaluated mesalamine (Asacol) between 1 g to 4 g a day,77,79 and one trial evaluated mesalamine (Pentasa) at 1.5 g a day.78 Two of these trials included comparisons with corticosteroids56,64 and one included comparisons with immunomodulators.56 These trials are also reported in those sections of the report.

#### Study Design

The five RCTs were double blind (Appendix D, Evidence Table 2).56,64,77-79 One trial64 included participants with both active (CDAI greater than 150) and inactive (CDAI less than 150) disease at randomization; patients with active disease were analyzed as part of a subgroup analysis. The trials were conducted in the United States and Europe and had very few inclusions but used different definitions of remission.

The trials took places at multiple centers in the United States,56,79 Canada,56 and Europe.64,78 One trial occurred at a single center in the United States.77 One trial occurred in the United States and Canada.56 The trials occurred during the 1970s through 1990s with the most recent publication in 1994.^77^ Trial duration ranged from 6^64^ to 17 weeks.56 77 The minimum eligibility age was 18 years in 3 trials and 15 years in two trials.56 78

Four trials required a minimum CDAI of 150 and one trial required at least two bowel movements a day to indicate active disease.78 Maximum CDAI inclusion criteria included 400,^79^ 450^56,77^ and no upper limit.64 The trial that required at least two bowel movements per day excluded patients with more than five bowel movements per day or any patient with fever, inability to work, or other symptoms indicative of severe disease.78 Disease activity related exclusions were rare. One study excluded patients with abscess,64 another excluded patients with an extensive resection.77 Disease location requirements included ileal disease,64 small bowel disease,78 and colonic disease.77

Remission was defined as a CDAI less than 150 in one trial.64 Another trial used CDAI less than 150 as part of a composite outcome included clinical events.56 Two trials required CDAI less than 150 combined with a 50^79^ or 70^77^ point decrease in the CDAI. The trial that required bowel movements per day for inclusion defined remission based on a review of the clinical notes and endoscopic records.78

Most trials prohibited patients from taking therapies that were not assigned as part of the trial. No trial specifically excluded patients with prior use of any medication, although exclusion of patients taking immunomodulators, aminosalicylates, or corticosteroids one week to 90 days before randomization occurred in three trials.77-79

#### Population Characteristics

The trial64 that included patients with active and inactive disease at randomization did not report the population characteristics separately by disease activity and is not included in the population characteristics summary. The four remaining trials randomized 710 participants (Appendix D, Evidence Table 3). The proportion of male participants in each trial group ranged from 27 to 67 percent. Only two trials56,77 commented on the percentage of Caucasians, which ranged from 90 to 100 percent among all groups. Only one trial reported on smoking (“smoker”),79 ranging between 29 and 50 percent across the four groups. Two trials reported mean age at enrollment with means of 30 and 37 years with the other two trials reporting median age at enrollment of 31 and 38 years. All trials reported duration of disease, ranging between 3.3 and 9.9 years (mean) and 3.5 and 7 years (median). All but one trial77 reported on disease location: ileal-only location ranged between 23 and 100 percent, ileocolonic location between 44 and 85 percent, and colonic location between 9 and 25 percent. All trials reported baseline CDAI, ranging between 205 and 277 (mean) and 153 and 177 (median). We derived the value of 153 from the trial78 that included participants based on bowel movements per day. None of the trials reported concurrent medication use. Prior medication use was reported in two trials56,79: aminosalicylate use was 17 and 38 percent and prior corticosteroids use was 16 and 38 percent.

#### Key Points

Table 19 summarizes the strength of evidence for the trials evaluating aminosalicylates in terms of remission induction. We found at least moderate strength of evidence or a clinically meaningful difference in the following comparisons:

- Aminosalicylates (mesalamine at least 3.2 g daily, or sulfasalazine) were more effective than placebo in inducing a remission at weeks 16-17 (absolute RD, 12 to 25 percent; placebo rate, 18 to 36 percent). (SOE: Low)
- Sulfasalazine (3 g/day) was more effective than placebo in inducing a remission at week 104 (absolute RD, 14 percent; placebo rate, 8 percent). (SOE: Low)
- Sulfasalazine (1 g/15 kg) was more effective than placebo in healing fistulas at 17 weeks in patients with actively draining fistulas (absolute RD in fistula closure, 11 percent; placebo rate, 11 percent). (SOE: Low)

Table 19 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating aminosalicylates to induce remission among patients with active Crohn's disease at randomization

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
Comparison | Outcome | Number of Trials (Participants) | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect Strength of Evidence
ASA vs. placebo-wks 2-3 | Disease activity measures | 5 (330)56 64 78 | Medium | Inconsistent | Direct | Imprecise | Favors neither RD, -8 to 9%; placebo rate, 8 to 79% SOE: Low
ASA (mesalamine ≥ 3.2 g daily or sulfasalazine) vs. placebo-wks 16-17 | Disease activity measures | 5 (456)56 64 77 79 | Medium | Consistent | Direct | Imprecise | Favors ASA RD, 12 to 25%; placebo rate, 18 to 36% SOE: Low
ASA (mesalamine < 3.2 g daily) vs. placebo-wk 16 | Disease activity measures | 5 (302)78 79 | Medium | Consistent | Direct | Imprecise | Favors neither RD, 2 to 6%; placebo rate, 18 to 25% SOE: Low
Sulfasalazine vs. placebo – wk 104 | Disease activity measures | 1 (112)64 | High | Unknown (single trial) | Direct | Precise | Favors sulfasalazine RD, 14%; placebo rate, 8% SOE: Low
Sulfasalazine vs. placebo-wk 17 | Fistula response | 1 (18)55 | High | Unknown (single trial) | Direct | Imprecise | Favors sulfasalazine RD in fistula closure, 11%; placebo rate, 11% SOE: Low

ASA = aminosalicylates; RD = risk difference; SOE = strength of evidence; vs. = versus; wk = week

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

#### Monotherapy Versus Placebo

##### Aminosalicylates Versus Placebo

###### Disease Activity Measures

Five RCTs involving 678 patients met the inclusion criteria.56,64,77-79 Table 20 summarizes the effects of aminosalicylate therapy to induce remission (see also Appendix D, Evidence Table 4). A meta-analysis was not performed due to variability in aminosalicylate preparation, doses, outcome definitions, and outcome time points. Four of five trials clinically favored aminosalicylates over placebo at one or more time points but only two trials reported statistical significance at the last reported time point.64,79

Table 20 Randomized controlled trials comparing the efficacy of aminosalicylates with placebo to induce remission among patients with active Crohn's disease at randomization

Author, Year | Followup (Weeks) | Main Intervention (Dose), n | Total Dose (g/day) | Comparison, n | Remission Definition | Remission Rate (%)
Summers, 1979^56^ | 3 | Sulfasalazine (1 g/15 kg/day), 74 | 1g/15 kg | Placebo, 77 | CDAI<150^†^ | 20% vs. 11%
Summers, 1979^56^ | 17 | Sulfasalazine (1 g/15 kg/day), 74 | 1 g/15 kg | Placebo, 77 | CDAI<150^†^ | 42% vs. 30%
Malchow, 1984^64^ | 3 | Sulfasalazine (3 g/day), 54 | 3 | Placebo, 58 | CDAI<150^‡^ | 87% vs. 79%^*^
Malchow, 1984^64^ | 16 | Sulfasalazine (3 g/day), 54 | 3 | Placebo, 58 | CDAI<150^‡^ | 57% vs. 36%^*^
Malchow, 1984^64^ | 104 | Sulfasalazine (3 g/day), 54 | 3 | Placebo, 58 | CDAI<150^‡^ | 22% vs. 8%^*^
Rasmussen, 1987^78^ | 2 | Mesalamine (1500 mg every 24 hr), 30 | 1.5 | Placebo, 37 | CDAI decrease by >33% | 0% vs. 8%
Rasmussen, 1987^78^ | 16 | Mesalamine (1500 mg every 24 hr), 30 | 1.5 | Placebo, 37 | CDAI decrease by >33% | 27% vs. 25%
Singleton, 1993^79^ | 16 | Mesalamine (1 g every 24 hr), 80 | 1 | Placebo, 80 | CDAI≤150 and 50-pt decrease | 23% vs. 18%
Singleton, 1993^79^ | 16 | Mesalamine (2 g every 24 hr), 75 | 2 | Placebo, 80 | CDAI≤150 and 50-pt decrease | 24% vs. 18%
Singleton, 1993^79^ | 16 | Mesalamine (4 g every 24 hr), 75 | 4 | Placebo, 80 | CDAI≤150 and 50-pt decrease | 43% vs. 18%^*^
Tremaine, 1994^77^ | 16 | Mesalamine (800 mg every 6 hr), 20 | 3.2 | Placebo, 18 | CDAI<150 and 70-pt decrease | 45% vs. 22%

CDAI = Crohn's Disease Activity Index; g = gram; HBI = Harvey-Bradshaw Index; hr = hour; kg = kilogram; mg = milligram; pt = point; vs. = versus

* Study report significant difference at 0.05 alpha level. For Malchow 1984,^64^ significance level does not specify time point in the 104 week trial – thus all time points are marked as significant for a given comparison where appropriate

† One component of a composite outcome.

‡ One component of a composite outcome including CDAI criteria (decrease or less than 100 points increase during first treatment, no increase during second treatment, and score less than 150 or 60-point decrease after third treatment), no need to repeat induction therapy, absence of clinical criteria (death due to Crohn's disease, fever for more than 2 weeks, need for Crohn's disease surgery, development of new fistulas or abscesses, or disease worsening by endoscopy or radiography) and not withdrawn from the trial

###### Fistula Response

One trial reported in two publications compared daily sulfasalazine with placebo.55,56 Eighteen patients had draining perianal disease at the time of randomization. Fistula response was higher in the sulfasalazine group (22 vs. 11 percent) but was not statistically significant (P > 0.05).

### Comparative Effectiveness of Therapies To Induce Remission in Adult Subgroups

We abstracted all subgroup analyses that reported on all levels of the effect-modifying variable (Appendix G). Only trials that performed a statistical test for interaction were included in this section.

#### Key Points

- We saw no consistent relationship for the interaction of a medication and disease characteristic on remission rates in adults with Crohn's disease.

#### Baseline CRP

Three trials reported results by baseline CRP in categories of high versus low CRP.37 38 45 Only one trial,38 which evaluated remission at 4 weeks for adalimumab versus placebo, reported a P-value for an interaction term. Remission rates for high-versus-low CRP (cutoff at 10 mg/L) did not differ between groups (P=0.67).

#### Baseline Corticosteroid Use

Three trials reported a subgroup analysis by baseline corticosteroid use.38 44 45 Only one trial,38 that evaluated remission at 4 weeks for adalimumab versus placebo, reported a P-value for an interaction term. Remission rates were higher for patients who were on corticosteroids at the time of randomization (P=0.01).

#### Baseline Immunomodulator Use

Four trials reported a subgroup analysis by baseline immunomodulator use.33,37-39 Two of the trials33,38 reported a P-value for an interaction term. One trial,38 evaluating 4 week remission for adalimumab versus placebo, found no effect of baseline immunomodulator use (P=0.88). Another trial, evaluating natalizumab versus placebo at 10 weeks, found higher response and remission rates for patients on baseline immunomodulators at randomization (P < 0.05).

#### Prior TNF-Alpha Inhibitor Exposure

Three trials reported a subgroup analysis by prior TNF-alpha inhibitor use.33,39,80 Only one trial,33 which evaluated natalizumab versus placebo at 10 weeks, reported a P-value for an interaction term. Response rates were higher for patients with prior TNF-alpha inhibitor exposure (P < 0.05). The trial saw no effect for remission (P > 0.05).

The following subgroup analyses were reported in the trials, but did not meet the criteria for inclusion: baseline mucosal lesions, baseline aminosalicylates, baseline antibiotic use, prior immunomodulator exposure, prior aminosalicylates exposure, prior corticosteroids exposure, disease duration, disease location, and prior Crohn's disease-related surgery.

### Quality Assessment

Out of the 53 trials included in this report that addressed KQ1, 32 percent were rated as good quality, 45 percent as fair quality, and 23 percent as poor quality (Appendix D, Evidence Table 5). All were RCTs with parallel group design by inclusion criteria for the systematic review. Among these 53 RCTs, 59 percent reported adequately generated allocation sequence. Sixty-two percent adequately concealed allocation. Seventy-two percent reported being double blinded while 28 percent were not double blinded or did not report on blinding. Seventy percent of trials reported withdrawals and dropouts while 30 percent had incomplete outcome data. Fifty-one percent of these RCTs had some form of threat to the validity of results that they reported such as not clearly differentiating between patients with active and inactive disease or not performing a statistical test for interaction in subgroup analyses. Seventy percent received pharmaceutical support with 38 percent having pharmaceutical company employed co-authors. Twenty-three percent did not report on conflicts.

## Key Question 2 Effectiveness of Therapies To Maintain Remission in Adults

Table 21 summarizes the evidence grades and specific conclusions for each comparison. Details of the evidence grades are included in the Results and in Appendix D, Table 6.

Table 21 Key findings and strength of evidence comparing pharmacologic therapies for the management of Crohn's disease to maintain remission^*^

Comparison Maximum Trial Duration | Disease Activity Measure Weeks 48-54 | Disease Activity Measure After 54 Weeks | Mucosal Healing | Hospitalizations | Surgeries | Reduction of Steroids | Fistula Response | Inflammatory Bowel Disease Questionnaire^†^
Natalizumab vs. placebo 48 weeks | Favors natalizumab; Moderate | Insufficient | Insufficient | Insufficient | Insufficient | Week 48 Favors natalizumab; Moderate | Insufficient | Week 48 Favors natalizumab; Moderate
Adalimumab vs. placebo 52 weeks | Favors adalimumab; Low | Insufficient | Insufficient | Week 52 Favors adalimumab for all-cause hospitalizations Favors neither for CD-related hospitalizations; Moderate | Week 52 Favors neither; Moderate | Week 52 Favors adalimumab; Low | Insufficient | Week 52 Favors neither; Low
CP vs. placebo 18 weeks | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 18 Favors neither; Low
Infliximab vs. placebo 52 weeks | Favors neither among all randomized Favors infliximab among responders; Low | Insufficient | Week 52 Favors infliximab; Low | Week 52 Favors infliximab; Moderate | Week 52 Favors neither among patients with fistulizing disease; Moderate | Week 52 Favors infliximab; Low | Week 40 Favors infliximab; Low | Week 52 Favors infliximab; Low
Infliximab + azathioprine vs. infliximab 104 weeks | Insufficient | Week 104 Favors neither; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Week 104 Favors neither; Low
Infliximab + azathioprine vs. infliximab + hydrocortisone 104 weeks | Favors neither; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Azathioprine vs. placebo 104 weeks | Favors azathioprine (≥1.7 mg/kg/day) Favors neither (<1 mg/kg/day); Low | Week 104 Favors azathioprine (≥1.7 mg/kg/day) Favors neither (<1 mg/kg/day); Low | Insufficient | Insufficient | Insufficient | Week 26 Favors azathioprine; Low | Insufficient | Insufficient
Azathioprine vs. budesonide 52 weeks | Favors azathioprine; Low | Insufficient | Week 52 Favors azathioprine; Moderate | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Azathioprine vs. prednisone 104 weeks | Favors azathioprine; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Azathioprine vs. sulfasalazine 104 weeks | Favors neither; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Methotrexate (IM) vs. placebo 40 weeks | Week 40 Favors methotrexate; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Budesonide vs. placebo 52 weeks | Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 52 Favors neither; Low
Prednisone vs. placebo 104 weeks | Favors neither; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
6-methyl-prednisolone vs. placebo 104 weeks | Favors 6-methyl-prednisolone; Low | Week 104 Favors 6-methyl-prednisolone; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Budesonide vs. mesalamine 52 weeks | Favors budesonide; Moderate | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 52 Favors budesonide; Moderate
Steroids (other) vs. sulfasalazine 104 weeks | Favors neither; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
6-methyl-prednisolone + sulfasalazine vs. placebo 104 weeks | Favors neither; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Steroids + sulfasalazine vs. steroids 104 weeks | Favors neither; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Steroids + sulfasalazine vs. sulfasalazine 104 weeks | Favors neither; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Mesalamine (controlled-release) vs. placebo 52 weeks | Favors mesalamine; Low | Week 104 Favors neither; Moderate | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Week 48 Favors neither; Low
Mesalamine (pH-release) vs. placebo 208 weeks | Favors mesalamine; Low | Week 104 Favors placebo; Low Week 208 Favors mesalamine; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Olsalazine vs. placebo 52 weeks | Favors neither; Moderate | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Sulfasalazine vs. placebo 104 weeks | Favors neither; Low | Week 104 Favors neither; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient

ASA = aminosalicylates; CP = certolizumab pegol; NA = not applicable; evidence grading was not conducted for this comparison and outcome; Steroids = corticosteroids; TNF = tumor necrosis factor-alpha inhibitor; vs. = versus

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

* All other comparisons and outcomes were graded as insufficient because there were no eligible trials.

† Patient reported outcomes were measured by the Inflammatory Bowel Disease Questionnaire except where indicated by a footnote. Scores for the Inflammatory Bowel Disease Questionnaire range from 32 to 224, with higher scores indicating better quality of life.36

### Natalizumab

#### Trial Design and Population Characteristics

One placebo-controlled RCT reported in two publications evaluated the efficacy of natalizumab to maintain remission subsequent to an induction trial reported in KQ1 (Appendix D, Evidence Tables 7 and 8).33,81 The maintenance trial randomized 339 patients who responded to natalizumab or placebo as defined by a 70-point decrease from baseline CDAI at weeks 10 and 12, had an absolute CDAI less than 220 at week 12 and who did not require an intervention.33 The induction responders were randomized to the same dose used in the induction trial. The induction non-responders were randomized, but their results were not reported. Participants received an intravenous infusion every 4 weeks of natalizumab 300 mg (n=168) or placebo (n=171) for 44 weeks and were followed for 48 weeks. Concomitant medications allowed during the trial period included aminosalicylates, corticosteroids, immunomodulators, and antibiotics.

The population characteristics are described in KQ1.^81^ There were no major differences between the induction and maintenance populations. However, the placebo and natalizumab groups differed in the maintenance trial. Placebo patients were more likely to be female, more likely to smoke, and had a 13-point higher mean CDAI at the beginning of the maintenance trial.33

#### Key Points

Table 22 summarizes the strength of evidence for the trial evaluating natalizumab in terms of maintenance of remission. We found at least moderate strength of evidence or a clinically meaningful difference for the following areas:

- Natalizumab (300 mg every 4 weeks) was more efficacious than placebo to maintain remission at week 48 among patients who achieved at least a response during a natalizumab induction trial (48-week absolute RD, 33 percent; placebo rate, 22 percent). (SOE: Moderate)
- Natalizumab patients were less likely to require steroids than placebo among patients in a sustained remission at 48 weeks (absolute RD, 27 percent; placebo rate, 15 percent). (SOE: Moderate)
- Natalizumab was favored over placebo as measured by a patient-reported outcome at week 48, although both natalizumab and placebo patients had lower scores at the end of the trial (absolute between-group difference in change in mean IBDQ from randomization, 19 points; placebo mean change in IBDQ, -23 points). (SOE: Moderate)

Table 22 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating natalizumab to maintain remission

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
| | | Risk of Bias | Consistency | Directness | Precision
Natalizumab vs. placebo–wk 48 | Disease activity measures | 1 (339)33 | Medium | Unknown (single study) | Direct | Precise | Favors natalizumab RD, 33%; placebo rate, 22% SOE: Moderate
Natalizumab vs. placebo–wk 48 | Reduction of steroids | 1 (143)33 | Medium | Unknown (single study) | Direct | Precise | Favors natalizumab RD, 27%; placebo rate, 15% SOE: Moderate
Natalizumab vs. placebo–wk 48 | Patient-reported outcomes | 1 (217)81 | Medium | Unknown (single study) | Direct | Precise | Favors natalizumab Absolute between-group difference in change in mean IBDQ from randomization to induction trial, 19 pts; placebo change in mean IBDQ, -23 pts SOE: Moderate

IBDQ = Inflammatory Bowel Disease Questionnaire; pts = points; pts = points; RD = absolute risk difference; SOE = strength of evidence; wk = week

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

Scores for the Inflammatory Bowel Disease Questionnaire range from 32 to 224, with higher scores indicating better quality of life.36

#### Monotherapy Versus Placebo

##### Natalizumab Versus Placebo

###### Disease Activity Measures

At week 48, 33 percent more natalizumab patients were in remission than placebo, which was clinically meaningful and statistically significant (Table 23).33 The persistence of remission from the time of randomization was also reported. Of the 250 patients who were in remission at the time of randomization, 39 percent in the natalizumab group and 15 percent in the placebo group (24 percent difference) remained in remission for all measures through 48 weeks (trial reported P < 0.001). We presented details of the results in Appendix D, Evidence Table 9.

Table 23 Randomized controlled trials comparing the efficacy of natalizumab with placebo to maintain remission at week 48 in patients with Crohn's disease who have at least achieved a response to a prior induction trial

Author, Year | Followup (Weeks) | Main Intervention (Dose), n | Comparison, n | Remission Rate (CDAI<150, No Need for Rescue Therapy, and No Missing Data), %
Sandborn, 2005^33^ | 48 | Natalizumab (300 mg IV every 4 wks), 168 | Placebo, 171 | 55% vs. 22%^*^

IV = intravenous; wks = weeks

* Trial reported P < 0.05

###### Reduction of Steroids

Of the 143 patients in sustained remission at 48 weeks, 42 percent of the natalizumab group no longer required treatment with corticosteroids compared with 15 percent in the placebo group. This finding is clinically meaningful and statistically significant (P < 0.001).33

###### Patient-Reported Outcomes

Patient-reported outcomes were reported in a separate publication from the disease activity measures.81 Forty-eight weeks after the initiation of maintenance therapy, the mean change in IBDQ decreased in both groups, but the decrease was not as substantial for natalizumab and the difference met the clinically meaningful difference threshold. At 48 weeks, the mean total IBDQ score dropped from 184 to 180 in the natalizumab group and from 179 to 156 in the placebo group, the difference between groups was statistically significant when measured from the value at the beginning of the induction trial (P < 0.001), but was not reported from the beginning of the maintenance trial. There were no meaningful differences between any component of the SF-36 between randomization for the maintenance trial and week 48.

### TNF-Alpha Inhibitors

Eight trials evaluated a TNF-alpha inhibitor as monotherapy or in combination with another drug to maintain remission. Six of the trials compared TNF-alpha inhibitor monotherapy with placebo: two evaluated adalimumab,82,83 one evaluated certolizumab pegol,84 and three evaluated infliximab.85-87 The two combination therapy trials focused on the role of azathioprine with infliximab. One trial compared a combination of infliximab and azathioprine versus infliximab with hydrocortisone pretreatment.88 An azathioprine withdrawal trial89 examined a combination of infliximab and azathioprine versus infliximab alone in patients that previously controlled their disease for at least 6 months using a combination of infliximab and azathioprine.

#### Trial Design

Eight RCTs reported in 16 publications met the inclusion criteria (Appendix D, Evidence Table 7).82-97 Trials reported in multiple publications included an adalimumab trial with four publications,82,90,95,96 an infliximab trial with four publications,86,91,93,94 and another infliximab trial with three publications.87,92,97

Six of the eight RCTs were blinded.82-87 The two combination therapy trials were not blinded. In the hydrocortisone pre-treatment trial, the patients were aware which medications they were taking but the investigators were not.88 In the azathioprine withdrawal trial, all participants and study personnel were aware of the treatment assignment.89 All trials except the azathioprine withdrawal trial89 had run-in periods when all patients received the study drug prior to randomization. The duration of the run-in period ranged between 2 and 12 weeks. Subsequent to the run-in period, the trials randomized all patients or those that had a clinical response (CDAI drop of 70 to 100 points) or remission (CDAI<150). In five trials, an inclusion criteria at the start of the trial (before the run-in) was a CDAI of 220 to 450.^82-86^ All trials reported a CDAI outcome except one study that used fistula closure at 14 weeks as a measure of response.87

All trials allowed patients to take medications to treat their Crohn's disease as long as they were using them at stable doses during the trial. Most studies allowed for stable doses of prednisone (20-30mg or less), thiopurines or methotrexate, aminosalicylates, and antibiotics at entry. Two studies evaluating adalimumab and certolizumab pegol allowed for prior exposure to an TNF-alpha inhibitor more than 12 weeks from randomization82 84 as long as the patients responded to the drug and did not have an adverse reaction. Two trials83 88 did not permit prior TNF-alpha inhibitor use. In the azathioprine withdrawal trial, all participants had used infliximab and azathioprine for at least 6 months prior to randomization.89 Because infliximab was the first approved TNF-alpha inhibitor agent for Crohn's disease, patients in the three infliximab trials85-87 would not have received TNF-alpha inhibitors prior to the induction or run-in period.

Not all patients had entered remission by using the study drug. In two trials,83 85 the run-in period occurred as part of induction trials that are described in KQ1.^37^ 43 These two trials differ from the others because patients who experienced clinical remission85 or response83 using placebo were eligible for randomization. In three trials, all patients who received the induction doses during the run-in period were randomized, even if they did not experience clinical remission or response after the induction dose.82,86,87 The results for the responders are reported because these results are most representative of maintenance of remission consistent with our definition for this KQ. The results for all patients who were randomized, representing the intention to treat population, are also summarized when available.

In four studies randomized patients were not required to complete the study using the assigned treatment.82,83,86,87 Patients who relapsed were permitted to withdraw from the trial and initiate active drug or increase the dose of the drug. Patients who withdrew were considered not in remission for the disease activity endpoints. For hospitalization and surgery, one study considered patients as hospitalized or as having had surgery among those who withdrew and initiated active drug or increased dose,90 while another allowed patients to switch to active drug or increase dose and were not considered treatment failures in the hospitalization and surgery analyses.94 For other outcomes including fistula response, reduction of steroids, and patient-reported outcomes, it was unclear if patients who withdrew were considered treatment failures. To account for the patients who were no longer followed under ideal RCT conditions (unaware of treatment assignment and disease activity unrelated to treatment), the risk of bias was considered Medium or High for these trials. Early withdrawal and downgrading of the risk of bias for outcomes other than disease activity occurred for adalimumab at 8 weeks82,95 and infliximab at 12 weeks.86,87,94

Five out of eight trials took place in North America,82,83,85-87 while seven out of eight took place in Europe.82,83,85-89 All of the trials but one88 was multicenter in design. The starting year of enrollment ranged between 1995 and 2004. Following randomization, the maximum trial duration was 52 weeks (range, 18 to 104 weeks). All trials were limited to adult patients with Crohn's disease, although one trial89 included patients 16 years and older.

#### Population Characteristics

The trials randomized 1,798 patients (Appendix D, Evidence Table 8). Males comprised 44 percent of participants. Response to open-label induction was 64 percent for the largest adalimumab maintenance trial,82 64 percent for the only certolizumab pegol trial,84 and 59 percent for the largest infliximab maintenance trial.86 Response to open-label drug in the infliximab fistula trial was 69 percent.87 The remission rate of those who enrolled from the primary adalimumab induction trial37 into a subsequent maintenance trial83 was 20 percent. Only one trial reported race,90 which was more than 90 percent Caucasians. Of trials that reported current smokers, rates ranged from 32 to 45 percent. Median duration of disease ranged from 5 to 12 years. Mean age at enrollment ranged between 34 to 38 years old. Disease location distribution was as follows: ileal, 16 to 30 percent; ileocolonic, 46 to 62 percent; and colonic 17 to 39 percent. Mean CDAI after the run-in period ranged from 152 to 170, reflecting that some patients attained a remission while others attained only a response. Drug use rates were as follows: concomitant aminosalicylates, 38 to 74 percent; corticosteroids, 21 to 56 percent; thiopurine, 11 to 42 percent, and methotrexate, 0 to 12 percent.

#### Key Points

Table 24 summarizes the strength of evidence for the trials evaluating a TNF-alpha inhibitor in terms of maintenance of remission. We found at least moderate strength of evidence or a clinically meaningful difference in the following comparisons:

- Adalimumab was more efficacious than placebo in maintaining a remission at week 52 among patients who had at least a response to open-label adalimumab (range in week 52 absolute RD, 11 to 39 percent; placebo rate range, 12 percent to 44 percent). (SOE: Low)
- Adalimumab was superior to placebo in decreasing Crohn's disease-related hospitalization rates during a 52-week period in patients who have achieved at least a response to open-label drug (HR, 0.4; 95% CI, 0.2 to 0.7). (SOE: Moderate)
- Adalimumab and placebo did not differ in decreasing surgical rates during a 52-week period in patients who had achieved at least a response to open-label drug (surgery rates, 0.3 percent for adalimumab group and 4.1 percent for placebo group). (SOE: Moderate)
- Adalimumab was superior to placebo in maintaining a steroid-free state at 52 weeks in patients who had achieved at least a response to open-label drug and were able to come off steroids (absolute RD in steroid-free state, 10 to 31 percent; placebo rate, 6 to 57 percent). (SOE: Low)
- Certolizumab pegol (400 mg every 4 weeks) was more efficacious than placebo to maintain remission at week 18 among patients who had at least a response to open-label certolizumab pegol (absolute RD, 19 percent; placebo rate, 29 percent). (SOE: Low)
- Infliximab was more efficacious than placebo to maintain remission at week 52 among patients who had at least a response to open-label infliximab (absolute RD, 6 to 25 percent; placebo rate, 15 to 35 percent). (SOE: Low)
- Infliximab was superior to placebo in achieving mucosal healing at week 52 in patients who have achieved at least a response to open-label drug (absolute RD, 26 to 43 percent; placebo rate, 7 to 18 percent). (SOE: Low)
- Infliximab was superior to placebo in decreasing Crohn's disease-related hospitalization rates during a 52-week period (including both responders and non-responders to induction) (9 to 23 per 100 patients in the infliximab group, 19 to 38 per 100 patients in the placebo group). (SOE: Moderate).
- Infliximab was no different from placebo in decreasing Crohn's disease-related surgeries during a 52-week period (including both responders and non-responders to induction) (3% in the infliximab group, 8% in the placebo group). (SOE: Moderate)
- Infliximab was superior to placebo in decreasing surgical rates during a 40-week period in patients with active fistulizing disease who had achieved fistula response to open-label drug (number of surgeries and procedures per 100 patients, 65 surgeries/procedures for infliximab and 126 surgeries/procedures per 100 patients for placebo). (SOE: Moderate)
- Infliximab was superior to placebo in reducing corticosteroid use at week 52 in patients who had achieved at least a response to open-label drug (discontinuation of steroids while in remission, OR, 4.2; 95% CI, 1.5 to 11.5). (SOE: Low)
- Infliximab was superior to placebo in closing fistulas at week 40 in adults with Crohn's disease who had achieved an initial fistula response to open-label drug (absolute RD, 17 percent; placebo rate, 19 percent). (SOE: Low)
- Infliximab was superior to placebo in improving patient-reported outcomes at weeks 28 and 52 in patients who had achieved at least one response to open-label drug (absolute between-group difference in change in mean IBDQ from baseline [prior to open-label run-in], -5 to 23 points; placebo mean change in IBDQ, -31 to 9 points). (SOE: Low)

Table 24 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating a TNF-alpha inhibitor to maintain remission

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
| | | Risk of Bias | Consistency | Directness | Precision
Adalimumab vs. placebo–wk 52 | Disease activity measures | 2 (554)82 83 95 | High | Consistent | Direct | Precise | Favors adalimumab RD range, 11% to 39%; placebo rate range, 12% to 44% SOE: Low
Adalimumab vs. placebo–wk 52 | Hospitalization | 1 (778)90 | Medium | Unknown (single study) | Direct | Precise | Favors adalimumab for all-cause hospitalizations Favors neither for Crohn's disease related hospitalizations RD range, -6% to -13%; placebo rate range, 16% to 25% SOE: Moderate
Adalimumab vs. placebo–wk 52 | Surgery | 1 (778)90 | Medium | Unknown (single study) | Direct | Precise | Favors neither RD, -3.4%; placebo rate, 3.8% SOE: Moderate
Adalimumab vs. placebo–wk 52 | Reduction of steroids | 2 (219)82 83 | High | Consistent | Direct | Precise | Favors adalimumab RD, 10% to 31%; placebo rate, 6% to 57% SOE: Low
Adalimumab vs. placebo–wk 52 | Patient-reported outcomes | 2 (554)95 96 | High | Consistent | Direct | Precise | Favors neither Absolute between-group difference in change in mean IBDQ from randomization, 14 to 22 pts; placebo mean change, -10 to -25 pts SOE: Low
CP vs. placebo–wk 18 | Disease activity measures | 1 (428)84 | Medium | Unknown (single study) | Indirect | Precise | Favors CP RD, 19%; placebo rate, 29% SOE: Low
CP vs. placebo–wk 18 | Patient-reported outcomes | 1 (424)84 | Medium | Unknown (single study) | Indirect | Precise | Favors neither Difference in final adjusted mean IBDQ, 8 pts; final placebo mean, 163 pts SOE: Low
Infliximab vs. placebo–wk 52 | Disease activity measures | 1 (573)86 94 | High | Unknown (single study) | Direct | Imprecise | Favors neither among all randomized Favors infliximab among responders to induction RD range, 6% to 25%; placebo rate, 15% to 35% SOE: Low
Infliximab vs. placebo–wk 52 | Mucosal healing | 1(58)91 94 | High | Unknown (single study) | Direct | Precise | Favors infliximab RD, 26% to 43%; placebo rate, 7% to 18% SOE: Low
Infliximab vs. placebo–wk 40, 52 | Hospitalization | 2 (855)92 94 | Medium | Consistent | Direct | Precise | Favors infliximab Crohn's disease-related hospitalizations per 100 patients, 9 to 23 in infliximab group, 19 to 38 in placebo group SOE: Moderate
Infliximab vs. placebo–wk 52 | Surgery | 1 (573)94 | Medium | Unknown (single study) | Direct | Precise | Favors neither Rate of Crohn's disease-related surgery, 3%; placebo rate, 8% SOE: Moderate
Infliximab vs. placebo (patients with fistulas) –wk 40 | Surgery | 1 (195)92 | Medium | Unknown (single study) | Direct | Precise | Favors infliximab Rate of Crohn's disease-related surgery per 100 patients, 65; placebo rate per 100 patients, 126 SOE: Moderate
Infliximab vs. placebo–wk 52 | Reduction of steroids | 1 (325)86 | High | Unknown (single study) | Direct | Precise | Favors infliximab RD, 20%; placebo rate, 9% SOE: Low
Infliximab vs. placebo–wk 40 | Fistula response | 1 (282)87 | Medium | Unknown (single study) | Indirect | Precise | Favors infliximab RD, 17%; placebo rate, 19% SOE: Low
Infliximab vs. placebo–wks 36-52 | Patient-reported outcomes | 3 (603)85 87 93 | High | Inconsistent | Direct | Imprecise | Favors infliximab Absolute between-group difference in change in median IBDQ -5 to 23 pts; placebo mean change, -31 to 9 pts SOE: Low
Infliximab + azathioprine vs. infliximab–wk 104 | Disease activity measures | 1 (80)89 | High | Unknown (single study) | Direct | Imprecise | Favors neither Absolute difference [with regard to need for infliximab stoppage or change in dosage interval], 5%; infliximab alone rate, 55% SOE: Low
Infliximab + azathioprine vs. infliximab–wk 104 | Mucosal healing | 1 (49)89 | High | Unknown (single study) | Direct | Imprecise | Favors neither RD for absence of ulcers, 3%; infliximab alone rate, 61% SOE: Low
Infliximab + azathioprine vs. infliximab–wk 104 | Patient-reported outcomes | 1 (80)89 | High | Unknown (single study) | Direct | Imprecise | Favors neither Difference in overall median IBDQ, -2 pts; infliximab only median, 176 pts SOE: Low
Infliximab + azathioprine vs. infliximab + hydrocortisone IV premedication–wk 52, 104 | Disease activity measures | 1 (46)88 | High | Unknown -(single study) | Direct | Imprecise | Favors neither RD across time points, -5%; infliximab and hydrocortisone rate range, 77% to 84% SOE: Low

CI = 95% confidence interval; CP = certolizumab pegol; HR = hazard ratio; IBDQ = Inflammatory Bowel Disease Questionnaire; NA = not applicable; OR = odds ratio; pts = points; RD = absolute risk difference; SOE = strength of evidence; TNF = tumor necrosis factor; wk = week

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

Scores for the Inflammatory Bowel Disease Questionnaire range from 32 to 224, with higher scores indicating better quality of life.36

#### Monotherapy Versus Placebo

##### TNF-Alpha Inhibitors Versus Placebo

###### Disease Activity Measures

Six trials published in nine publications reported on disease activity.82-86,94,95,97 Table 25 summarizes the effects of TNF-alpha inhibitor therapy versus placebo to maintain remission at week 52. Among all patients who were randomized and among those who responded to induction dosing, adalimumab was consistently favored over placebo according to the clinically meaningful difference and statistical significance. Infliximab was favored over placebo only among responders to induction dosing.

Table 25 Randomized controlled trials comparing the efficacy of TNF-alpha inhibitor therapy with placebo or another treatment to maintain remission in patients with Crohn's disease who had a response to the study medication prior to randomization

Author, Year | Time Point | Main Intervention (Dose), n | Comparison, n | Remission Rate (CDAI<150 and Remained on Randomized Treatment or Did Not Require Rescue Therapy), %
Colombel, 2007^82^ | 52 wks | Adalimumab (40 mg sc every 2 wks), 172 | Placebo, 170 | 36% vs. 12%^*^
Colombel, 2007^82^
Colombel, 2007^82^ | 52 wks | Adalimumab (40 mg sc every wk), 157 | Placebo, 170 | 41% vs. 12%^*^
Sandborn, 2007^83^ | 52 wks | Adalimumab (40 mg sc every 2 wks), 19 | Placebo, 18 | 79% vs. 44%^*^
Sandborn, 2007^83^
Sandborn, 2007^83^ | 52 wks | Adalimumab (40 mg sc every wk), 18 | Placebo, 18 | 83% vs. 44%^*^
Schreiber, 2007^84^ | 18 wks | Certolizumab pegol (400 mg sc every 4 wks), 216 | Placebo, 212 | 48% vs. 29%^*^
Hanauer, 2002^86^ | 52 wks | Infliximab (5 mg/kg IV every 8 wks), 113 | Placebo, 110 | 30% vs. 15%^*^
Hanauer, 2002^86^ | 52 wks | Infliximab (10 mg/kg IV every 8 wks), 112 | Placebo, 110 | 40% vs. 15%^*^
Rutgeerts, 1999^85^ | 28 wks | Infliximab (10 mg/kg IV every 8 wks), 37 | Placebo, 36 | 64% vs. 35%
Van Assche, 2008^89^ | 104 wks | Infliximab (5 mg/kg IV every 8 wks) + azathioprine (pre-trial dose), 40 | Infliximab (5 mg/kg IV every 8 wks), 40 | 40% vs. 45%
Mantzaris, 2009^88^ | 52 wks | Infliximab (5 mg/kg IV every 8 wks) + azathioprine (2-2.5 mg/kg/day), 21 | Infliximab (5 mg/kg IV every 8 wks) + hydrocortisone (250 mg), 22 | 79% vs. 84%
Mantzaris, 2009^88^ | 52 wks
Mantzaris, 2009^88^ | 104 wks | Infliximab (5 mg/kg IV every 8 wks) + azathioprine (2-2.5 mg/kg/day), 21 | Infliximab (5 mg/kg IV every 8 wks) + hydrocortisone (250 mg), 22 | 72% vs. 77%

CDAI = Crohn's Disease Activity Index; IV = intravenous infusion; mg = milligrams; mg/kg = milligrams per kilogram; NR = not reported; sc = subcutaneous injections; vs. = versus; wk = week

* Trial reported P < 0.05

Three trials (totaling 889 patients) compared infliximab or adalimumab with placebo at 52 weeks.82,83,86,94,95 The efficacy differed between the analyses that included responders to induction and all randomized patients. Two of these trials reported results for all randomized patients and responders to induction dosing. In the analysis of all randomized patients for the adalimumab trial at 52 weeks, remission rates were 51, 49, and 38 percent for the 40 mg every other week, 40 mg weekly, and placebo groups, respectively (P < 0.05 for both groups vs. placebo).95 The responders to induction dosing also had clinically and statistically significant results at 52 weeks.82 In contrast, the infliximab trial did not have clinically or statistically significant results when all randomized patients were analyzed at 52 weeks (41 vs. 35 percent),94 but did have clinically and statistically significant results in the responders to induction analysis.86 In the third trial83 that randomized patients who achieved remission in an induction trial,37 remission rates were clinically and statistically significantly higher in the adalimumab compared with the placebo group. A meta-analysis was not performed because two trials randomized all patients after induction dosing and one trial randomized those in remission after an induction trial.

In two trials, the last reported time point was earlier than 48 weeks: 18 weeks for certolizumab pegol84 and 28 weeks for infliximab.85 Both trials found clinically meaningful differences compared with placebo, although only the certolizumab pegol results were statistically significant. An infliximab trial that included women with rectovaginal fistulas was not included because it reported changes in median CDAI scores rather than remission and the last reported time point was 40 weeks.97

###### Mucosal Healing

One infliximab trial94 included 58 patients with ulceration at baseline who received an additional colonoscopy at 52 weeks.91 In the analysis of all randomized patients (44 vs. 18 percent; P=0.04)94 and the analysis of responders to induction (50 vs. 7 percent; P=0.007),91 the infliximab groups were more likely to have clinically meaningful and statistically significant complete mucosal healing (absence of ulcers) at 52 weeks compared with placebo.

###### Hospitalization

Three trials reported on hospitalizations.90,92,94 Adalimumab and infliximab were consistently favored over placebo at 52 weeks according to the clinically meaningful threshold and were statistically significant.

One trial90 with 778 randomized participants compared adalimumab with placebo at 52 weeks with regard to Crohn's disease-related and all-cause hospitalizations. The results were clinically meaningful for all-cause but not Crohn's disease-related hospitalizations. Those who received the drug either every other week or weekly had a 14 and 12 percent risk of 12-month all-cause hospitalization respectively, compared with 25 percent for placebo (P < 0.01 for both comparisons with placebo based on a log-rank test). The 12-month risk of Crohn's disease-related hospitalizations was 10 and 7 percent, respectively, compared with 16 percent for placebo (P < 0.02 for both comparisons with placebo based on a log-rank test). The clinically meaningful results for all-cause but not Crohn's disease-related hospitalizations was also found in analysis restricted to responders to induction therapy.

Two infliximab trials reported on hospitalizations.92,94 One infliximab trial94 randomized 573 participants and evaluated the rate of hospitalization. At 52 weeks, the rates of Crohn's disease-related hospitalization per 100 patients were 23, 24, and 38 in the 5 mg/kg infliximab, 10 mg/kg infliximab, and placebo groups, respectively (P < 0.05 for both comparisons). The finding was clinically meaningful and statistically significant for both doses of infliximab.

The infliximab trial that included only patients with draining fistulas92 compared infliximab with placebo among the 282 randomized patients and the 195 patients to had a response to the induction dose. Among the 282 randomized patients, hospitalizations occurred in 9 percent of the infliximab and 19 percent of the placebo group by week 40. This difference was clinically meaningful and statistically significant for all randomized patients and among those who responded to the induction dose (P < 0.05).

###### Surgery

The same three trials that reported on hospitalizations also reported on surgeries.90,92,94 Compared with placebo, there was no difference in the occurrence of surgery according to the clinically meaningful threshold when considering the rate equivalent of the 10 percent difference threshold to be a difference in 10 per 100 patients between groups. All three trials reported statistically significant findings.

One trial compared adalimumab with placebo with regard to Crohn's disease-related surgeries in 778 randomized patients.90 Surgeries for abscess drainage and seton placement were not counted as events.90 At 52 weeks, fewer Crohn's disease-related surgeries occurred in the groups who received adalimumab every other week and weekly compared with placebo (0.4 and 0.8 vs. 3.8 per 100 patients; P < 0.05 for all comparisons vs. placebo), but the differences were not clinically meaningful. Statistically significant but not clinically meaningful differences were also observed among those that responded to induction therapy.

Another trial94 evaluated the rate of hospitalization in 573 patients randomized to infliximab or placebo. At 52 weeks, the number of patients requiring Crohn's disease-related intra-abdominal surgeries in the 5 and 10 mg scheduled infliximab groups combined was 11 of 385 (3%), compared with 14 of 188 (8%) in the placebo group, which was not clinically meaningful but was statistically significant. Reported values are for both responders and non-responders to induction; values for responders only were not reported separately.

One trial with 195 total responders (among 282 total randomized patients with fistulas) compared infliximab with placebo.92 Among patients who responded to open-label infliximab, infliximab maintenance had a significantly decreased rate of all surgeries and procedures (65 vs. 126 surgeries per 100 patients; P < 0.05) as well as major surgeries (2 vs. 11 surgeries per 100 patients; P < 0.05) at 40 weeks compared with those who received placebo. The findings were clinically meaningful for all surgeries but not major surgeries. Results for all randomized patients were similar.

###### Reduction of Steroids

Three trials reported on reduction in steroids, including two adalimumab82 83 and one infliximab trials.86 All three found clinically meaningful differences favoring the TNF-alpha inhibitor over placebo.

One trial82 randomized patients to placebo, 40 mg of adalimumab every other week, and 40 mg of adalimumab weekly. Of the 198 responders who did not require steroids at randomization, the proportion of individuals who remained steroid-free at 52 weeks was 6, 29, and 23 percent, respectively. Adalimumab was clinically favored and statistically significant compared with placebo (P < 0.001 for both adalimumab groups compared with placebo). In a smaller trial,83 21 of 55 patients were on systemic steroids or budesonide at randomization and had results available at 52 weeks. At 52 weeks, rates of steroid discontinuation for the placebo, 40 mg every other week and 40 mg every week groups were 57, 67, and 88 percent, respectively. The difference was clinically meaningful, but statistical significance was not provided.

One trial with 335 participants compared infliximab (5 mg every 8 weeks or 10 mg every 8 weeks) with placebo.86 At 52 weeks, three times as many patients in the infliximab groups combined had discontinued corticosteroids while in remission compared with placebo (29 vs. 9 percent; OR, 4.2; 95% CI, 1.5 to 11.5). This finding was clinically meaningful and statistically significant.

###### Fistula Response

One trial87 with 282 participants compared infliximab with placebo for fistula healing. At 40 weeks, infliximab was favored over placebo according to the clinically meaningful and statistically significant thresholds. All of the patients had a fistula for at least 3 months' duration and received open-label induction with infliximab as part of the trial. The trial assessed response (50 percent reduction in the number of draining fistulas) 10 and 14 weeks after starting induction, and randomized 195 total responders to infliximab or placebo. Eight weeks after randomization, all patients who had lost response (both groups) could receive infliximab. At week 40 after randomization, the proportion of patients in the placebo group with complete fistula healing (complete absence of draining fistulas) was 19 percent, compared with 36 percent in the infliximab group (P=0.009). This finding was clinically meaningful and statistically significant.

###### Patient-Reported Outcomes

Six trials with 2,581 participants compared TNF-alpha inhibitors with placebo.82-85,87,93,95 There was not a consistent finding that TNF-alpha inhibitors were favored over placebo according to the clinically meaningful difference. A meta-analysis was not performed because some studies reported the mean IBDQ values at baseline and followup while others reported the percent of patients who achieved a particular IBDQ threshold, two studies reported at less than 48 weeks84,85 and one study included only fistulizing disease patients.87

Two trials with 554 participants compared adalimumab with placebo.95,96 In both trials, there was no clinically meaningful difference between adalimumab and placebo at 52 weeks when all randomized patients were analyzed.95 Among patients who responded to induction,96 clinically meaningful results were observed for some patient-reported outcomes.

One trial compared certolizumab pegol with placebo.84 At 18 weeks after randomization, patients on certolizumab pegol did not have clinically meaningful adjusted mean IBDQ scores than those on placebo (final IBDQ scores 171 versus 163, respectively). This trial did not report baseline IBDQ scores by intervention group, so the change in IBDQ per group was not calculable.

Three trials compared infliximab with placebo.85 87 93 In the largest trial, there was not a clinically meaningful difference in the IBDQ score at 52 weeks in the 5 mg/kg group, but there was a meaningful difference in the 10 mg/kg group, although neither was statistically significant.93 At 52 weeks, the proportion of patients in the 5 and 10 mg/kg infliximab groups with an IBDQ greater than 170 was 38 and 46 percent, compared with 35 percent in the placebo group (P > 0.05). One trial87 looked exclusively at fistulizing Crohn's disease and did not find a clinically meaningful difference between 5 mg/kg infliximab and placebo at 40 weeks. Another infliximab trial85 had its final time point at 36 weeks and observed a decrease in both groups although the decrease was less in the infliximab group and met the clinically meaningful difference threshold (8-point median decrease from baseline in the 10 mg/kg infliximab group compared with a 31-point decrease in the placebo group), although statistical significance was not reported. A meta-analysis was not performed for the infliximab trials because only one trial reported at 52 weeks.93

#### Combination Therapy Versus Monotherapy

##### Infliximab and Azathioprine Versus Infliximab Alone

###### Disease Activity Measures

One trial89 with 80 participants examined Crohn's patients who were in an extended remission (>6 months) on combination infliximab and azathioprine. The trial then randomized patients to continue or discontinue azathioprine and studied them for 104 weeks. Both the patients and study personnel where aware of the treatment assignment for the duration of the trial. Twenty-four out of 40 (60 percent) patients in the azathioprine continuation group and 22 out of 40 (55 percent) patients in the discontinuation group required a change in the infliximab dosing interval or stoppage of infliximab, the outcome most closely related to disease activity. The difference between groups was not clinically meaningful.

###### Mucosal Healing

The above trial89 performed baseline and end of trial colonoscopy in 49 out of 80 randomized patients (all but one patient had colonic lesions at baseline). Sixteen out of 25 (64 percent) participants on a combination of infliximab and immunomodulators showed an absence of ulcers, compared with 14 out of 23 (61 percent) participants on infliximab alone. There was no clinically meaningful difference in mucosal healing between groups.

###### Patient-Reported Outcomes

This trial89 reported that the median IBDQ from week 8 through week 104 did not differ between the two groups. Baseline IBDQ was not provided and the IBDQ at each measure was not reported so the change in IBDQ could not be calculated.

#### Combination Therapy Versus Combination Therapy

##### Infliximab and Azathioprine Versus Infliximab With Hydrocortisone Intravenous Premedication

###### Disease Activity Measures

In one trial of 46 participants88 rates of remission at 12 and 24 months were not clinically meaningfully different between the groups. At 12 months, 79 percent in the infliximab and azathioprine group and 84 percent in the infliximab with hydrocortisone premedication group were in remission. At 24 months, rates of remission were 72 and 77 percent, respectively. This trial had two major limitations. The trial blinded the investigators, but not the subjects. Additionally, the groups were not well balanced with respect to prior Crohn's medication use. All of the patients in the infliximab and azathioprine group were azathioprine naïve, whereas only six out of 23 patients in the infliximab and corticosteroids group were azathioprine naïve.

### Thiopurines

We identified six trials. Five trials56,98-101 compared azathioprine with placebo, two trials56,102 compared azathioprine with corticosteroids, and one trial56 compared azathioprine with sulfasalazine. No trials used 6-mercaptopurine. One trial is also included in the corticosteroids and aminosalicylates sections.56

#### Trial Design

Per our inclusion criteria, all six trials were RCTs (Appendix D, Evidence Table 7). In all trials, patients were in remission at the time of randomization. All trials were multicenter with five trials98-102 conducted in Europe, and one in the U.S.56 The years of enrollment ranged from 1971 to 2009. In one trial the azathioprine dose was 1 mg/kg/day,56 in two trials the dose was 2.0 mg/kg/day,99,103 and in one trial the dose was 2.0 to 2.5 mg/kg/day.102 Prior to randomization, patients were in remission for one month,102 6 months,100 24 months,101 or 42 months.98 Two trials56,99 did not report duration of remission prior to randomization. In three trials,98,100,101 patients had to have been in remission on azathioprine. Trial duration ranged between 6 and 18 months. Relapse was defined by CDAI scores in four trials56,98,101,102 while two trials used an unnamed disease activity score.99,100

One trial required steroid dependence for entry, but with a prednisone dose less than 30 mg.102 One trial101 excluded patients receiving corticosteroids or aminosalicylates at the time of randomization. One trial98 excluded patients taking more than 10 mg of prednisone in addition to any immunosuppressant, aminosalicylates, or antibiotic. The remainder allowed prednisone or aminosalicylates at trial entry. Three trials excluded patients with previous surgery,98,101,102 while the other trials allowed remission to be achieved with medication or surgery. One trial excluded patients with left-sided colonic disease.102

#### Population Characteristics

Half of the patients were males (Appendix D, Evidence Table 8). The mean ages ranged from 28 to 40 years and the median ages ranged from 31 to 47 years. Race was reported in one trial (92 percent Caucasian).56 All trials reported mean duration of disease at randomization ranging from 2 to 11 years. Mean CDAI ranged from 39 to 132 across all reporting trial groups. Two trials reported smoking histories ranging from 42 to 92 percent.98,102 In trials that reported disease distribution, ileal involvement ranged from 3 to 60 percent, ileocolonic 11 to 67 percent, and colonic 7 to 63 percent. Concomitant steroid use ranged from 5 to 100 percent across trial groups, while concomitant aminosalicylates use was excluded in two trials,98,102 allowed in two trials,100,101 and use was not mentioned or unclear in two trials.99,100

#### Key Points

Table 26 summarizes the strength of evidence for the trials evaluating a thiopurine in terms of maintenance of remission. We found at least moderate strength of evidence or a clinically meaningful difference for the following comparisons:

- Azathioprine (1.7 to 2.1 mg/kg/day) was more efficacious than placebo to maintain remission at weeks 52, 78, and 104 (range in absolute RD, 13 to 39 percent; placebo rate, 47 to 79 percent). (SOE: Low)
- Azathioprine was superior to placebo in reducing steroid use at week 26 in adults with Crohn's disease participating in a maintenance trial (absolute reduction in prednisone use from baseline, 9.4 mg; placebo reduction, 6.1 mg). (SOE: Low)
- Azathioprine was more efficacious than budesonide to maintain remission at week 52 (absolute RD, 15 percent; budesonide rate, 64 percent). (SOE: Low)
- Azathioprine was more efficacious than prednisone to maintain remission at week 52 (absolute RD, 12 percent; prednisone rate, 57 percent). (SOE: Low)
- Azathioprine was superior to budesonide in achieving mucosal healing at week 52 in adults with Crohn's disease participating in a maintenance trial (absolute RD for absence of ulcers, 55 percent; budesonide rate, 5 percent). (SOE: Moderate)

Table 26 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating a thiopurine to maintain remission

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
| | | Risk of Bias | Consistency | Directness | Precision
Azathioprine (1 mg/kg/d) vs. placebo - wks 52, 104 | Disease activity measures | 1 (155)56 | Medium | Unknown (single study) | Direct | Imprecise | Favors neither RD, -11 to 5%; placebo rate, 40 to 64% SOE: Low
Azathioprine (1.7 to 2.1 mg/kg/d) vs. placebo - wks 52, 78, 104 | Disease activity measures | 3 (163)98 100 101 | Medium | Inconsistent | Direct | Imprecise | Favors azathioprine RD, 13 to 39%; placebo rate, 47 to 79% SOE: Low
Azathioprine vs. placebo - wk 26 | Reduction of steroids | 1 (20)104 | Medium | Unknown (single study) | Indirect | Precise | Favors azathioprine Absolute reduction in prednisone use from baseline, 9.4 mg; placebo reduction, 6.1 mg SOE: Low
Azathioprine vs. budesonide - wk 52 | Disease activity measures | 1 (77)102 | Medium | Unknown (single study) | Direct | Imprecise | Favors azathioprine RD, 15%; budesonide rate, 64% SOE: Low
Azathioprine vs. prednisone - wk 52 | Disease activity measures | 1 (115)56 | High | Unknown (single study) | Direct | Imprecise | Favors azathioprine RD, 12%; prednisone rate, 57% SOE: Low
Azathioprine vs. prednisone - wk 104 | Disease activity measures | 1 (115)56 | High | Unknown (single study) | Direct | Imprecise | Favors neither Wk 104: RD, -3%; corticosteroid rate, 32% SOE: Low
Azathioprine vs. budesonide - wk 52 | Mucosal healing | 1 (77)102 | Medium | Unknown (single study) | Direct | Precise | Favors azathioprine RD for absence of ulcers, 55%; budesonide rate, 5% SOE: Moderate
Azathioprine vs. sulfasalazine - wks 52, 104 | Disease activity measures | 1 (115)56 | High | Unknown (single study) | Direct | Imprecise | Favors neither RD range, -2% to 7%; sulfasalazine rate range, 31% to 62% SOE: Low

mg = milligrams; RD = absolute risk difference; vs. = versus; wk = weeks

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

#### Monotherapy Versus Placebo

##### Azathioprine Versus Placebo

###### Disease Activity Measures

Five trials56,98-101 with 328 patients compared azathioprine with placebo (Table 27 and Appendix D, Evidence Table 9). Among the trials using 2 mg/kg/day of azathioprine, azathioprine was favored over placebo. The two trials that used less than 2 mg/kg/day did not find a clinically meaningful difference between azathioprine and placebo.56,98

Table 27 Randomized controlled trials comparing the efficacy of thiopurines with placebo or another treatment to maintain remission in patients with inactive Crohn's disease

Author, Year | Time Point | Main Intervention (Dose), n | Comparison, n | Relapse Definition | Remission Rate, %
Willoughby, 1971^99^ | 24 wks | Azathioprine (2 mg/kg/d), 5 | Placebo, 5 | Significant deterioration in clinical state requiring change in treatment | 80% vs. 40%
O'Donoghue 1978^100^ | 1 yr | Azathioprine (2 mg/kg/d), 24 | Placebo, 27 | Significant deterioration in clinical state requiring change in treatment | 95% vs. 59%
Summers, 1979^56^ | 1 yr | Azathioprine (1 mg/kg/d), 54 | Placebo, 101 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 69% vs. 64%
Summers, 1979^56^ | 2 yr | Azathioprine (1 mg/kg/d), 54 | Placebo, 101 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 29% vs. 40%
Villien, 2004^101^ | 1 yr | Azathioprine (median dose 2.1 mg/kg), 14 | Placebo, 15 | CDAI rise of >75 and CDAI >150, or increased disease activity requiring new medication or surgical therapy | 86% vs. 47%^*^
Lemann, 2005^98^ | 18 mos | Azathioprine (median dose 1.7 mg/kg), 40 | Placebo, 43 | CDAI > 250, CDAI of 150-250 on 3 consecutive weeks with at least 75 points above baseline, or need for Crohn's abdominal surgery | 92% vs. 79%
Mantzanis, 2009^102^ | 1 yr | Azathioprine (2.0-2.5 mg/kg/d),38 | Budesonide (6-9 mg/d), 39 | CDAI increase of > 100 points from baseline and > 150 | 79% vs. 64%
Summers, 1979^56^ | 1 yr | Azathioprine (1 mg/kg/d), 54 | Prednisone (1-4 mg/kg), 61 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 69% vs. 57%
Summers, 1979^56^ | 2 yr | Azathioprine (1 mg/kg/d), 54 | Prednisone (1-4 mg/kg), 61 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 29% vs. 32%
Summers, 1979^56^ | 1 yr | Azathioprine (1 mg/kg d), 54 | Sulfasalazine (1-2 g/15 kg), 58 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 69% vs. 62%
Summers, 1979^56^ | 2 yr | Azathioprine (1 mg/kg d), 54 | Sulfasalazine (1-2 g/15 kg), 58 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 29% vs. 31%

CDAI = Crohn's Disease Activity Index; d = day; g = gram; kg = kilogram; mg = milligrams; mos = months; NA = not applicable; vs. = versus; wks = weeks; yr = year

* Study reported P < 0.05

Three trials98,100,101 involving 163 patients assessed the efficacy of withdrawing azathioprine in patients who were in remission for at least 6 months using azathioprine (range 6 to 42 months). Two of these trials included 80 participants and found azathioprine to be clinically and statistically superior to placebo at 52 weeks.100,101 One trial98 found that azathioprine was clinically, but not statistically favored compared with placebo at 78 weeks. The trial that did not find statistical significance included lower doses of azathioprine (1.7 mg/kg/day) and patients had been in remission for a longer duration of time prior to randomization (minimum of 42 months) than the statistically significant trials. Meta-analysis was not performed because only two studies100,101 analyzed doses of 1.7 mg/kg/day or above at 52 weeks.

One trial56 involving 155 patients included patients who had inactive disease within the year before randomization that had been induced medically, as part of an induction trial reported in the same publication, or surgically. No meaningful differences between azathioprine and placebo were found at 1 or 2 years. The trial used a low dose of azathioprine at 1 mg/kg/day. Post-operative patients may behave differently from those who are medically induced into remission, but no subgroup analysis was reported to examine if disease activity differed by method of remission induction.

One trial99 included steroid-dependent patients at randomization and involved steroid tapering as part of the design, but did not report results at 48 weeks or later. Disease activity results were clinically meaningful at 24 weeks but the trial did not report statistical significance. The trial included ten patients in total.

###### Reduction in Steroids

One trial with 20 participants compared azathioprine with placebo.104 Average baseline daily prednisone dose was 19 mg in the azathioprine group and 17 mg in placebo. The trial compared the numerical reduction (in grams) in dose of steroid between the groups at 26 weeks. Patients on azathioprine had a 15.5 mg mean reduction in steroids compared with 6.1 mg for patients given placebo (P < 0.05). Although there was a substantial decrease in prednisone dose in both groups, and especially azathioprine, it is not possible to assess the clinical meaning given our definitions.

#### Monotherapy Versus Monotherapy

##### Azathioprine Versus Corticosteroids

###### Disease Activity Measures

We included two trials56,102 with 192 patients (Table 27). In both trials, the remission rate at 1 year was higher in the azathioprine group according to the clinically meaningful threshold but was not statistically significant.56,102 At 2 years there was no clinically meaningful difference.56

###### Mucosal Healing

One trial with 77 participants compared azathioprine with budesonide at 52 weeks.102 The rate of complete mucosal healing (absence of ulcers) was 60 percent in the azathioprine group and 5 percent in the budesonide group, which was clinically meaningful and statistically significant (P < 0.0001). Comparisons using the CDEIS also favored azathioprine.

##### Azathioprine Versus Sulfasalazine

###### Disease Activity Measures

One trial56 with 115 patients was included (Table 27). There was no meaningful difference between the azathioprine and sulfasalazine groups at 1 or 2 years.

### Methotrexate

One trial105 randomized 76 patients to intramuscular methotrexate or placebo (Appendix D, Evidence Table 9). All patients had previously taken part in an induction trial reported in KQ1.^63^

#### Trial Design

The trial blinded both participants and study personnel and randomized adults with Crohn's disease who were in a steroid-free remission (CDAI < 150) at entry (Appendix D, Evidence Table 7). Patients achieved remission through methotrexate at 25 mg intramuscular weekly for a period of 16 to 24 weeks. The trial randomized participants to receive weekly intramuscular injections of either 15 mg of methotrexate or placebo for a period of 40 weeks. The primary outcome measure was relapse, defined as an increase in the CDAI of at least 100 points or the initiation of steroids or thiopurines. Immunomodulators, corticosteroids, infliximab, aminosalicylates, antibiotics, tube feeding, and parental nutrition were not allowed.

#### Population Characteristics

A total of 76 patients participated (Appendix D, Evidence Table 8). Males ranged from 40 to 61 percent across both groups. Mean age ranged from 32 to 38 years. Forty-two to 50 percent were smokers. Mean duration of disease ranged from 4 to 8 years. Mean CDAI ranged from 84 to 94. Ranges of disease location were as follows: ileal disease 31 to 45 percent, ileocolonic disease 28 to 44 percent, and colonic disease 25 to 28 percent. Prior thiopurine use was less than 5 percent in both groups.

#### Key Points

Table 28 summarizes the strength of evidence for the trial evaluating methotrexate in terms of remission maintenance. We found at least moderate strength of evidence or a clinically meaningful difference for the following comparison:

- Intramuscular methotrexate (15 mg weekly) was more efficacious than placebo to maintain remission at week 40 (absolute RD, 26 percent; placebo rate, 39 percent). (SOE: Low)

Table 28 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating methotrexate to maintain remission

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
| | | Risk of Bias | Consistency | Directness | Precision
Methotrexate (intramuscular) vs. placebo – wk 40 | Disease activity measures | 1 (76)105 | Medium | Unknown (single study) | Indirect | Precise | Favors methotrexate RD, 26%; placebo rate, 39% SOE: Low

RD = absolute risk difference; SOE = strength of evidence; vs. = versus; wk = weeks

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

#### Monotherapy Versus Placebo

##### Methotrexate Versus Placebo

###### Disease Activity Measures

One RCT105 evaluated the difference between methotrexate and placebo to maintain remission in patients with Crohn's disease (Table 29). Sustained remission was not reported in the trial. Relapses were less common in the methotrexate than placebo group. The difference in relapse met the clinically meaningful and statistically significant thresholds at 40 weeks.

Table 29 Remission rates reported in randomized controlled trials comparing the efficacy of methotrexate with placebo in patients with inactive Crohn's disease

Author, Year | Followup (Weeks) | Main Intervention (Dose), n | Comparison, n | Relapse Definition | Remission Rate, %
Feagan, 2000^105^ | 40 | Methotrexate (15 mg/wk IM), 36 | Placebo, 40 | (≥100 increase in CDAI or use of a thiopurine or steroid | 65% vs. 39%^*^

CDAI = Crohn's Disease Activity Index; IM = intramuscular; mg/wk = milligrams per week; vs. = versus

* Trial reported difference in relapse rates significant at 0.05 alpha level

### Corticosteroids

Eleven trials evaluated the efficacy of corticosteroids to maintain remission in patients with inactive Crohn's disease (Appendix D, Evidence Table 7). Nine trials compared corticosteroids with placebo.56,64,106-112 Two trials56,64 compared corticosteroids with aminosalicylates in addition to placebo, one trial compared budesonide directly with mesalamine,113 and one trial75 compared a combination of corticosteroids and aminosalicylates with aminosalicylates alone. Seven trials used budesonide 3 to 6 mg per day, two trials used prednisone 0.25 mg/kg per day alone and in combination with sulfasalazine,56,75 and two trials used 6-methylprednisolone 0.25 mg/kg per day to 8 mg per day alone112 or in combination with sulfasalazine.64

Five trials also appear in KQ1. One trial64 reported relapse rates in the population with inactive disease at randomization with the active disease patients reported in KQ1. Four trials included patients who had previously participated in an induction trial.65,66,68,69 One trial is also included in the thiopurines and aminosalicylates sections.56

#### Trial Design

Nine of the 11 trials were described as double-blind. One study blinded investigators, but not patients,113 and blinding was not reported in one study.56 Of the 11 trials, four trials were conducted in the U.S. and North America, seven in Europe, one in Australia, one in Asia, and one in Africa (Appendix D, Evidence Table 7). One was a single center trial113 and the remaining ten took place at multiple sites. Seven trials reported enrollment dates; these trials took place between 1971 and 1996. Six trials had run-in periods from 4 to 12 weeks in duration; in these trials the participants were already in remission due to a separate prior trial comparing corticosteroids with placebo;75,106,108-111 in one trial75 the run-in period was part of the same trial comparing corticosteroids or corticosteroids and aminosalicylates. Five trials did not have a run-in period,56,64,107,112,113 with one trial113 requiring all patients to taper their corticosteroids dose before beginning the trial. Median trial duration was 52 weeks (range from 13 to 104 weeks).

Nine trials included patients with CDAI less than or equal to 150 while one trial107 defined inactive disease as having a CDAI less than or equal to 200 and another64 included patients with both active (CDAI ≥ 150) and inactive (CDAI < 150) disease initially, and then analyzed them separately (the active disease results are reported in KQ1). Two trials106,109 required a minimum duration of remission beyond the induction period, from 8 to 10 weeks. Two trials required patients to be steroid-dependent.107,113 All trials reported a minimum age of inclusion of 18 years, with three exceptions,56,75,112 which did not report a minimum age. No trials required any other prior medication use aside from what is mentioned above. One trial113 excluded patients who had been maintained on mesalamine or azathioprine at the time of enrollment. Another trial106 excluded patients who had received mesalamine at any time, or immunomodulator or corticosteroids at the time of the initial run-in trial.65 All trials used CDAI as the outcome measure. No trials used alternative activity indices.

#### Population Characteristics

The description of the population characteristics exclude one trial64 because it included both active and inactive disease in the baseline population. These ten trials randomized a total of 1,028 patients across all trial groups (Appendix D, Evidence Table 8). The proportion of male participants in each trial group ranged from 22 to 67 percent. Only two trials56,107 reported on race, with Caucasian participants making up 91 to 98 percent across all trial groups. Only one trial113 reported smoking (with no definition given), which ranged between 82 and 86 percent across both trial groups. Six trials reported mean age at enrollment, which ranged between 32 and 41 years. Seven trials reported mean duration of disease, which ranged between 3 to 9 years. Seven trials reported disease location: ileal location ranged between 33 and 89 percent, ileocolonic location between 11 and 49 percent, and colonic location between 0 and 33 percent. No trials reported perianal location. All but two trials reported mean baseline CDAI,75,112 ranging from 65 to 139. Only one trial reported concurrent medication use:107 aminosalicylates in 48 to 49 percent of participants and thiopurine in 9 to 15 percent of participants across both trial groups. One trial reported prior thiopurine use113 in 41 to 43 percent of all participants across both trial groups. Of the six trials where patients were in an induction trial involving corticosteroids, corticosteroid frequency ranged from 80 to 100 percent across groups of five trials. In one trial75 corticosteroids use prior to entry ranged from 47 to 52 percent across groups.

#### Key Points

Table 30 summarizes the strength of evidence for the trials evaluating corticosteroids to maintain remission. We found at least moderate strength of evidence or a clinically meaningful difference for the following comparisons:

- 6-methylprednisolone was more efficacious than placebo to maintain remission at weeks 54 and 104 (absolute RD across time points, 11 to 12 percent; placebo rate, 32 to 48 percent). (SOE: Low)
- Budesonide (6 mg daily) was more efficacious than mesalamine (3 g daily) to maintain remission at week 52 (absolute RD, 27 percent; mesalamine rate, 18 percent). (SOE: Moderate)
- Budesonide was favored over mesalamine as measured by the IBDQ quality of life outcome at 12 months, although both budesonide and mesalamine patients had lower quality of life at the end of the trial than at the beginning (absolute between-group difference in change in mean IBDQ, 30 to 36 points; mesalamine mean change, -51 to -76 points). (SOE: Moderate)

Table 30 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating a corticosteroid to maintain remission

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
| | | Risk of Bias | Consistency | Directness | Precision
Budesonide vs. placebo--wk 52 | Disease activity measures | 5 (557)106 108-111 | Medium- | Inconsistent | Direct | Imprecise | Favors neither 3mg pooled RR, 1.0; CI, 0.8 to 1.2; placebo rate, 33% to 40% 6mg pooled RR, 1.2; CI, 0.9 to 1.5; placebo rate, 33% to 42% SOE: Low
Budesonide vs. placebo--wks 13 and 52 | Patient-reported outcomes | 2 (122)107 111 | Medium | Consistent | Direct | Imprecise | Favors neither Absolute between-group difference in change in mean IBDQ from baseline, 2 to 11 pts; placebo mean change, -4 to -31 pts SOE: Low
Prednisone vs. placebo--wks 54 and 104 | Disease activity measures | 1 (162)56 | High | Unknown (single study) | Direct | Imprecise | Neither favored RD across time points, 0% to 9%; placebo rate, 59% to 72% SOE: Low
6-methylprednisolone vs. placebo--wks 54 and 104 | Disease activity measures | 1 (118)64 | High | Unknown (single study) | Direct | Imprecise | Favors 6-methylprednisolone RD across time points, 11% to 12%; placebo rate, 32% to 48% SOE: Low
Budesonide vs. mesalamine--wk 52 | Disease activity measures | 1 (57)113 | Medium | Unknown (single study) | Direct | Precise | Favors budesonide RD, 27%; mesalamine rate, 18% SOE: Moderate
Budesonide vs. mesalamine--wk 52 | Patient-reported outcomes | 1 (57)113 | Medium | Unknown (single study) | Direct | Precise | Favors budesonide Absolute between-group difference in change in mean IBDQ, 30 to 36 pts; mesalamine mean change, -51 to -76 pts SOE: Moderate
Prednisone or 6-methylprednisolone vs. sulfasalazine --wks 54, 104 | Disease activity measures | 2 (248)56 64 | High | Consistent | Direct | Imprecise | Favors neither RD across time points, 5% to 9%; ASA rate, 37% to 67% SOE: Low
6-methylprednisolone + sulfasalazine vs. placebo--wks 54, 104 | Disease activity measures | 1 (108)64 | High | Unknown (single study) | Direct | Imprecise | Favors neither RD across time points, 2% to 5%; placebo rate, 32% to 48% SOE: Low
Steroids + sulfasalazine vs. steroids--wks 26-54, 104 | Disease activity measures | 2 (181)64 75 | Medium | Inconsistent | Direct | Imprecise | Favors neither RD across time points, -9% to -6%; steroid rate, 22% to 60% SOE: Low
6-methylprednisolone + sulfasalazine vs. sulfasalazine--wks 54, 104 | Disease activity measures | 1(119)64 | High | Unknown (single study) | Direct | Imprecise | Favors neither RD, -3% to -2%; sulfasalazine rate, 37% to 55% SOE: Low

ASA = aminosalicylates; CI = 95% confidence interval; IBDQ = Inflammatory Bowel Disease Questionnaire; NA = not applicable; pt = points; RD = absolute risk difference; RR = relative risk; SOE = strength of evidence; steroid = corticosteroids; vs. = versus; wk = weeks

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable.

Scores for the Inflammatory Bowel Disease Questionnaire range from 32 to 224, with higher scores indicating better quality of life.36

#### Monotherapy Versus Placebo

##### Corticosteroids Versus Placebo

###### Disease Activity Measures

Nine trials, including 854 participants, compared corticosteroids with placebo (Table 31; Appendix D, Evidence Table 9).56,64,106-112 Six trials used budesonide 3 to 6 mg per day, two64,112 used 6-methylprednisolone, and one56 used prednisone. In two trials107,112 the final time point was at 26 weeks or less.

Table 31 Remission rates reported in randomized controlled trials comparing the efficacy of corticosteroids with placebo or another treatment in patients with inactive Crohn's disease

Author, Year | Followup (Weeks) | Main Intervention (Daily Dose), n | Comparison (Daily Dose), n | Relapse Definition | Remission Rate (%)
Lofberg, 1996^110^ | 52 | Budesonide (3 mg), 31 | Placebo, 27 | CDAI > 150 and ≥ 60-pt increase in CDAI from baseline, or acute deterioration in status | 26 vs. 37%
Lofberg, 1996^110^ | 52 | Budesonide (6 mg), 32 | Placebo, 27 | CDAI > 150 and ≥ 60-pt increase in CDAI from baseline, or acute deterioration in status | 41 vs. 37%
Greenberg, 1996^111^ | 52 | Budesonide (3 mg), 33 | Placebo, 36 | CDAI > 150 and ≥ 60-pt increase in CDAI from baseline | 30 vs. 33%
Greenberg, 1996^111^ | 52 | Budesonide (6 mg), 36 | Placebo, 36 | CDAI > 150 and ≥ 60-pt increase in CDAI from baseline | 39 vs. 33%
Ferguson, 1998^108^ | 52 | Budesonide (3 mg), 26 | Placebo, 27 | CDAI > 150 and ≥ 60-pt increase in CDAI from baseline, or any deterioration requiring a different medication or surgery | 54 vs. 40%
Ferguson, 1998^108^ | 52 | Budesonide (6 mg), 22 | Placebo, 27 | CDAI > 150 and ≥ 60-pt increase in CDAI from baseline, or any deterioration requiring a different medication or surgery | 52 vs. 40%
Gross, 1998^109^ | 52 | Budesonide (3 mg), 84 | Placebo, 95 | CDAI > 150 on 2 consecutive weeks | 33 vs. 35%
Cortot, 2001^107^ | 13 | Budesonide (6 mg), 59 | Placebo, 58 | CDAI > 200 and ≥ 60-pt increase in CDAI from baseline | 68 vs. 35%^*^
Hanauer, 2005^106^ | 52 | Budesonide (6 mg), 54 | Placebo, 54 | CDAI ≥ 150 and ≥ 60-pt increase in CDAI from baseline or clinical deterioration | 53 vs. 42%
Summers, 1979^56^ | 54 | Prednisone (0.25 mg/kg), 61 | Placebo, 101 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 72 vs. 72%
Summers, 1979^56^ | 104 | Prednisone (0.25 mg/kg), 61 | Placebo, 101 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 68 vs. 59%
Malchow, 1984^64^ | 54 | 6-Methylprednisolone (8 mg), 66 | Placebo, 52 | CDAI > 150 or clinical deterioration | 60 vs. 48%
Malchow, 1984^64^ | 104 | 6-Methylprednisolone (8 mg), 66 | Placebo, 52 | CDAI > 150 or clinical deterioration | 43 vs. 32%
Brignola, 1988^112^ | 26 | 6-Methylprednisolone (0.25 mg/kg), 9 | Placebo, 9 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 weeks | 89 vs. 22%
Mantzaris, 2003^113^ | 52 | Budesonide (6 mg), 29 | Mesalamine (3 g), 28 | CDAI > 150 and ≥ 100-pt increase in CDAI | 45 vs. 18%^*^
Summers, 1979^56^ | 54 | Prednisone (0.25 mg/kg), 61 | Sulfasalazine (0.5 mg/kg), 58 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 72 vs. 67%
Summers, 1979^56^ | 104 | Prednisone (0.25 mg/kg), 61 | Sulfasalazine (0.5 mg/kg), 58 | CDAI > 150 and ≥ 100-pt increase in CDAI for 2 consecutive weeks, or a need for surgery, development of a fistula, fever, or radiologic progression | 68 vs. 59%
Malchow, 1984^64^ | 54 | 6-Methylprednisolone (8 mg), 66 | Sulfasalazine (3 g), 63 | CDAI > 150 or clinical deterioration | 60 vs. 55%
Malchow, 1984^64^ | 104 | 6-Methylprednisolone (8 mg), 66 | Sulfasalazine (3 g), 63 | CDAI > 150 or clinical deterioration | 43 vs. 37%
Malchow, 1984^64^ | 54 | 6-Methylprednisolone (8 mg) + sulfasalazine (3 g), 56 | Placebo, 52 | CDAI > 150 or clinical deterioration | 53 vs. 48%
Malchow, 1984^64^ | 104 | 6-Methylprednisolone (8 mg) + sulfasalazine (3 g), 56 | Placebo, 52 | CDAI > 150 or clinical deterioration | 34 vs. 32%
Singleton, 1979^75^ | 26 | Prednisone (0.25 mg/kg) + sulfasalazine (1 mg/15 kg), 29 | Prednisone (0.25 mg/kg), 30 | CDAI > 150 and CDAI 100-point increase | 16 vs. 22%
Malchow, 1984^64^ | 54 | 6-Methylprednisolone (8 mg) + sulfasalazine (3 g), 56 | 6-Methylprednisolone (8 mg), 66 | CDAI > 150 or clinical deterioration | 53 vs. 60%
Malchow, 1984^64^ | 104 | 6-Methylprednisolone (8 mg) + sulfasalazine (3 g), 56 | 6-Methylprednisolone (8 mg), 66 | CDAI > 150 or clinical deterioration | 34 vs. 43%
Malchow, 1984^64^ | 54 | 6-Methylprednisolone (8 mg) + sulfasalazine (3 g), 56 | Sulfasalazine (3 g), 63 | CDAI > 150 or clinical deterioration | 53 vs. 55%
Malchow, 1984^64^ | 104 | 6-Methylprednisolone (8 mg) + sulfasalazine (3 g), 56 | Sulfasalazine (3 g), 63 | CDAI > 150 or clinical deterioration | 34 vs. 37%

CDAI = Crohn's Disease Activity Index; mg = milligrams; kg = kilograms; pt = points; vs. = versus

* Trial reported significant at the 0.05 alpha level.

Two meta-analyses were conducted on five trials106 108-111 comparing budesonide 3 and 6 mg per day with placebo at 52 weeks (Figure 8). Four of the trials included participants from induction trials summarized in KQ1.^106^ 108 110 111 There was no difference between budesonide and placebo to maintain remission at 52 weeks for the 3 mg dose (RR of remission, 1.0; 95% CI, 0.8 to 1.2) nor the 6 mg dose (RR of remission, 1.2; 95% CI, 0.9 to 1.5). There was no significant heterogeneity among the trials for either dose (I-squared, 0). The excluded budesonide trial found that 33 percent more patients who switched to 6 mg budesonide were in remission compared with placebo at 13 weeks, which was clinically and statistically significant.107

Figure 8 Pooled relative risk of a remission^*^ * In all trials, relapse was defined as a Crohn's Disease Activity Index more than 150 with at least a 60-point increase from baseline. Ferguson 1998, Lofberg 1996, and Hanauer 2005 also defined relapse to include clinical deterioration. All patients who did not relapse were considered in remission for the analysis. of Crohn's disease at week 52 comparing budesonide with placebo

CI = confidence interval; mg = milligrams; RR = relative risk

Note: Boxes indicate individual trial point estimates. The box size denotes the weight of the trial, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each trial. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate.3 mg Test for heterogeneity: Q=1.83 with 3 degrees of freedom (p=0.61).6 mg Test for heterogeneity: Q=0.30 with 3 degrees of freedom (p=0.96).3 mg and 6 mg I-squared statistic = 0%.

Figure 8 is a forest plot type of diagram depicting the pooled relative risk, with 95% confidence interval, of a relapse at week 52 comparing budesonide with placebo. Five trials are included, which are Loftberg 1996, Greenberg 1996, Ferguson 1998, Gross 1998, and Hanauer 2005. The information presented in the plot shows the relative risk, number of events of relapse on budesonide, total number on budesonide in the study, number of events of relapse on placebo, and total number of placebo in the study. The results are analyzed by the dose of budesonide. For 3mg of budesonide, there are 4 trials included with a pooled relative risk of 1.0 (95% CI 0.7 to 1.3). For 6mg of budesonide, there are 4 trials included with a pooled relative risk of 1.2 (95% CI, 0.9 to 1.6). We did not find any substantial heterogeneity.

There was no meaningful difference in relapse rates in the prednisone trial at 54 or 104 weeks.56

More 6-methylprednisolone patients were in remission compared with placebo at 54 and 104 weeks, although statistical significance was not reported.64 A 6-methylprednisolone trial that reported its last measure at 26 weeks also favored 6-methylprednisolone to placebo according to the clinically meaningful threshold, but did not report statistical significance.112

###### Patient-Reported Outcomes

Two trials with 122 participants compared budesonide with placebo and did not find clinically meaningful differences.107,111 In a trial111 of patients who had participated in an 8-week induction trial, the IBDQ decreased in all groups and there were not clinically meaningful nor statistically significant differences. At 12 months, IBDQ decreased from 185 to 156 in the budesonide 3 mg group, 184 to 161 in the budesonide 6 mg group, and 181 to 150 in the placebo group.114 Another trial107 examined steroid-dependent patients and measured the IBDQ at week 13. The mean IBDQ score rose from 162 to 169 in the budesonide group and dropped from 158 to 154 in the placebo group, which was not clinically meaningful but was statistically significant.107

#### Monotherapy Versus Monotherapy

##### Corticosteroids Versus Aminosalicylates

###### Disease Activity Measures

Three trials,56,64,113 involving 305 participants, included comparisons of corticosteroid therapy with aminosalicylates to maintain remission from 52 to 104 weeks (Table 31). An investigator- but not patient-blinded trial of 6 mg budesonide found a clinically and statistically significant difference compared with 3 g mesalamine at 52 weeks,113 but the 6-methylprednisolone64 and prednisone56 trials did not find clinically meaningful differences compared with sulfasalazine. No meta-analysis was performed because of the different formulations of corticosteroids and aminosalicylates used.

###### Patient-Reported Outcomes

In the budesonide trial, all patients reported worse quality of life at the end of the trial.113 At 1 year, mean IBDQ score decreased from 188 to 148 in the budesonide group and 186 to 110 in the mesalamine group. Budesonide was clinically and statistically (P=0.0001) favored to mesalamine, although the budesonide patients also reported feeling significantly worse.

#### Combination Therapy Versus Placebo

##### Combination of Corticosteroids and Aminosalicylates Versus Placebo

###### Disease Activity Measures

In one trial64 of 108 participants (Table 31), there was no clinically meaningful difference in remission at 54 and 104 weeks between those on 6-methylprednisolone 8 mg per day and sulfasalazine 3 g per day combination therapy and those on placebo.

#### Combination Therapy Versus Monotherapy

##### Combination of Corticosteroids and Aminosalicylates Versus Corticosteroids Alone

###### Disease Activity Measures

Two trials,64,75 including 181 participants, compared a combination of corticosteroids and sulfasalazine with corticosteroids alone to maintain remission of Crohn's disease (Table 31). Neither trial found a clinically meaningful difference.

##### Combination of Corticosteroids and Aminosalicylates Versus Aminosalicylates Alone

###### Disease Activity Measures

In one trial64 of 119 participants (Table 31), there was no clinically meaningful difference in relapse rates at 54 or 104 weeks in those randomized to the combination of 6-methylprednisolone 8 mg/day and sulfasalazine 3 g/day compared with those randomized to sulfasalazine 3 g/day alone.

### Aminosalicylates

Fourteen trials compared aminosalicylates versus placebo to maintain remission (Appendix D, Evidence Table 7).56,64,115-126 One trial64 included both those with active (CDAI greater than 150) and inactive disease (CDAI less than 150) at randomization, with the active disease group reported in KQ1. One trial is also included in the thiopurines and corticosteroids sections.56

#### Trial Design

Of the 14 trials, ten trials were conducted in Europe, four in North America and the U.S., two in Asia, and one in Africa (Appendix D, Evidence Table 7). All were multicenter trials except two,124,125 and one126 which said that patients were recruited from outpatient clinics but did not specify the study sites. Eleven trials used mesalamine; seven used pH-release mesalamine and four used controlled-release. The pH-release mesalamine begins release in the terminal ileum but is mainly released in the colon. The controlled-release mesalamine begins release in the proximal small bowel. Two trials used sulfasalazine and one used olsalazine. Mesalamine doses ranged from 1 to 4 grams daily. The starting year of enrollment was between 1971 and 2000. Three trials115,118,119 had run-in periods involving induction of remission with 6-methylprednisolone or prednisone for 4 to 8 weeks. Median trial duration was 52 weeks (range, 6 to 208 weeks).

Twelve trials included only patients with a CDAI less than 150, one with a CDAI less than 120,^126^ and one with a HBI less than 4.^121^ Five trials required a minimum duration of remission prior to the trial, ranging from 4 weeks to 24 months.116,121,122,124,126 No trials required patients to be steroid-dependent or resistant. Seven trials reported a minimum age of inclusion of 18 years, with two119,122 including those 15 years old and over, and the remaining trials not reporting a minimum age. Regarding medication use in the 1 to 3 months prior to the trials, four trials116,122,124,126 excluded patients who had used corticosteroids within this time frame, four116,118,120,122,excluded those on any other immunosuppressives, and one trial117 excluded those with recent thiopurine or cyclosporine use.

#### Population Characteristics

All of the following statistics exclude one trial64 due to its inclusion of both those with active and inactive disease in the baseline population (Appendix D, Evidence Table 8). Thirteen trials are summarized here. Another trial117 did not distinguish between those patients in medical remission and those in surgical remission when reporting population characteristics, so we included statistics on both groups in the totals below.

The included trials randomized a total of 1,825 patients across all trial groups. The proportion of male participants in each trial group ranged from 39 to 70 percent. Only one trial56 reported on race, with Caucasian participants making up 94 to 98 percent across both trial groups. Three trials117,118,121 reported smoking (“smoker” or “present smoker”), which ranged between 18 and 38 percent. Six trials reported mean age at enrollment, which ranged between 29 and 40 years. All seven trials reported mean duration of disease, which ranged between 3 and 7 years. The trials reported disease location as follows: ileal location ranged between 11 and 100 percent, ileocolonic location between 18 and 91 percent, and colonic location between 9 and 97 percent. One trial reported perianal location,122 which ranged from 11 to 14 percent. All but four trials reported baseline CDAI.115,121,122,126 Mean CDAI ranged from 48 to 89 points. One trial121 reported mean HBI values, ranging from 2.2 to 2.3 across the two groups. No trials reported concurrent medication use. Prior corticosteroid use ranged from 13 to 94 percent across three trials.119,124,125 In one trial,121 82 to 87 percent of patients were on an aminosalicylate at trial entry.

#### Key Points

Table 32 summarizes the strength of evidence for the trials evaluating aminosalicylates in terms of remission maintenance. Listed are the comparisons with at least moderate strength of evidence or a clinically meaningful difference.

- Mesalamine (controlled-release) at 3 to 4 g daily was more efficacious than placebo to maintain remission at weeks 48 to 52 (absolute RD across time points, 7 to 11 percent; placebo rate, 22 to 58 percent). (SOE: Low)
- Mesalamine (controlled-release) at 2 g daily was no more efficacious than placebo to maintain remission at week 104 (absolute RD, 6 percent, placebo rate, 58 percent). (SOE: Moderate).
- Mesalamine (pH-release) at 2.4 g daily was more efficacious than placebo to maintain remission at week 208 (absolute RD, 18 percent; placebo rate, 29 percent). (SOE: Low )
- Olsalazine at 2 g daily was no more efficacious than placebo to maintain remission at week 52 (absolute RD, 2 percent, placebo rate, 74 percent). (SOE: Moderate).

Table 32 Numbers of trials and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for trials evaluating an aminosalicylate to maintain remission

Comparison | Outcome | Number of Trials (Participants) | Domains Pertaining to Strength of Evidence | | | | Magnitude of Effect Strength of Evidence
| | | Risk of Bias | Consistency | Directness | Precision
Mesalamine (controlled-release) vs. placebo—wks 48, 52 | Disease activity measures | 2 (309)117 119 | High | Consistent | Direct | Imprecise | Favors mesalamine (controlled-release) RD, 7 to 11%; placebo rate, 22 to 58% SOE: Low
Mesalamine (controlled-release) vs. placebo—wk 104 | Disease activity measures | 1 (161)122 | Low | Unknown (single study) | Direct | Imprecise | Favors neither RD, 6%; placebo rate, 58% SOE: Moderate
Mesalamine (controlled-release), vs. placebo--wk 48 | Patient-reported outcomes | 1 (246)117 | Medium | Unknown (single study) | Direct | Imprecise | Favors neither Absolute between-group difference in change in mean IBDQ, 1 pt; placebo mean change, -14 pts SOE: Low
Mesalamine (pH-release) vs. placebo—wk 52 | Disease activity measures | 7 (756)115 118 120 121 123 125 126 | Medium | Inconsistent | Direct | Precise | Favors mesalamine (pH-release) RR, 1.1; 95% CI, 1.0 to 1.3 SOE: Low
Mesalamine (pH-release) vs. placebo—wk 104 | Disease activity measures | 1 (117)118 | High | Unknown (single study) | Direct | Imprecise | Favors placebo RD, -17%; placebo rate, 42% SOE: Low
Mesalamine (pH-release) vs. placebo—wk 208 | Disease activity measures | 1 (59)121 | Medium | Unknown (single study) | Direct | Imprecise | Favors mesalamine (pH-release) RD, 18%; placebo rate, 29% SOE: Low
Olsalazine vs. placebo—wk 52 | Disease activity measures | 1 (328)116 | Low | Unknown (single study) | Direct | Imprecise | Favors neither RD, 2%; placebo rate, 74% SOE: Moderate
Sulfasalazine vs. placebo—wks 54, 104 | Disease activity measures | 2 (274)56 64 | High | Inconsistent | Direct | Imprecise | Favors neither RD, -5 to 7%; placebo rate, 32 to 72% SOE: Low

ASA = aminosalicylates; IBDQ = Inflammatory Bowel Disease Questionnaire; pt = points; RD = absolute risk difference; SOE = strength of evidence; vs. = versus; wk = weeks

Note: The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Moderate = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable

Scores for the Inflammatory Bowel Disease Questionnaire range from 32 to 224, with higher scores indicating better quality of life.36

#### Monotherapy Versus Placebo

##### Aminosalicylates Versus Placebo

###### Disease Activity Measures

Fourteen trials, including 1,789 participants, compared aminosalicylate compounds with placebo to maintain remission (Table 33; Appendix D, Evidence Table 9).56,64,115-126 One trial64 included both patients with active and inactive Crohn's disease at randomization with the active disease results reported in KQ1. There was a great deal of heterogeneity in the absolute relapse rates across the included trials with a range of 0 to 71 percent for the groups receiving aminosalicylates and 14 to 78 percent for placebo.

Table 33 Remission rates reported in randomized controlled trials comparing the efficacy of aminosalicylates with placebo in patients with inactive Crohn's disease

Author, Year | Followup (Weeks) | Main Intervention (daily dose), n | Comparison, n | Relapse Definition | Remission Rate (%)
Summers, 1979^56^ | 54 | Sulfasalazine (0.5 g/15 kg), 58 | Placebo, 101 | CDAI > 150 and 100-pt rise in CDAI or clinical criteria | 67 vs. 72%
Summers, 1979^56^ | 104 | Sulfasalazine (0.5 g/15 kg), 58 | Placebo, 101 | CDAI > 150 and 100-pt rise in CDAI or clinical criteria | 59 vs. 59%
Malchow, 1984^64^ | 54 | Sulfasalazine (3 g), 63 | Placebo, 52 | CDAI > 150 or clinical deterioration | 55 vs. 48%
Malchow, 1984^64^ | 104 | Sulfasalazine (3 g), 63 | Placebo, 52 | CDAI > 150 or clinical deterioration | 37 vs. 32%
Wellmann, 1988^126^ | 52 | Mesalamine (pH-release), 31 | Placebo, 35 | CDAI > 150 | 68 vs. 60%
Prantera, 1992^123^ | 52 | Mesalamine (pH-release) (2.4 g), 64 | Placebo, 61 | CDAI > 150 and 100-pt increase in CDAI | 66 vs. 45%^*^
Brignola, 1992^124^ | 16 | Mesalamine (controlled-release) (2 g), 21 | Placebo, 22 | CDAI > 150 for 2 weeks or 100-pt increase in CDAI | 48 vs. 41%
Gendre, 1993^122^ | 104 | Mesalamine (controlled-release) (2 g), 80 | Placebo, 81 | CDAI > 250 or CDAI between 150 and 250 with 50-pt increase for 2 weeks | 64 vs. 58%
Arber, 1995^121^ | 52 | Mesalamine (pH-release) (1 g), 28 | Placebo, 31 | HBI > 4 | 73 vs. 45%
Bresci, 1995^125^ | 52 | Mesalamine (pH-release) (2.4 g), 32 | Placebo, 31 | CDAI ≥ 150 or 100-pt increase in CDAI and LI ≥ 100 – cumulative^†^ | 84 vs. 71%
Bresci, 1995^125^ | 208 | Mesalamine (pH-release) (2.4 g), 32 | Placebo, 31 | CDAI ≥ 150 or 100-pt increase in CDAI and LI ≥ 100 – cumulative^†^ | 47 vs. 29%
Thomson, 1995^120^ | 52 | Mesalamine (pH-release) (3 g), 102^‡^ | Placebo, 105^‡^ | CDAI > 150 and 60-pt increase in CDAI | 73 vs. 68%^‡^
Thomson, 1995^120^ | 52 | Mesalamine (pH-release) (3 g), 36^§^ | Placebo, 43^§^ | CDAI > 150 and 60-pt increase in CDAI | 60 vs. 74%^§^
Modigliani, 1996^119^ | 52 | Mesalamine (controlled-release) (4 g), 65 | Placebo, 64 | CDAI > 150 and 100-pt increase in CDAI or failure to discontinue steroids | 29 vs. 22%
de Franchis, 1997^118^ | 52 | Mesalamine (pH-release) (3 g), 58 | Placebo, 59 | CDAI > 150 and 60-pt increase in CDAI and increase in at least 2 of 3 acute phase reactants | 34 vs. 41%
de Franchis, 1997^118^ | 104 | Mesalamine (pH-release) (3 g), 58 | Placebo, 59 | CDAI > 150 and 60-pt increase in CDAI and increase in at least 2 of 3 acute phase reactants | 25 vs. 42%
Sutherland, 1997^117^ | 48 | Mesalamine (controlled-release) (3 g), 87 | Placebo, 93 | CDAI > 150 and 60-pt increase in CDAI, or physician-diagnosed disease flare, hospitalization for disease flare, or need for corticosteroids therapy | 69 vs. 58%
Mahmud, 2001^116^ | 52 | Olsalazine (2 g), 167 | Placebo, 161 | CDAI > 150 or 60-pt increase in CDAI | 76 vs. 74%
Prantera, 2005^115^ | 52 | Mesalamine (pH-release) (4 g), 23 | Placebo, 17 | CDAI > 150 or withdrawal for other reasons | 13 vs. 18%

CDAI = Crohn's Disease Activity Index; g = grams; HBI = Harvey-Bradshaw Index; ITT = intention-to-treat; LI = Laboratory Index; pt = points; vs. = versus

* Trial reported significant at the 0.05 alpha level

† LI - laboratory index (-26 + (1.3 × erythrocyte sedimentation rate) + (0.03 × white blood cell) + (5.5 × C-reactive protein) + (0.08 × alpha-1-antitrypsin)

‡ Results were reported separately for patients with Crohn's colitis and Crohn's ileitis. These are the results for patients with Crohn's colitis.

§ Results were reported separately for patients with Crohn's colitis and Crohn's ileitis. These are the results for patients with Crohn's ileitis.

Thirteen of 14 trials reported at 48 weeks or later (Figure 9). One controlled-release mesalamine trial reported the last measure at 16 weeks and found no clinically meaningful difference between mesalamine and placebo.124 Of the remaining 13 trials, there was variation in efficacy by the formulation of the aminosalicylate and, particularly, the brand of mesalamine.

Figure 9 Pooled relative risk of remission* of Crohn's disease at weeks 48 to 54 comparing an aminosalicylate with placebo

ASA = aminosalicylates; CI = confidence interval; diff = difference; g = grams; kg = kilograms; RR = relative risk

Note: Boxes indicate individual trial point estimates. The box size denotes the weight of the trial, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each trial. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimateSulfasalazine test for heterogeneity: Q=1.03 with 1 degree of freedom (p=0.31); I-squared = 3%Mesalamine, pH-release test for heterogeneity: Q=10.06 with 7 degrees of freedom (p=0.19); I-squared = 30%

Mesalamine, controlled-release test for heterogeneity: Q=0.13 with 1 degree of freedom (p=0.72); I-squared = 0%

Olsalazine test for heterogeneity: Q=0 with 0 degrees of freedom; I-squared is not applicable.

Figure 9 is a forest plot type of diagram depicting the pooled relative risk, with 95% confidence interval, of remission at weeks 48 to 54 comparing an aminosalicylate with placebo. The trials are grouped by the type of aminosalicylate. For sulfasalazine, there are two trials included. The pooled relative risk is 1.0 (95% confidence interval [CI] 0.8 to 1.2). For ph-release mesalamine, there are 8 trials included. The pooled relative risk if 1.1 (95% CI, 1.0 to 1.3). For controlled-release mesalamine, there are two trials included. The pooled relative risk was 1.2 (95% CI, 1.0 o 1.5). For olsalazine, there is one trial with a relative risk of 1.0 (95% CI, 0.9 to 1.2). None of the meta-analyses had substantial heterogeneity.

pH-release mesalamine was favored over placebo in seven trials115,118,120,121,123,125,126 at 52 weeks (RR, 1.1; 95% CI, 1.0 to 1.3) (Figure 9). At 104 weeks, placebo was favored over pH-release mesalamine, while at 208 weeks pH-release mesalamine was favored over placebo. Controlled-release mesalamine was favored over placebo in one117 of two trials at 48 to 52 weeks,117,119 but there was no difference from placebo at 104 weeks.122 There was no clinically meaningful difference between sulfasalazine and placebo at 54 or 104 weeks,56,64 or olsalazine and placebo at 52 weeks.116

###### Patient-Reported Outcome

One 48-week trial with 246 patients compared controlled-release mesalamine (750 mg every 6 hours) with placebo.117 At the last visit (early termination or trial completion), mean IBDQ dropped from 193 to 180 in the controlled-release mesalamine group, while it dropped from 193 to 179 in the placebo group. The difference is not clinically meaningful. Patients who were randomized after a surgically induced remission were included in the results and no subgroup analysis was performed to examine the effect of the medication on medically induced remission.

### Comparative Effectiveness of Therapies To Maintain Remission in Adult Subgroups

#### Key Points

- We saw no consistent relationship for the interaction of a medication and disease characteristic on remission rates in adults with Crohn's disease.

We planned to report results for trials that performed a statistical test for interaction. The following subgroup analyses were performed, but did not contain any trials that reported a P-value for an interaction term: baseline CRP, baseline immunomodulator use, baseline antibiotic use, prior TNF-alpha inhibitor exposure, disease location, and prior Crohn's disease-related surgery (Appendix G).

### Quality Assessment

Among the 47 included RCTs, 66 percent adequately generated their allocation sequence and 32 percent were unclear in how they generated their allocation sequence (Appendix D, Evidence Table 10). Seventy-two percent of these RCTs adequately concealed their allocation of participants into the different trial groups. Seventy percent of trials were double blind, while 30 percent were not double blinded or did not report on blinding. Fifty-three percent of these trials reported withdrawals and dropouts, but the other 47 percent did not report on withdrawals or dropouts. Forty-three percent of these RCTs had some additional form of threat to the validity of results that they reported such as not clearly differentiating between patients with active and inactive disease or not performing a statistical test for interaction in subgroup analyses. Fifty-seven percent and 33 percent of these RCTs received pharmaceutical support and company involvement in the design, conduct or reporting of the trial, respectively. The funding source was not reported in 23 percent of the trials. The overall quality ratings included 30 percent were rated as good quality, 43 percent as fair quality, and 27 percent as poor quality.

Five TNF-alpha inhibitor trials were double blind trials at randomization, but allowed patients to increase the dose of the drug or switch from placebo to active drug if they were not responding to the randomized dose.83,87,88,94,95 When assessing the risk of bias, we downgraded these trials to at least medium risk of bias.

## Key Question 3 Safety of Therapies in Adults

Forty-seven RCTs including 9,139 Crohn's disease patients and 61 observational studies including 136,583 inflammatory bowel disease (IBD) patients reported data on one or more adverse effects of treatment. As noted for Key Questions 1 and 2, the main drug classes of interest were biologics, thiopurines, methotrexate, corticosteroids, and aminosalicylates. Because some observational studies combined thiopurines and methotrexate as immunomodulators, the additional classification of immunomodulators appears in this section. If more than three trials of similar design (e.g., induction trial, maintenance trial, prospective, retrospective, or case-control study) reported on a medication-outcome relationship, we considered a meta-analysis.

### Key Points

We summarized the key points below with the corresponding evidence grades. We provided additional details about the evidence grades in Table 34 and Appendix D, Evidence Table 11.

Table 34 Key findings and strength of the available evidence comparing pharmacologic therapies for the management of Crohn's disease in terms of safety-related outcomes

Comparison | Mortality | Lymphoma | Cervical Cancer | All Cancers | Infections | Tuberculosis | Infusion- and Injection-Site Reactions | Bone Fractures
Natalizumab vs. placebo | NF; Low SOE | NF; Low SOE | | NF; Low SOE | NF; Low SOE | | NF; Low SOE
Natalizumab + infliximab vs. infliximab | | NF; Low SOE | | NF; Low SOE | NF; Low SOE | | NF; Low SOE
TNF vs. no TNF | | | NF; Low SOE | NF; Low SOE | NF; Low SOE | NF; Low SOE
Infliximab vs. placebo | NF; Low SOE | NF; Low SOE | | | | | Placebo favored; Low SOE
Adalimumab vs. placebo | NF; Low SOE | NF; Low SOE | | | | | Placebo favored; Low SOE
CP vs. placebo | NF; Low SOE | NF; Low SOE | | | | | NF; Low SOE
Infliximab vs. azathioprine | NF; Low SOE | | | NF; Low SOE | NF; Low SOE | | Azathioprine favored; Low SOE
TNF + IMM vs. no therapy | | NF; Low SOE | | NF; Low SOE | NF; Low SOE
Infliximab + IMM vs. infliximab | NF; Low SOE | NF; Low SOE | | NF; Low SOE | NF; Low SOE | NF; Low SOE | NF; Low SOE
Infliximab + IMM vs. IMM | NF; Low SOE | | | NF; Low SOE | NF; Low SOE | NF; Low SOE | NF; Low SOE
Infliximab + IMM vs. steroids | NF; Low SOE | NF; Low SOE | | | NF; Low SOE
Infliximab + Thiopurine vs. infliximab + methotrexate | | | | | | | NF; Low SOE
TNF + IMM + steroids vs. no therapy | | NF; Low SOE | | NF; Low SOE | NF; Low SOE
Infliximab + steroids vs. no therapy | | NF; Low SOE | | NF; Low SOE | NF; Low SOE
Infliximab + steroids vs. infliximab | | | | NF; Low SOE | | | NF; Low SOE
IMM vs. placebo | NF; Low SOE | NF; Low SOE | NF; Low SOE | NF; Low SOE | NF; Low SOE | | Placebo favored; High SOE
Azathioprine vs. steroids | NF; Low SOE | | | NF; Low SOE | NF; Low SOE
Azathioprine vs. sulfasalazine | NF; Low SOE | | | NF; Low SOE | NF; Low SOE
Thiopurine + prednisone vs. placebo | | NF; Low SOE | | NF; Low SOE | NF; Low SOE
Azathioprine + prednisone vs. azathioprine | NF; Low SOE
IMM + steroids vs. steroids | | | | | NF; Low SOE
Thiopurine + ASA vs. thiopurine | | NF; Low SOE | | NF; Low SOE | NF; Low SOE
Steroids vs. placebo | Placebo favored; Low SOE | NF; Low SOE | NF; Low SOE | NF; Low SOE | NF; Low SOE | | | NF; Low SOE
Budesonide vs. prednisone | | | | | | | | NF; Moderate SOE
Prednisone vs. ASA | NF; Low SOE | | | NF; Low SOE | NF; Low SOE
Steroids + ASA vs. other | NF; Low SOE | | | | NF; Low SOE
ASA vs. placebo | NF; Low SOE | NF; Low SOE | NF; Low SOE | NF; Low SOE | NF; Low SOE

ASA = aminosalicylates; CP = certolizumab pegol; IMM = immunomodulator; NF = neither favored; SOE = strength of evidence; steroids = corticosteroids; TNF = tumor necrosis factor-alpha inhibitor

Note: We defined the strength of the evidence as follows: High = High confidence that the evidence reflects the true effect. Mod = Moderate confidence that the evidence reflects the true effect. Low = Low confidence that the evidence reflects the true effect. Insufficient = Evidence is unavailable. Blank cells indicate insufficient evidence.

#### Mortality

- Mortality rates were less than 1 percent in most of the observed comparisons.
- The only comparison for which mortality differed between groups was treatment with corticosteroids compared with treatment without corticosteroids. The relative risks (RRs) in observational studies ranged from 1.0 to 2.5, favoring no corticosteroids, with followup ranging from 6 weeks to 7 years. (SOE: Low)
- In other comparisons, mortality did not differ between groups that received natalizumab, TNF-alpha inhibitors, immunomodulators, aminosalicylates, or combinations of these drugs. The RRs in observational studies compared with no treatment or another treatment ranged from 0.8 to 1.0 for TNF-alpha inhibitors, 0.7 to 1.3 for immunomodulators, and 0.7 for aminosalicylates, with followup ranging from 4 weeks to 12 years. (SOE: Low)

#### Hepatosplenic T-Cell Lymphoma

- We identified 37 unique cases of hepatosplenic T-cell lymphoma associated with treatment of Crohn's disease from research reports, case series, and the Adverse Events Reporting System.
- Ninety-five percent of the cases used a thiopurine, and 76 percent of the cases used at least one biologic, but we could not establish a causal relationship because of limitations in the available information.

#### Lymphoma

- Lymphoma occurred in less than 1 percent of patients in most observed comparisons.
- The risk of lymphoma did not differ between groups that received natalizumab, TNF-alpha inhibitors, immunomodulators, corticosteroids, aminosalicylates, or combinations of these drugs. The observational RRs, compared with no treatment or another treatment, ranged from 0.6 to 1.7 for TNF-alpha inhibitors, 0.3 to 5.3 for immunomodulators, 1.0 for corticosteroids, and 1.0 for aminosalicylates, with followup ranging from 4 weeks to 12 years. (SOE: Low)
- RCTs of immunomodulators, corticosteroids, or aminosalicylates did not report lymphoma as an outcome.

#### Cervical Cancer

- The studies reported very few cervical cancer cases.
- The risk of cervical cancer did not differ between groups that received TNF-alpha inhibitors, immunomodulators, corticosteroids, or aminosalicylates, or combinations of these drugs, with followup ranging from 26 weeks to 3 years. (SOE: Low)
- Most of the RCTs, and all of the studies of natalizumab, did not include cervical cancer as an outcome.

#### All Cancers

- The risk of non-melanoma skin cancer was higher with TNF-alpha inhibitors alone or with immunomodulators used recently (within 90 days) or persistently (within 90 days and greater than 365 days), than it was with no TNF-alpha inhibitors or no immunomodulators. The odds ratios (ORs) in observational studies ranged from 2.1 to 6.8. (SOE: Low)
- The risk of non-melanoma skin cancer was higher with thiopurines used recently (within 90 days) or persistently (within 90 days and greater than 365 days), than it was with no thiopurines. The ORs in observational studies ranged from 3.8 to 4.3. (SOE: Low)
- The risk of adenocarcinoma of the small bowel was higher with 6-mercaptopurine than with no 6-mercaptopurine. The odds ratio (OR) in an observational study was 10.8, with an unreported length of followup. (SOE: Low)
- For all other comparisons, the risk of specific cancers or all cancers did not differ between treatment groups. The RRs, compared with no treatment or another treatment, from observational studies ranged from 0 to 10.8, with followup ranging from 4 weeks to 12 years. (SOE: Low)

#### Infections

- Trials frequently reported serious infections, and they occurred in less than 5 percent of patients in most trials.
- Trials occasionally reported opportunistic infections, and they occurred less than 5 out of every 100 person-years.
- Trials frequently reported infections (including serious and opportunistic), with a maximum incidence of 83 percent of patients in one trial. Most trials reported far fewer infections (5 to 20 percent of patients).
- The risk of infection did not differ between groups that received natalizumab, TNF-alpha inhibitors, immunomodulators, or aminosalicylates. The RRs, hazard ratios (HRs), or ORs from RCTs and observational studies, compared with no treatment or another treatment, were 0.3 to 1.3 for natalizumab, 0.3 to 11.1 for TNF-alpha inhibitors, 0.3 to 5.4 for immunomodulators, 0.4 to 3.4 for corticosteroids, and 0.9 to 1.8 for aminosalicylates, with followup ranging from 4 weeks to 9 years. (SOE: Low)
- The risk of infection was lower with prednisone and sulfasalazine than with prednisone alone. The RR from one RCT was 0.3, with 8 weeks of followup. (SOE: Moderate)

#### Tuberculosis

- The studies reported only six cases of tuberculosis, most likely because many RCTs screened patients for tuberculosis or treated them before enrollment.
- The risk of developing tuberculosis did not differ between treatment groups in five RCTs comparing TNF-alpha inhibitors with placebo, one RCT comparing a combination of infliximab and immunomodulators with infliximab, and one RCT comparing a combination of infliximab and immunomodulators with immunomodulators. The followup ranged from 4 to 52 weeks. (SOE: Low)

#### Infusion- and Injection-Site Reactions

- Trials of biologics frequently reported infusion and injection-site reactions, with infusion reactions occurring in 0 to 40 percent of patients. Most trials reported that fewer than 20 percent of patients experienced reactions.
- The rate of infusion reactions did not differ between treatment groups in most comparisons. (SOE: Low) The RRs from RCTs and observational studies were as follows: for natalizumab versus placebo, RR ranged from 0.8 to 1.5; for certolizumab pegol versus placebo, RR ranged from 0.2 to 1.7; for combinations with infliximab versus infliximab alone, RR ranged from 0.3 to 1.5; and for infliximab combined with thiopurine versus infliximab combined with methotrexate, RR ranged from 0.8 to 1.4.
- The rate of infusion reactions was higher with infliximab and adalimumab than with placebo. The RRs from RCTs ranged from 1.1 to 3.2. (SOE: Low)
- The rate of infusion reactions was higher with infliximab than with azathioprine. The RR from one RCT was 3.0, with 1 year of followup. (SOE: High)
- We did not find any trials that administered corticosteroids or aminosalicylates intravenously.

#### Bone Fractures

- None of the studies of biologics, immunomodulators, or aminosalicylates reported on bone fractures.
- The risk of bone fracture did not differ between treatment groups that received budesonide or prednisolone. The RR from one RCT with 2 years of followup was 1.0. (SOE: Moderate)
- The risk of bone fracture did not differ between corticosteroid users and corticosteroid non-users. The RR from observational studies ranged from 0 to 2.5, with 2 years of followup. (SOE: Low)

### Study Design and Population Characteristics

Forty-seven RCTs and 61 observational studies reported on one or more safety-related outcomes. Tables 12 and 13 in Appendix D list the study designs and population characteristics of those studies.

Forty-five of 87 RCTs (52 percent) that reported efficacy also reported a safety outcome of interest by treatment group. The 45 RCTs reporting safety included 9,139 Crohn's disease patients. The majority of RCTs assessed safety at study visits but did not indicate how they ascertained safety (e.g., study-specific form or open-ended question) nor did they indicate if there were specific safety concerns of interest. We assumed all RCTs that actively assessed efficacy outcomes also actively assessed safety. Similarly, we assumed all RCTs that used blinded assessment for efficacy outcomes also used blinded assessment of safety.

The observational studies included 12 prospective studies (n=29,075), 37 retrospective studies (n=66,177), 11 case-control studies (n=40,040), one cross-sectional study (n=207),127 and two observational studies of unclear study design (n=694).128 129 All of the case-control and 75 percent of the prospective studies clearly stated a specific safety outcome of interest. Eight case-control studies reported cancer outcomes, two reported on infections, and one reported on bone fractures. All of the retrospective studies aimed to assess safety, but only about half of the studies specified the exact safety outcomes of interest. No observational study mentioned active ascertainment or blinded assessment of safety outcomes. Three of the prospective studies relied upon the patients' personal gastroenterologists to complete study-specific forms related to safety.130-132

Multiple publications used data from several cohorts. These included 23 studies based on a general practice database, a single health center with care delivered at multiple sites, or a single IBD clinic.128,133-154 Most cohorts with multiple publications reported different outcomes in each publication. However, when relevant, we noted the duplication of outcomes in different studies from the same center.

Some of the centers also served as sites for clinical trials. Unless the authors of the observational study reported that the patients' outcomes were also reported in clinical trials, we did not note duplication of reporting in clinical trials and observational studies.

#### Study Design of Observational Studies

Thirty-two observational studies occurred at multiple centers. Twenty-eight observational studies occurred at single centers. Of the single-center studies, 13 occurred in the United States (U.S.), one in Canada, 12 in Europe, one in Australia, and one in Africa. Of the multi-center studies, eight occurred in the U.S., one occurred in the U.S. and Europe, and the remainder occurred in Canada, Australia, or a single country in Europe. No single or multi-center study included a site in Asia. Among 45 studies that reported year of enrollment, the starting year ranged from 1946 to 2009 (seven studies did not report year of enrollment). Median followup ranged from 16 weeks to 9 years (mean 34 weeks to 3.7 years). Eighteen studies did not report average followup. The majority of case-control studies used information from electronic records collected for routine care from multiple centers.

#### Population Characteristics of Observational Studies

Thirty-two studies reported results for IBD patients without reporting results for Crohn's disease patients separately. Twenty-nine studies reported results separately for Crohn's disease patients or included these patients exclusively. The age distribution was very inclusive with some studies including patients of all ages (zero to 90 years).

The majority of observational studies reporting safety included all activity levels and severities of Crohn's disease. One study explicitly included patients by disease behavior and activity. One study included patients without abscess or stricture with either fistulizing disease or luminal refractory Crohn's disease with a Crohn's Disease Activity Index (CDAI) of 220 to 400.^128^ A study on maintenance of remission required patients have 6 months of remission with azathioprine therapy to be eligible.146 Another prospective azathioprine study required patients to have well-controlled IBD to be eligible.155

Most of the observational studies had no restrictions for previous medication use. Twenty studies included only patients who had used infliximab, five studies required adalimumab use, one study required certolizumab pegol use, and two studies required that patients had used a TNF-alpha inhibitor. These studies compared safety of the TNF-alpha inhibitors alone or in combination with other medications. Three retrospective studies required azathioprine use as they aimed to compare effectiveness of azathioprine with or without another medication.146,156,157

### Mortality

Twenty-seven RCTs including 6,867 Crohn's disease patients reported mortality by comparison group. No RCTs of methotrexate reported on mortality. Seven prospective, 13 retrospective, and one observational study of unclear study design (including 41,877 Crohn's disease patients in total) reported mortality as an outcome by comparison group128 (Appendix D, Evidence Table 14).

#### Biologics

Tables 35 and 36 summarize the RCTs and Figure 10 summarizes the observational studies evaluating biologics in terms of mortality. We provided additional details about these studies below.

Table 35 Summary of reported mortality results in randomized controlled trials comparing a biologic alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | Biologic | Comparison | # of Deaths in Biologic Group | # of Patients in Biologic Group | # of Deaths in Comparison Group | # of Patients in Comparison Group
Rutgeerts, 1999^85^ | 36 | Infliximab | Placebo | 0 | 37 | 1 | 36
Hanauer, 2002^86^ | 52 | Infliximab | Placebo | 3 | 193 | 0 | 188
Sandborn, 2005^33^ | 48 | Natalizumab | Placebo | 2 | 723 | 0 | 181
Colombel, 2010^45^ | 54 | Infliximab + placebo | Azathioprine + placebo | 0 | 163 | 1 | 161
Van Assche, 2008^89^ | 104 | Infliximab + immunomodulators | Infliximab | 0 | 40 | 1 | 40
Colombel, 2010^45^ | 54 | Infliximab + azathioprine | Azathioprine + placebo | 0 | 179 | 1 | 161

Table 36 Summary of randomized controlled trials that reported no deaths when comparing the effectiveness of a biologic alone or in combination with placebo or another treatment in patients with Crohn's disease^*^

Biologic | Comparison | # of Trials Reporting no Deaths | Range of Followup (Weeks) | # of Participants (Estimated Person-Years) in Biologic Group | # of Participants (Estimated Person-Years) in Comparison Group
Natalizumab | Placebo | 2^32^ 81 | 12 | 474 (109) | 464 (107)
Adalimumab | Placebo | 4^37^ 38 82 83 | 4-52 | 938 (584) | 519 (297)
Certolizumab pegol | Placebo | 4^39-41^ 84 | 12-26 | 833 (284) | 638 (243)
Infliximab | Placebo | 3^44^ 86 87 | 18-52 | 363 (310) | 362 (309)
Infliximab + azathioprine | Infliximab + placebo | 1^45^ | 54 | 179 (186) | 163 (169)
Infliximab+ azathioprine | Infliximab + hydrocortisone | 1^88^ | 104 | 23 (46) | 23 (46)
Infliximab + thiopurine | Thiopurine + placebo | 1^46^ | 52 | 57 (57) | 56 (56)

* Eight RCTs compared a biologic to another medication and did not report on mortality.33-35 42 43 47 48 80

Figure 10 Summary of Peto odds ratios of mortality among observational studies comparing a biologic alone or in combination with another treatment in patients with Crohn's disease

ADA = adalimumab; ASA = aminosalicylates; BUDE = budesonide; CI = confidence interval; Comp = comparison; CP = certolizumab pegol; IFX = infliximab; IMM = immunomodulator; MTX = methotrexate; NR = not reported; OR = odds ratio; Pro = prospective cohort; Retro = retrospective cohort; STEROID = corticosteroids; THIO = thiopurine; TNF = tumor necrosis factor-alpha inhibitor

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Inflammatory bowel disease population

^‡^ Adjusted OR, 0.8 (95% CI, 0.3 to 1.8)

^§^ Adjusted OR, 1.0 (95% CI, 0.5 to 1.9)

Figure 10 is a forest plot summarizing the Peto odds ratios of mortality among observational studies comparing a biologic alone or in combination with another treatment. Fourteen studies, with 28 comparisons, are included. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratios are: 0.7 and a 95% confidence interval of 0.3 to 1.4 for Fidder 2009; and, 1.1 and a 95% confidence interval of 0.6 to 1.9 for Lichtenstein 2006. The results are summarized in the preceding section.

##### Adalimumab Versus Placebo

Four RCTs compared adalimumab with placebo in 1,457 patients and reported mortality.37,38,83,95 The 4- or 52-week trials reported no deaths during the study periods. However, one person died during an induction period prior to randomization after receiving adalimumab.95

##### Other Combinations With Adalimumab

Four prospective studies (n=2,042) reported no deaths in patients taking adalimumab alone or in combination with aminosalicylates, corticosteroids, or immunomodulators.158-161 There were two deaths after the study period in one study.161 One death was from aminosalicylates toxicity (the study did not report any other concomitant medications). The study also did not report any concomitant medications for the other patient who died.

##### Certolizumab Pegol Versus Placebo

Four RCTs compared certolizumab pegol with placebo in 1,472 patients and reported mortality.39-41 84 Three studies were induction trials lasting 12- or 26-weeks.39-41 The trials did not report any deaths during the study periods. One 26-week trial reported one death after the study period in the certolizumab pegol group.39

An 18-week trial of 428 responders from an 8-week induction phase compared certolizumab pegol with placebo among patients without obstruction, stricture, or abscess.84 One patient died of an accidental fentanyl overdose during the induction phase (1 percent), but the trial did not report any deaths during the randomization period.84

##### Other Combinations With Certolizumab Pegol

One prospective study (n=60) reported no deaths in patients taking certolizumab pegol with or without concomitant aminosalicylates, budesonide, other corticosteroids, or thiopurine.132

##### Infliximab Versus Placebo

Four RCTs including 1,022 patients compared infliximab with placebo and reported mortality.44,85-87 An 18-week induction trial of 94 fistulizing Crohn's disease patients compared infliximab infusion with placebo.44 It reported no deaths during the study period.

A 36-week maintenance trial85 compared retreatment with infliximab or placebo among 73 responders to a single induction dose in a previous 12-week trial.43 The trial reported no deaths in the infliximab group, but reported one death in the placebo group. The deceased patient received infliximab during the induction period.85 The trial corresponding to the induction period did not report on mortality and did not report this death.43

A 40-week maintenance trial of 282 responders and non-responders to a 14-week induction period with infliximab, compared infliximab with placebo.87 They reported no deaths during the study period, but did report two deaths after the completion of the study. (The deaths occurred in 1 percent of the 306 given an induction dose prior to randomization.)

In a 52-week maintenance trial, 573 responders and non-responders to a 2-week induction period of a single infliximab dose were given either infliximab or a placebo in 5 and 10 mg/kg doses administered intravenously every 8 weeks.86 They reported three deaths in the 5 mg/kg infliximab group (2 percent), but reported no deaths in the 10 mg/kg infliximab and placebo groups.86

##### Infliximab Versus No Infliximab

One prospective study of 6,290 Crohn's disease patients compared no infliximab use during the observation period with infliximab use within 12 weeks of enrollment, after 30 days of enrollment, or any other time during the observation period.131 The study followed mortality through June 30, 2004, instead of August 2004, because there was incomplete information on medication usage after June 30, 2004. There was no statistically significant increase in mortality comparing infliximab with no infliximab during the study period in the relative rate (incidence rate ratio [IRR], 1.2; 95% CI, 0.7 to 2.1), unadjusted OR (OR, 1.1; 95% CI, 0.6 to 1.9), or OR adjusted for demographic factors and ever having used prednisone, immunomodulators, or narcotic analgesics (1.0; 95% CI, 0.5 to 1.9). The OR analysis excluded two deaths because they occurred after June 30, 2004. The relative rate appears to have included these deaths.

##### Infliximab Versus Immunomodulators

One RCT including 324 patients compared infliximab with immunomodulators and reported mortality. A 50-week induction trial compared infliximab with azathioprine among patients who were naïve to TNF-alpha inhibitors, azathioprine, 6-mercaptopurine, and methotrexate.45 The trial collected safety information through week 54. There was one death among the 161 azathioprine patients, and no deaths among the 163 infliximab patients.

##### Combination of Infliximab and Immunomodulators Versus Infliximab

Three RCTs and three observational studies including 1,296 patients compared a combination of infliximab and immunomodulators with infliximab alone, and reported mortality.45,46,89,128,162,163 Three RCTs including 535 patients compared a combination of infliximab and immunomodulators with infliximab alone. A 50-week induction trial compared infliximab and concomitant azathioprine with infliximab alone, among patients who were naïve to TNF-alpha inhibitors, azathioprine, 6-mercaptopurine, and methotrexate.45 The trial collected safety information through week 54. One patient died prior to randomization of the 817 patients assessed for eligibility (less than 1 percent). The trial did not report any deaths in the 179 combination infliximab and azathioprine patients or 161 infliximab patients during the study period. An open-label 104-week RCT of 80 patients compared retreatment with infliximab with or without continuation of the current immunomodulators.89 One patient who discontinued immunomodulators died during the study period (1 percent). A 52-week induction trial, of 113 steroid-dependent patients with luminal Crohn's disease reported no deaths in the combination infliximab and thiopurines or infliximab alone treatment groups.46

Two retrospective studies including 761 Crohn's disease patients compared a combination of infliximab and immunomodulators with infliximab alone and reported mortality. A single-center retrospective study of 122 patients administered a mean of three infliximab infusions per patient and followed them for an average of 40 to 65 weeks.162 The trial did not record any deaths in the charts of the 58 patients treated with infliximab with concomitant azathioprine or 6-mercaptopurine, nor did it record any deaths in the charts of the 23 patients treated with concomitant methotrexate. The trial recorded one death in the medical records of 36 patients who received infliximab without concomitant thiopurines or methotrexate (3 percent). Another single-center study reported no deaths in either treatment group.163

One study reported no deaths among 362 patients treated with infliximab without immunomodulators, and no deaths among 211 patients who received infliximab and an immunomodulator during the 12-week treatment period.128 Researchers describe the study as a large series. It was likely retrospective in design because another study at the same center (reporting cancer outcomes) was retrospective.149 The study reporting cancer outcomes compared infliximab with no infliximab and reported that three patients treated with infliximab died from their cancer through September 2004. Because the 12-week study reporting on mortality did not report these deaths, they likely did not occur during the first 12 weeks of followup, or occurred after the end of followup of the mortality study.128

##### Combination of Infliximab and Immunomodulators Versus Immunomodulators

One 50-week trial including 340 patients naïve to TNF-alpha inhibitors, azathioprine, 6-mercaptopurine, and methotrexate compared infliximab and concomitant azathioprine with azathioprine alone and reported on mortality.45 The trial reported no deaths in the 169 combination infliximab and azathioprine patients. One of 170 azathioprine patients died during the study period (less than 1 percent).

##### Combination of Infliximab and Immunomodulators Versus Corticosteroids

One 2-year trial studied 46 corticosteroid-dependent patients with luminal Crohn's disease who achieved remission during the 8-week induction period. The trial compared infliximab and concomitant azathioprine given daily with infliximab and hydrocortisone given at the time of the infusion.88 The trial reported no deaths during the study period. One retrospective study of 71 patients reported no deaths in either the infliximab combined with corticosteroids group, or the infliximab combined with no previous use of corticosteroids group.163

##### Other Combinations With Infliximab

Three retrospective cohorts including 954 patients reported on the safety profile of infliximab use at their study centers.137 145 164 For all Crohn's disease patients, the studies reported concomitant medications at the time of the first infliximab infusion given at the center. However, the studies only reported on concomitant medication use between infusion and the time of death for patients who died. They classified patients with unavailable information as infliximab without concomitant medication. Because of the potential misclassification, we did not include these studies in the tables or the strength of evidence grading, but we did report them here because they met our inclusion criteria.

When studies categorized patients who had received infliximab but were not taking concomitant medications through the time of death as infliximab with no concomitant medications at infliximab initiation, they had the greatest mortality in two of three studies (11 and 32 percent) compared with infliximab with corticosteroids (9 and 3 percent) or compared with infliximab with an immunomodulator with or without corticosteroids (less than 5 percent). The other study reported no deaths in the groups including infliximab without concomitant medication, 2 percent mortality when patients received infliximab combined with an immunomodulator, and 12 percent mortality when patients received infliximab combined with immunomodulators and corticosteroids.164 A previous study from one of the centers reported on the infliximab outcomes among the first 100 patients, and included one death from chronic pancreatitis 16 weeks after last infliximab infusion.138 Based on the age at death, this patient is likely the same patient who died of organ failure 8 weeks after the last infusion as reported in the first 500 infliximab patients.137

One of these studies also reported mortality among 30 of the 157 patients who used adalimumab after infliximab.145 The study did not observe any deaths among the 30 adalimumab patients, compared with seven deaths among 127 infliximab users who did not subsequently use adalimumab (6 percent). The Peto OR comparing infliximab followed by adalimumab, with infliximab not followed by adalimumab, in terms of risk of mortality, was 0.3 (95% CI, 0 to 3.5).145

##### Natalizumab Versus Placebo

Three RCTs from two articles reported mortality for natalizumab versus placebo in 1,414 patients.32 33 The two trials (reported in the same publication) included an initial induction trial of 904 patients followed for 8 weeks, and a subsequent maintenance trial of 428 responders from that initial trial.33 One death occurred during the induction trial study period in the natalizumab group (less than 1 percent) and an additional death from progressive multifocal leukoencephalopathy occurred in the natalizumab group after the study ended during the open-label extension (less than 1 percent).33 No deaths occurred in the placebo groups. A 12-week trial of 510 patients did not report any deaths in the induction or study periods.32

##### Other Combinations With TNF-Alpha Inhibitors

One retrospective study reported no deaths from infection in 489 patients who received adalimumab, certolizumab pegol, or infliximab alone or in combination with steroids or immunomodulators.165 A 104-week retrospective study reported that 10 percent of adalimumab or infliximab users died during the study period compared to 3 percent of patients who had never used a biologic. The corresponding Peto OR is 4.3 (95% CI, 0.9 to 27.6).150

#### Immunomodulators

We summarized the effects of immunomodulators on mortality in patients with Crohn's disease in Table 37 (for RCTs) and Figure 11 (for observational studies). We provided additional details about the studies below.

Table 37 Summary of reported mortality results in randomized controlled trials comparing an immunomodulator alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Follow-up (Weeks) | Immunomodulator | Comparison | # Deaths in IMM Group | # of Patients in IMM Group | # of Deaths in Comparison Group | # of Patients in Comparison Group
O'Donoghue, 1978^100^ | 52 | Azathioprine | Placebo | 1 | 24 | 0 | 27
Lemann, 2005^98^ | 48 | Azathioprine | Placebo | 1 | 40 | 0 | 43
Summers, 1979^56^ | 104 | Azathioprine | Placebo | 0 | 113 | 0 | 178
Mantzaris, 2009^102^ | 52 | Azathioprine | Budesonide | 0 | 112 | 0 | 83
Summers, 1979^56^ | 104 | Azathioprine | Prednisolone | 0 | 113 | 0 | 146
Summers, 1979^56^ | 104 | Azathioprine | Sulfasalazine | 0 | 113 | 0 | 132
Reinisch, 2008^51^ | 28 | Azathioprine + prednisone | Prednisone | 0 | 52 | 0 | 28

IMM = immunomodulator

Figure 11 Summary of Peto odds ratios of mortality among observational studies comparing an immunomodulator alone or in combination with another treatment in patients with Crohn's disease

CI = confidence interval; Comp = comparison; IMM = immunomodulator; NR = not reported; OR = odds ratio; Pro = prospective cohort; Retro = retrospective cohort; THIO = thiopurine

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Inflammatory bowel disease population

^‡^ Adjusted OR, 0.7 (95% CI, 0.4 to 1.3)

^§^ Adjusted OR, 1.3 (95% CI, 0.9 to 1.9)

^║^ Adjusted hazards ratio, 0.8 (95% CI, 0.4 to 1.9); the total number of mortality events for all treatment groups combined is 264 out of 5,537 patients. The studies did not report the number of events by treatment group.

Figure 11 is a forest plot summarizing the Peto odds ratios of mortality among observational studies comparing an immunomodulator alone or in combination with another treatment. Four studies are included. The studies and their comparisons are: Beaugerie, 2009, a prospective study, comparing a thiopurine with no thiopurine; Lichtenstein 2006, a prospective study comparing an immunomodulator with no immunomodulator; Hutfless 2007, a retrospective study comparing an immunomodulator with no immunomodulators; and, Lewis 2008 is a retrospective study comparing current immunomodulators with no immunomodulators. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratios are: 1.2 and a 95% confidence interval of 0.9 to 1.6 for Beaugerie 2009; and, 0.6 and a 95% confidence interval of 0.4 to 1.1 for Lichtenstein 2006; 1.2 and a 95% confidence interval of 0.8 to 1.8 for Hutfless 2007. The results are summarized in the preceding section.

##### Azathioprine Versus Placebo

Three RCTs compared azathioprine with placebo in 425 patients and reported on mortality. One RCT reported no deaths due to Crohn's disease in either group.56 Two RCTs compared continuation of azathioprine with placebo among 134 prevalent users of azathioprine. Researchers conducted one RCT at multiple centers and powered it as a non-inferiority trial to assess recurrent Crohn's disease among those who had used azathioprine and been in remission for at least 42 months. This trial reported one death in the 40 azathioprine patients (3 percent) compared with zero deaths in the 43 placebo patients.98 One RCT required at least 6 months of azathioprine-induced remission before randomizing patients to azathioprine or placebo.100 One patient, who had been randomized to continue azathioprine after 10 years of azathioprine use, died during the study period. The trial did not report any deaths in the placebo group.

##### Azathioprine Versus Aminosalicylates

One 2-year RCT including 245 patients compared azathioprine with sulfasalazine. The trial reported no deaths due to Crohn's disease during the study period.56

##### Azathioprine Versus Corticosteroids

Two RCTs reported on mortality when comparing azathioprine with prednisone in 336 patients.56,102 One RCT compared 113 azathioprine patients and 146 prednisone patients over 2 years. The RCTs reported no deaths due to Crohn's disease during the study period.56 Another RCT compared 112 azathioprine with 83 budesonide patients, and reported no deaths during the study period.102

##### Combination of Azathioprine and Prednisone Versus Prednisone

One RCT including 81 patients compared three separate treatment regimens: 2.5 mg/kg per day azathioprine with concomitant 1 mg/kg per day of prednisone or at least 40 mg per day of prednisone (n=52), the same dose of prednisone and a placebo (n=29); and a medication not of interest for this report, everolimus (n=63).51 Researchers stopped the study early due to lack of efficacy with everolimus, and reported no deaths within 7 months of followup.

##### Immunomodulators Versus No Immunomodulators

One prospective study and two retrospective studies including a total of 11,829 Crohn's disease patients reported on mortality. One prospective and one retrospective study reported on mortality comparing immunomodulators with no immunomodulators.131,151 The prospective study reported 1 percent mortality among 3,764 persons who had taken immunomodulators during the study period, compared with 1 percent mortality among 2,526 who had not taken immunomodulators during the study period.131 The OR was 0.7 (95% CI, 0.4 to 1.3) comparing immunomodulators with no immunomodulators, after adjusting for age; sex; race; disease location; duration of disease; severity; and having ever used infliximab, prednisone, and narcotic analgesics.131 The retrospective study compared current use of thiopurine with no use of thiopurine during the study period. The hazard ration (HR) was 0.8 (95% CI, 0.4 to 1.9) comparing current thiopurine use versus no use (no recorded use, or no use within 182 days of death), after adjusting for age, sex, comorbidity, and time from registration.134 In contrast, the third retrospective study reported an OR of 1.3 (95% CI, 0.9 to 1.0), comparing immunomodulators with no immunomodulators, after adjusting for age, sex, and smoking.151 This retrospective studies did not adjust for use of other Crohn's disease medications or disease characteristics.

#### Corticosteroids

We summarized the effects of corticosteroids on mortality in patients with Crohn's disease in Table 38 (for RCTs) and Figure 12 (for observational studies).

Table 38 Summary of reported mortality results in randomized controlled trials comparing prednisone alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | Corticosteroid | Comparison | # of Deaths in Steroid Group | # of Patients in Steroid Group | # of Deaths in Comparison Group | # of Patients in Comparison Group
Summers, 1979^56^ | 104 | Prednisone | Placebo | 0 | 146 | 0 | 178
Malchow, 1984^64^ | 104 | Prednisone | Placebo | 3 | 113 | 0 | 110
Summers, 1979^56^ | 104 | Prednisone | Sulfasalazine | 0 | 146 | 0 | 132
Malchow, 1984^64^ | 104 | Prednisone | Sulfasalazine | 3 | 113 | 0 | 117
Malchow, 1984^64^ | 104 | Prednisone + sulfasalazine | Placebo | 1 | 112 | 0 | 110
Malchow, 1984^64^ | 104 | Prednisone + sulfasalazine | Sulfasalazine | 1 | 112 | 0 | 117
Malchow, 1984^64^ | 104 | Prednisone + sulfasalazine | Prednisone | 1 | 112 | 3 | 113

Steroid = corticosteroid.

Note: One trial did not report on mortality.74

Figure 12 Summary of Peto odds ratios of mortality among observational studies comparing a corticosteroid alone or in combination with another treatment in patients with Crohn's disease

CI = confidence interval; Comp = comparison; NR = not reported; OR = odds ratio; PRED = prednisone; Pro = prospective cohort; Retro = retrospective cohort; STEROID = corticosteroid

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Adjusted OR, 2.1 (95% CI, 1.1 to 3.8)

^‡^ Adjusted OR, 1.0 (95% CI, 0.7 to 1.4)

^§^ Adjusted hazards ratio, 2.5 (95% CI, 1.9 to 3.3); the total number of mortality events for all treatment groups combined is 264 out of 5537 patients. The studies did not report the number of events by treatment group.

^║^ Inflammatory bowel disease population

Figure 12 is a forest plot summarizing the Peto odds ratios of mortality among observational studies comparing a corticosteroid alone or in combination with another treatment. Four studies are included. The studies and their comparisons are: Lichtenstein 2006, a prospective study comparing an prednisone with no prednisone; Hutfless 2007, a retrospective study comparing a corticosteroid with no corticosteroid; Lewis 2008, a retrospective study comparing a current corticosteroid with no corticosteroid; and, Goldstein 1967, a retrospective study comparing a corticosteroid with no corticosteroid. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratios are: 2.2 with 95% confidence interval 1.3 to 3.9 for Lichtenstein 2006 and 1.1 with 95% confidence interval of 0.8 to 1.4 for Hutfless 2007. The results are summarized in the preceding section.

##### Corticosteroids Versus Placebo

Two RCTs including 547 patients compared corticosteroids with placebo and reported on mortality.56,64 A 2-year RCT compared prednisone with placebo and reported no deaths due to Crohn's disease during the study period.56 An RCT that included a 6-week corticosteroid taper for patients with active disease and a 2-year maintenance phase for inactive disease reported three deaths in the prednisolone group during the 2-year period.64 An additional prednisolone patient died after the study period.

##### Corticosteroids Versus No Corticosteroids

Three observational studies including 15,070 Crohn's disease patients compared corticosteroids with no corticosteroids and reported mortality.131,134,151 One prospective study of 6,290 Crohn's disease patients compared mortality rates among patients who used prednisone during the study period versus those who did not.131 After adjusting for demographics, disease characteristics, and use of other Crohn's disease medications and narcotic analgesics, patients who used prednisone had a 2-fold increased odds of mortality compared with those who did not use prednisone during the study period (OR, 2.1; 95% CI, 1.1 to 3.8).

A retrospective study that observed 3,241 Crohn's disease patients for a median of 7 years reported no difference in mortality between those who used steroids during the study period and those who did not (age, sex, and smoking adjusted OR, 1.0; 95% CI, 0.7 to 1.4).151 A retrospective study that observed Crohn's disease patients for a mean of 4 years compared those who used corticosteroids currently, recently, or never during the study period. The HR was 2.5 (95% CI, 1.9 to 3.3) comparing current (within 91 days) corticosteroid use versus no use (no recorded use or use more than 182 days prior to death), after adjusting for age, sex, comorbidity, and time from registration.134 The adjusted HR comparing recent use (92 to 182 days prior to death) with no use (no recorded use or use more than 182 days prior to death) was 1.2 (95% CI, 0.6 to 2.4).134 The retrospective studies did not adjust for use of other Crohn's disease medications or disease characteristics.

##### Corticosteroids Versus Aminosalicylates

Two RCTs including 508 Crohn's disease patients compared corticosteroids with sulfasalazine and reported on mortality.56,64 One RCT compared prednisone with sulfasalazine and reported no deaths due to Crohn's disease during the study period.56 The other RCT reported three deaths in the prednisolone group during the study period and an additional death after the study period in both the prednisolone and sulfasalazine groups.64

##### Combination of Corticosteroids and Aminosalicylates Versus Other Treatment

One RCT of 452 Crohn's disease patients compared a combination of prednisolone and sulfasalazine with placebo, prednisolone, or sulfasalazine and reported on mortality. During the study period, there were three deaths on prednisolone, one death on prednisolone and sulfasalazine, and no deaths on sulfasalazine or placebo. After the study period, the trial reported an additional death in each group except the placebo group.64

#### Aminosalicylates

We summarized the effects of aminosalicylates on mortality in Table 39.

Table 39 Summary of reported mortality results in randomized controlled trials and observational studies comparing an aminosalicylate alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | Study Design | ASA | Comparison | # of Deaths in ASA Group | # of Patients in ASA Group | # of Deaths in Comparison Group | # of Patients in Comparison Group | Unadjusted OR^*^ (95% CI)
Lennard-Jones, 1977^166^ | 52 | RCT | Sulfasalazine | Placebo | 0 | 6 | 0 | 2 | NA
Summers, 1979^56^ | 104 | RCT | Sulfasalazine | Placebo | 0 | 132 | 0 | 178 | NA
Malchow, 1984^64^ | 104 | RCT | Sulfasalazine | Placebo | 0 | 117 | 0 | 110 | NA
Modigliani, 1996^119^ | 48 | RCT | Mesalamine | Placebo | 0 | 65 | 1 | 64 | NA
Hutfless, 2007^151^ | 364 | Retrospective cohort | ASA | No ASA | 175 | 2566 | 56 | 675 | 0.8 (0.6 to 1.1) †

ASA = aminosalicylates; CI = confidence interval; NA = not applicable; OR = odds ratio; RCT = randomized controlled trial

* We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

† Adjusted OR, 0.7 (95% CI, 0.5 to 1.1)

##### Aminosalicylates Versus Placebo

Four RCTs including 674 patients compared aminosalicylates with placebo and reported on mortality.56,64,119,166 One RCT treated 150 patients with prednisolone for 3 to 7 weeks. Those patients who entered clinical remission were then randomized to receive either mesalamine or placebo until weaned from prednisolone. The trial included an additional year of followup.119 One of 37 placebo patients died in the year after prednisolone discontinuation.

Three RCTs compared sulfasalazine with placebo. The first included eight patients who had not undergone intestinal resection within the preceding 6 months.166 No patients died. The second reported no deaths due to Crohn's disease during the study period.56 The third reported no deaths during the study period. However, one sulfasalazine patient died after the study period.64

##### Aminosalicylates Versus No Aminosalicylates

One retrospective study of 3,241 Crohn's disease patients reported 1 percent fewer deaths in the aminosalicylates-treated group compared with those who did not fill a prescription for aminosalicylates during the study period (age, sex, and smoking adjusted OR, 0.7; 95% CI, 0.5 to 1.1).151

#### Studies Evaluating Patients With IBD

Five studies reported on mortality in the treatment of IBD. The studies did not separate Crohn's disease from ulcerative colitis or indeterminate colitis. In general, the results were consistent between the studies. We provided details about those studies in Appendix F.

#### Studies Reporting Results for Crohn's Disease and IBD

One study (using administrative data) looked at the relationship between medications and mortality and did not find meaningful difference between Crohn's disease and IBD.151 The mortality ORs (adjusting for age, sex, and smoking) were similar in Crohn's disease and IBD for patients who used corticosteroid during the study period versus patients who did not (Crohn's disease OR, 1.0; IBD OR, 0.9); the same was true for aminosalicylate versus no aminosalicylate (Crohn's disease OR, 0.7; IBD OR, 0.8). The OR for mortality was greater than 1 for Crohn's disease patients who used immunomodulators during the study period versus those who did not, (OR, 1.3; 95% CI, 0.9 to 1.9) and less than 1 for IBD patients who used immunomodulators versus those who did not (OR, 0.9; 95% CI, 0.7 to 1.2), although neither finding was statistically significant. The study did not adjust ORs for use of the other medications that the study examined.

A collection of referral centers reported on mortality for patients with Crohn's disease or ulcerative colitis.150 In both the Crohn's disease and ulcerative colitis groups, there were more deaths in the patients treated with adalimumab or infliximab compared with those who never received a biologic.

### Progressive Multifocal Leukoencephalopathy

We identified one case of Progressive Multifocal Leukoencephalopathy (PML) associated with treatment of Crohn's disease.167 A 60-year-old man with a 28-year history of Crohn's disease was experiencing confusion and disorientation on July 2003. The patient expired three months later from PML. Subsequent immunohistochemical analysis of the brain tissue demonstrated positive staining for polyomavirus John Cunningham genotype 2, confirming the diagnosis of PML. The patient had received 5 doses of natalizumab over a 16-month interval. The last natalizumab dose was in May or June 2003, within 2 months of symptom presentation. The patient had also previously received infliximab starting in September 1998 (prior to European approval of infliximab in August 1999). The patient received the last infliximab infusion in September 2001, 20 months prior to the PML diagnosis. The patient had also used corticosteroids, antibiotics, and azathioprine (discontinued 8 months prior to suspected PML due to refractory anemia with low platelet counts and lymphopenia). The authors of the study linked the timing of the PML diagnosis to the use of natalizumab because John Cunningham virus appeared in serum samples (available from the IBD center's serum bank from March 1999) only after this patient received natalizumab. A randomized trial reported on this case during the period when the patient first received natalizumab.33 And an observational study reported the safety of infliximab at the study center.153 A search of the Adverse Events Reporting System did not identify additional cases.

### Lymphoma

Thirteen RCTs including 4,956 Crohn's disease patients reported on lymphoma risk by comparison group (Appendix D, Evidence Table 14). Three prospective studies (n=20,219), 12 retrospective studies (n=32,056), and one case-control study (n=15,471) reported lymphoma as an outcome. Lymphoproliferative disorders (including lymphoma) were a primary interest of outcome in one prospective study.130 No trials of immunomodulators, corticosteroids, or aminosalicylates reported on lymphoma risk. The total number of patients in the RCTs was 71,554.

#### Biologics

We summarized the risk of lymphoma associated with use of biologics in Crohn's disease in Table 40 (for RCTs) and Figure 13 (for observational studies). We also provided additional details regarding related studies.

Table 40 Summary of lymphoma risk in randomized controlled trials comparing a biologic alone or in combination with placebo or another treatment in patients with Crohn's disease^*^

Author, Year | Followup (Weeks) | Biologic | Comparison | # of Lymphoma Cases in Biologic Group | # of Patients in Biologic Group | # of Lymphoma Cases in Comparison Group | # of Patients in Comparison Group
Rutgeerts, 1999^85^ | 36 | Infliximab | Placebo | 0 | 37 | 1 | 36
Hanauer, 2002^86^ | 52 | Infliximab | Placebo | 0 | 385 | 1 | 188
Schreiber, 2005^40^ | 20 | Certolizumab pegol | Placebo | 0 | 218 | 0 | 73
Schreiber, 2007^84^ | 18 | Certolizumab pegol | Placebo | 0 | 216 | 0 | 212
Sandborn, 2007^39^ | 26 | Certolizumab pegol | Placebo | 0 | 331 | 1 | 329
Sandborn, 2007^38^ | 4 | Adalimumab | Placebo | 0 | 159 | 0 | 166
Hanauer, 2006^37^ | 4 | Adalimumab | Placebo | 0 | 225 | 0 | 74
Sandborn, 2007^83^ | 52 | Adalimumab | Placebo | 0 | 37 | 0 | 18
Sandborn, 2005^33^ | 48 | Natalizumab | Placebo | 0 | 723 | 0 | 181
Targan, 2007^32^ | 8 | Natalizumab | Placebo | 0 | 260 | 0 | 250
Sands, 2007^35^ | 20 | Natalizumab + infliximab | Infliximab | 0 | 52 | 0 | 27

* Three RCTs compared a biologic with placebo or another medication and did not report on lymphomas.42 45 89

Figure 13 Summary of Peto odds ratios of lymphoma among observational studies comparing a biologic alone or in combination with another treatment in patients with Crohn's disease

ADA = adalimumab; ASA = aminosalicylates; BIO = biologics; Bude = budesonide; CI = confidence interval; Comp = comparison; CP = certolizumab pegol; IFX = infliximab; IMM = immunomodulator; Main = main intervention; NR = not reported; OR = odds ratio; Retro = retrospective cohort; STEROID = corticosteroids; THIO = thiopurine; TNF = tumor necrosis factor-alpha inhibitor

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Inflammatory bowel disease population

^‡^ Incidence rate ratio, 1.7 events per person-year (95% CI, 0.2 to 6.3)

^§^ Incidence rate ratio, 0 events per person-year (95% CI, 0 to 6.5)

^║^ Incidence rate ratio, 1.5 events per person-year (95% CI, 0.04 to 8.7)

^¶^ Incidence rate ratio, 0 events per person-year (95% CI, 0 to 30.0)

Figure 13 is a forest plot type of diagram summarizing the Peto odds ratios of lymphoma among observational studies comparing a biologic alone or in combination with another treatment. Seven studies, with nineteen comparisons, are included. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratio is: 0.6 and a 95% confidence interval of 0.1 to 3.5 for Fidder 2009. The results are summarized in the preceding section.

##### Adalimumab Versus Placebo

Three RCTs including 679 patients compared adalimumab with placebo and reported no cases of lymphoma.37,38,83

##### Other Combinations With Adalimumab

One prospective (n=673)161 and one retrospective (n=118)140 study reported no cases of lymphoma in patients who used adalimumab alone or in combination with aminosalicylates, corticosteroids, or immunomodulators.

##### Certolizumab Pegol Versus Placebo

Three RCTs including 1,379 patients compared certolizumab pegol with placebo and reported on lymphoma risk.39,40,84 One trial reported one lymphoma case in a placebo group (less than 1 percent).39 The other two RCTs reported no cases of lymphoma.40 84

##### Other Combinations With Certolizumab Pegol

One prospective study (n=60) reported no deaths in patients who used certolizumab pegol alone or in combination with aminosalicylates, corticosteroids, or immunomodulators.132

##### Infliximab Versus Placebo

Two RCTs including 646 patients compared infliximab with placebo and reported on lymphoma risk.85,86 One study randomized infliximab responders and non-responders after a single infusion of infliximab or placebo.86 The other study85 compared retreatment with infliximab with placebo among responders to a single infusion from a previous RCT.43 The two trials reported no lymphoma cases in the infliximab groups (0 percent of 385 and 37 patients, respectively). However, in the placebo groups, one trial reported one lymphoma among 188 patients (less than 1 percent),86 and the other study saw one lymphoma in 36 patients (4 percent).85 The retreatment RCT reported that one lymphoma patient received infliximab in the induction period and later died from sepsis, although the induction study did report lymphoma or death.43

##### Natalizumab Versus Placebo

Three RCTs (published in two articles) included 1,414 patients and reported no cases of lymphoma in any natalizumab or control group during the study periods.32,33 One trial reported lymphoma after the study in a patient who had received natalizumab induction, placebo maintenance, and natalizumab during the open-label extension period.32

##### Combination of Natalizumab and Infliximab Versus Infliximab

One 20-week RCT including 79 infliximab non-responders randomized patients to additional treatments with natalizumab or placebo.35 The trial followed patients for up to 6 months. It reported no lymphoma cases.

##### TNF-Alpha Inhibitor Versus No TNF-Alpha Inhibitor

Two retrospective studies including 9,389 Crohn's disease patients compared a TNF-alpha inhibitor with no TNF-alpha inhibitor and reported on lymphoma risk.149,153,168

One study reported no lymphoma cases among 404 Crohn's disease patients with a record of infliximab in their charts, compared with one case of lymphoma among 404 Crohn's disease patients who did not have a record of infliximab in their charts. The study matched both sets of patients with respect to age, sex, followup, immunomodulator use, Crohn's disease location and duration, and study center.149 Because the non-Hodgkin's lymphoma patient did not use infliximab, the patient did not meet the inclusion criteria for another infliximab study at the center.128

A claims-based study of health plan members included 8,581 patients with one or more encounter with Crohn's disease. The study reported two lymphoma cases in TNF-alpha inhibitor users (1 per 100 person-years) and 64 lymphoma cases in patients who received no TNF-alpha inhibitor, immunomodulator, or corticosteroid (less than one per 100 person-years).168 Although the authors did not report a rate ratio; the unadjusted rate ratio comparing TNF-alpha inhibitor use with no therapy (based on the provided information) was 1.7 (95% CI, 0.2 to 6.3).168

##### Combination of TNF-Alpha Inhibitors, Immunomodulators, and Corticosteroids Versus No Therapy

The same claims-based study reported no lymphoma cases among 31 person-years of exposure to combination therapy with TNF-alpha inhibitors, immunomodulators, and corticosteroids, compared with 64 cases among 15,673 person-years of no therapy.168

##### Combination of TNF-Alpha Inhibitors and Immunomodulators Versus No Therapy

The same claims-based study reported one lymphoma case among 162 person-years of exposure to combination therapy with TNF-alpha inhibitors and immunomodulators (with or without corticosteroids), compared with 64 cases among 15,673 person-years of no therapy (less than one per 100 person-years in both groups).168 The corresponding unadjusted rate ratio was 1.5 (95% CI, 0 to 8.7).

##### Combination of TNF-Alpha Inhibitor and Corticosteroids Versus No Therapy

The same claims-based study reported no lymphoma cases among 142 person-years of exposure to combination therapy with TNF-alpha inhibitor and corticosteroids (with or without immunomodulators), compared with 64 cases among 15,673 person-years of no therapy.168

##### Other Combinations With Infliximab

Three retrospective cohorts including 954 patients described the safety profile of infliximab use at their study centers.137,145,164 As described in the mortality section, it is unclear if we have accurately classified patients by medication exposures. When these studies categorize patients who had received infliximab and immunomodulators at the time of lymphoma diagnosis as users of infliximab with immunomodulators at infliximab initiation, the three studies report four lymphomas. One of the studies reported four lymphomas among the 25 patients receiving infliximab in combination with immunomodulators and corticosteroids.164 The study reported no other lymphomas for the other treatment combinations (combination of infliximab, immunomodulators, and corticosteroids, combination of infliximab and corticosteroids, or infliximab alone).

#### Immunomodulators

Figure 14 summarizes the risk of lymphoma in observational studies evaluating immunomodulators in patients with Crohn's disease.

Figure 14 Summary of Peto odds ratios of lymphoma among observational studies comparing an immunomodulator alone or in combination with another treatment in patients with Crohn's disease

ASA = aminosalicylates; AZA = azathioprine; CaCo = case-control study; CI = confidence interval; Comp = comparison; IMM = immunomodulator; NR = not reported; OR = odds ratio; Pro = prospective cohort; Retro = retrospective cohort; STEROID = corticosteroids; THIO = thiopurine; TNF = tumor necrosis factor-alpha inhibitors

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Inflammatory bowel disease population

^‡^ Incidence rate ratio, 0.8 events per person-year (95% CI, 0.2 to 2.5)

^§^ Incidence rate ratio, 0 events per person-year (95% CI, 0 to 48.9)

^║^ Adjusted OR, 3.2 (95% CI, 1.0 to 10.2)

Figure 14 is a forest plot of diagram summarizing the Peto odds ratios of lymphoma among observational studies comparing an immunomodulator alone or in combination with another treatment. Seven studies, with eight comparisons, are included. The studies and their comparisons are: Beaugerie 2009, a prospective study comparing a thiopurine with a never user of a thiopurine; Fraser 2002, a retrospective study comparing azathioprine with no azathioprine; Lewis 2001, a retrospective study comparing a thiopurine with no thiopurine; Campbell 2001, a retrospective study comparing a combination of azathioprine and a 5-aminosalicylate acid with azathioprine only; Farrell 2000, a retrospective study comparing an immunomodulator with no immunomodulator; Marehbian 2009, a retrospective study with two combinations which are an immunomodulator with a combination of no TNF-alpha inhibitor, immunomodulator, nor corticosteroid; as well as a combination of an immunomodulator and a corticosteroid compared with a combination of no TNF-alpha inhibitor, immunomodulator, nor corticosteroid; and Armstrong 2010, a case-control study. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratios are: 3.3 and a 95% confidence interval of 1.4 to 7.5 for Beaugerie 2009, 1.6 and a 95% confidence interval of 0.3 to 7.3 for Fraser 2002, and 0.3 with a 95% confidence interval of 0.03 to 3.0 for Lewis 2001. The results are summarized in the preceding section.

##### Immunomodulators Versus No Immunomodulators

Two retrospective studies including 15,186 Crohn's disease patients reported lymphoma risk from immunomodulator use.136,168 A claims-based study including 8,581 Crohn's disease patients reported less than one lymphoma case per 100 person-years in both the no therapy group and the immunomodulator group (with or without corticosteroids or TNF-alpha inhibitors) (unadjusted relative rate, 0.8; 95% CI, 0.2 to 2.5).168 In one study comparing at least one prescription for a thiopurine with no thiopurine prescription, none of the 837 thiopurine users developed lymphoma, compared with seven of 5,768 non-users (less than 1 percent). The corresponding Peto OR was 0.3 (95% CI, 0 to 2.9).136

##### Combination of Immunomodulators and Corticosteroids Versus No Therapy

A claims-based study reported no lymphoma cases among patients receiving a combination of immunomodulators and corticosteroids (with or without TNF-alpha inhibitors), compared with less than one lymphoma per 100 person-years among patients receiving no therapy.168

##### Combination of Azathioprine and Aminosalicylates Versus Azathioprine

One retrospective study of 104 Crohn's disease patients reported a case of Waldenstrom's macroglobulinemia in the azathioprine and aminosalicylate group, compared with no lymphoma in the azathioprine-alone group.146

#### Corticosteroids

No trials that included corticosteroids reported on lymphoma. Table 41 summarizes the risk of lymphoma in observational studies evaluating corticosteroids in patients with Crohn's disease. We also provided additional details regarding related studies.

Table 41 Summary of risk of lymphoma in observational studies comparing a corticosteroid alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | Study Design | Corticosteroid | Comparison | # of Lymphoma Cases in Steroid Group | # of Patients in Steroid Group | # of Lymphoma Cases in Comparison Group | # of Patients in Comparison Group | Unadjusted Relative Measure (95% CI) | Adjusted Relative Measure (95% CI)
Lewis, 2001^136,*^ | 208 | Retrospective cohort | Steroid | No steroid | 4 | 4064 | 11 | 11100 | OR, 1.0 (0.3 to 3.1) | NR
Marehbian, 2009^168^ | 104 | Retrospective cohort | Steroid | No TNF or IMM or steroid | NR^†^ | NR | NR^‡^ | NR | IRR, 0 (0 to 2.5) | HR, 1.0 (0.4 to 2.4)

CI = confidence interval; HR = hazards ratio; IMM = immunomodulator; IRR = incidence rate ratio; NR = not reported; OR = odds ratio; Steroid = corticosteroid; TNF = tumor necrosis factor-alpha inhibitor

* Inflammatory bowel disease population

† There were 0 events during 379 person-years.

‡ There were 64 events during 15,673 person-years.

##### Corticosteroids Versus No Therapy

A claims-based study, that included 8,581 Crohn's disease patients, reported no lymphoma cases among the corticosteroid users (with or without immunomodulators or TNF-alpha inhibitors), compared with the no therapy group.168 The study reported a HR of 1.0 (95% CI, 0.4 to 2.4) comparing use of corticosteroids alone with no therapy, after adjustment for age, gender, geographic region, health plan, and comorbidity.

#### Studies Evaluating Patients with IBD

Seven studies reported on lymphoma risk in IBD patients without separating Crohn's disease from ulcerative colitis or indeterminate colitis patients. In general, the results were consistent between the studies. See Appendix F for more information about these studies.

#### Studies Reporting Results for Crohn's Disease and IBD

One retrospective study reported similar results for IBD patients as Crohn's disease patients, one lymphoma (less than 1 percent) among 1,465 thiopurine users compared with 14 lymphomas (less than 1 percent) among 15,531 non-users.136 The incidence density ratio comparing thiopurine to no thiopurine use was 0.8 for IBD, compared with the Peto OR of 0.3 for Crohn's disease. Neither was statistically significant. The study excluded a lymphoma case with diagnosis codes for both Crohn's disease and ulcerative colitis, according to the exclusion criteria. The patient had also received a liver transplant 4 months before the lymphoma diagnosis.

### Hepatosplenic T-Cell Lymphoma

The medical community first identified hepatosplenic T-cell lymphoma (HSTCL) as a diagnosis distinct from other T-cell lymphomas in 1996.^169^ HSTCL is a very rare type of lymphoma that is generally fatal.169 To assess the risk of HSTCL associated with treatment for Crohn's disease, we supplemented the primary search strategy by searching for case reports or case series published in the literature, or cases reported to the Food and Drug Administration's (FDA) Adverse Event Reporting System (AERS). A search of the publicly available AERS data files through March 2011 yielded 132 patient identification numbers representing 48 unique FDA-ascribed case numbers. From the literature and AERS search results, we considered 37 HSTCL cases unique based on age, sex, medications, country of origin, and length of survival. We considered two cases duplicative. We considered the remaining nine cases possibly unique. The case studies reported two of the 37 unique cases survived and none of the nine possibly unique cases survived (4 percent of 46 cases).

Tables 42 and 43 summarize the demographic and medication characteristics of the unique and possibly unique cases of HSTCL in patients with Crohn's disease. Of the 37 unique cases with Crohn's disease-associated HSTCL, most were young (86 percent younger than 40 years of age) and male (86 percent). Most cases (70 percent) had reported exposure to both a TNF-alpha inhibitor and thiopurines. Almost all cases (95 percent) had reported exposure to thiopurines compared with 75 percent who had exposure to at least one TNF-alpha inhibitor. Two cases (4 percent) reported exposure to a TNF-alpha inhibitor without thiopurines.

Table 42 Demographic and survival characteristics of patients with Crohn's disease who developed hepatosplenic T-cell lymphoma

Patient Characteristic | Unique Cases (n=37) | Possibly Unique Additional Cases (n=9)
Age at HSTCL diagnosis (in years) | N=36^*^ | N=0
Mean | 30 | --
Median | 26 | --
Range | 12 to 79 | --
Crohn's disease duration (in years) | N=16 | N=0
Mean | 10 | --
Median | 6 | --
Range | 4 to 35 | --
Sex, number of cases (%) | N=36 | N=6
Female | 5 (14%) | 1 (17%)
Survival, number of cases (%) | N=37 | N=9
Died | 24 (65%) | 4 (44%)
Survived | 2 (5%) | 0 (0%)
Outcome unclear or not reported | 11 (30%) | 5 (56%)

HSTCL = hepatosplenic T-cell lymphoma

* Number with report of characteristic. Mean and percentages based on this denominator.

Table 43 Medications used prior to diagnosis of hepatosplenic T-cell lymphoma in 37 unique patients with Crohn's disease

Medication | Number of Cases With Exposure (%) | Mean Cumulative Dose in Mg^*^ (Range) | Mean Duration of Drug Use in Years (Range) | Mean Number of Injections or Infusions (Range)
Biologics | 28 (76%) | -- | -- | --
Adalimumab | 8 (22%) | 920 (800-1040) | 1.5 (120 days-2.6 years) | 11.5 (10-13)
Infliximab | 27 (73%) | 41 (10-120) mg/kg | 1.8 (1 day-6 years) | 9 (1-24)
Natalizumab | 1 (3%) | NR | NR | 3 (n=1 )
Certolizumab pegol | 0 | NR | NR | NR
Thiopurines | 35 (95%) | -- | -- | --
6-mercaptopurine | 19 (51%) | 55,290 (3900-93530) | 4.5 (39 days-8 years) | NA
Azathioprine | 23 (62%) | 151,288 (1450-301,125) | 5.8 (39 days-13.5 years) | NA
Aminosalicylates | 15 (41%) | -- | -- | --
Balsalazide | 1 (3%) | NR | NR | NA
Mesalamine | 13 (35%) | NR | 5 (n=1) | NA
Salazopyrine | 2 (5%) | NR | 10 (n=1) | NA
Corticosteroids | 21 (57%) | -- | -- | --
Budesonide | 2 (5%) | NR | NR | NA
Hydrocortisone | 1 (3%) | NR | NR | NA
Prednisone | 14 (38%) | NR | NR | NA
Prednisolone | 4 (11%) | NR | 13 (n=1) | NA
Corticosteroid, unspecified | 6 (16%) | NR | 10 (n=1) | NA
Antibiotics^†^ | 7 (19%) | NR | NR | NA
Cyclosporine | 1 (3%) | NR | NR | NA

kg = kilograms; mg = milligrams; NA = not applicable; NR = not reported

* Reported as mg/kg for infliximab only

† The antibiotics used include ciprofloxacin, doxycycline, metronidazole, nitrofurantoin, and piperacillin/tazobactam.

### Cervical Cancer

One trial (n=660) reported on cervical cancer risk associated with medications for treatment of Crohn's disease. No trials of infliximab, adalimumab, natalizumab, immunomodulators, corticosteroids, or aminosalicylates reported on cervical cancer.

#### Certolizumab Pegol Versus Placebo

One RCT reported one carcinoma in situ of the cervix (grade 0) in a placebo patient (less than 1 percent of 197 females) and no cervical cancer in the 174 female certolizumab pegol patients during followup.39

#### Studies Evaluating Patients With Inflammatory Bowel Disease

Four observational studies reported on cervical cancer risk in IBD patients without separating Crohn's disease from ulcerative colitis or indeterminate colitis patients. We provided a summary of these studies in Appendix F.

#### Studies Reporting Results for Crohn's Disease and Inflammatory Bowel Disease

We did not identify any studies that reported on the comparative safety, in terms of cervical cancer, for patients with Crohn's disease and IBD.

### Other Cancers

Twenty-one RCTs including 7,149 Crohn's disease patients reported on other cancers by comparison group (Appendix D, Evidence Table 14). No methotrexate trial reported on cancer. One prospective (n=19,486), 12 retrospective (n=15,015), and one observational study of unclear study design (n=573)128 reported cancer as an outcome by comparison group.

#### Biologics

We summarized the risk of other cancers associated with treatment of Crohn's disease in Table 44 (for RCTs) and Figure 15 (for observational studies). We also provided additional details regarding related studies.

Table 44 Summary of the risk of other cancers in randomized controlled trials comparing a biologic alone or in combination with placebo or another treatment in patients with Crohn's disease^*^

Author, Year | Followup (Weeks) | Biologic | Comparison | # of Cancer Cases in Biologic Group | # of Patients in Biologic Group | # of Cancer Events in Comparison Group | # of Patients in Comparison Group
Sands, 2004^87^ | 40 | Infliximab | Placebo | 0 | 139 | 0 | 143
Hanauer, 2002^86^ | 52 | Infliximab | Placebo | 4 | 385 | 2 | 188
Sandborn, 2011^42^ | 6 | Certolizumab pegol | Placebo | 1 | 223 | 0 | 215
Schreiber, 2007^84^ | 18 | Certolizumab pegol | Placebo | 0 | 216 | 0 | 212
Sandborn, 2007^39^ | 26 | Certolizumab pegol | Placebo | 2 | 331 | 2 | 329
Schreiber, 2005^40^ | 12 | Certolizumab pegol | Placebo | 0 | 219 | 0 | 73
Sandborn, 2007^38^ | 4 | Adalimumab | Placebo | 0 | 159 | 0 | 166
Sandborn, 2007^83^ | 52 | Adalimumab | Placebo | 0 | 37 | 1 | 18
Colombel, 2007^82^ | 52 | Adalimumab | Placebo | 0 | 517 | 1 | 261
Targan, 2007^32^ | 12 | Natalizumab | Placebo | 1 | 260 | 0 | 250
Sandborn, 2005^33^ | 48 | Natalizumab | Placebo | 1 | 723 | 7 | 181
Colombel, 2010^45^ | 54 | Infliximab | Azathioprine | 0 | 163 | 2 | 161
Lemann, 2006^46^ | 24 | Infliximab + thiopurine | Thiopurine | 0 | 57 | 0 | 56
Colombel, 2010^45^ | 54 | Infliximab + azathioprine | Infliximab | 0 | 179 | 0 | 163
Colombel, 2010^45^ | 54 | Infliximab + azathioprine | Azathioprine | 0 | 179 | 2 | 161
Van Assche, 2008^89^ | 104 | Infliximab + immunomodulator | Infliximab | 0 | 40 | 2 | 40
Schroder, 2006^47^ | 48 | Infliximab + methotrexate | Infliximab | 0 | 11 | 0 | 8
Sands, 2007^35^ | 20 | Natalizumab + infliximab | Infliximab | 0 | 52 | 0 | 27

* Seven randomized controlled trials evaluating biologics did not report on any cancer outcomes.34,41,43,44,48,81,88

Figure 15 Summary of Peto odds ratios of cancer risk among observational studies comparing a biologic alone or in combination with another treatment in patients with Crohn's disease

BIO = biologics; CI = confidence interval; Comp = comparison; IFX = infliximab; IMM = immunomodulator; NR = not reported; OR = odds ratio; Pro = prospective cohort; Retro = retrospective cohort; STEROID = corticosteroids; THIO = thiopurine; TNF = tumor necrosis factor-alpha inhibitor

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Incidence rate ratio, 0.1 events per person-year (95% CI, 0.01 to 0.2)

^‡^ Incidence rate ratio, 0.9 events per person-year (95% CI, 0.6 to 1.4)

^§^ Incidence rate ratio, 0.7 events per person-year (95% CI, 0.1 to 2.1)

^║^ Incidence rate ratio, 0.6 events per person-year (95% CI, 0.3 to 1.0)

Figure 15 is a forest plot summarizing the Peto odds ratios of cancer among observational studies comparing a biologic alone or in combination with another treatment. Nine studies, with nineteen comparisons, are included. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratios are: 3.06 and a 95% confidence interval of 0.72 to 12.97 for Orlando 2005, 0.62 and a 95% confidence interval of 0.35 to 1.08 for Fidder 2009, 1.36 and a 95% confidence interval of 0.21 to 8.92 for Cottone 2010, and 1.29 a 95% confidence interval of 0.48 to 3.47 for Biancone 2006. The results are summarized in the preceding section.

##### Adalimumab Versus Placebo

Three RCTs including 1,158 Crohn's disease patients compared adalimumab with placebo and reported on cancer.37,38,82 A 4-week induction trial, including 325 patients randomized to adalimumab or placebo among patients who had lost response or were intolerant to infliximab, reported no cancers during the study period.38 A 52-week maintenance trial reported one cancer case in 261 placebo patients (less than 1 percent) and no cancer cases in 517 adalimumab patients.82 A 52-week maintenance trial of 276 responders to induction in a previous trial37 reported one cancer in 18 placebo patients, compared with no cancers in the 37 adalimumab patients who remained on randomized treatment during the entire study period.83

##### Other Combinations With Adalimumab

Two prospective (n=717)159,161 and one retrospective (n=118)140 study reported no deaths in patients who used adalimumab alone or in combination with aminosalicylates, corticosteroids, or immunomodulators.

##### Certolizumab Pegol Versus Placebo

Four RCTs including 1,818 Crohn's disease patients compared certolizumab pegol with placebo and reported on cancer.39,40,42,84 A 6-week induction trial reported one cancer (less than 1 percent) in the certolizumab pegol patients and no cancers in placebo.42 A 12-week induction trial (followed an additional 8 weeks for safety) reported no cancers in the 292 included patients.40 A 26-week induction trial reported two cancers in placebo patients (1 percent of 329) and two cancers in certolizumab pegol patients (1 percent of 331) during the study period.39 An 18-week maintenance trial reported no cancers during the study period.84 The trial reported one benign, malignant, or unspecified neoplasm (including cyst or polyp) during the 8-week induction phase which included 668 patients, but the trial did not provide specifics of the event.84

##### Other Combinations With Certolizumab Pegol

One prospective study (n=60) reported no deaths in patients who used certolizumab pegol alone or in combination with aminosalicylates, corticosteroids, or immunomodulators.132

##### Infliximab Versus Placebo

Two trials including 855 Crohn's disease patients reported on cancer risk.86 87 A maintenance trial reported one case of cancer in the 10 mg/kg intravenous every 8 weeks infliximab group, three cases in the 5 mg/kg intravenous every 8 weeks infliximab group, and two cases in the placebo group over 52 weeks of followup.86 A maintenance trial of fistulizing Crohn's disease reported no cancers during the 40-week trial period.87 Two cancers occurred after the trial ended. Both patients had received infliximab.

##### Infliximab Versus No Infliximab

One retrospective study including 808 Crohn's disease patients reported on cancer, comparing infliximab use with no use.149 The study reported nine cancers among 404 infliximab users followed for 48 months, compared with seven cancers among 404 no infliximab users followed for 60 months (2 percent in both groups). The study matched the two groups by factors including age, sex, followup, immunomodulator use, Crohn's disease site, Crohn's disease duration, and study center.149 The OR was 1.3 (95% CI, 0.5 to 3.8) comparing infliximab users with infliximab non-users accounting for the matching factors.149 Another study reporting results from the same infliximab patients,128 compared a combination of infliximab and immunomodulators with infliximab alone and reported one additional case of cancer among infliximab users.

##### Infliximab Versus Immunomodulators

One induction trial of 324 Crohn's disease patients, naïve to TNF-alpha inhibitors and immunomodulators, compared infliximab with azathioprine and reported mortality.45 The trial did not report any cancers in the 163 infliximab patients, and reported two cancers in the 161 azathioprine patients during the 50-week study period.

##### Combination of Infliximab and Immunomodulators Versus Infliximab

Three RCTs45,47,89 and two observational studies128,129 reporting on cancer risk (1,135 Crohn's disease patients total) compared a combination of infliximab and immunomodulators versus infliximab alone. The RCTs included 441 patients. One induction trial of 342 patients, naïve to TNF-alpha inhibitors and immunomodulators, reported no cancers during the 50-week study period in the combination infliximab and azathioprine, and infliximab alone groups.45 An open-label trial of 19 azathioprine intolerant or resistant patients compared a combination of infliximab and methotrexate with infliximab alone, and reported no malignancies during the 48-week study period.47 An 104-week open-label RCT of 80 non-fistulizing Crohn's disease patients, retreated with infliximab while continuing or discontinuing immunomodulators, reported two cancers in the infliximab group and no cancers in the combination infliximab and immunomodulators group.89

In the observational studies, one retrospective study of 573 Crohn's disease patients, followed for 12 weeks or 6 months, reported five cancers among 211 combination infliximab and immunomodulator patients and three cancers in 362 patients using infliximab without immunomodulators.128 The corresponding Peto OR was 2.9 (95% CI, 0.6 to 18.9). The other study reported no cancers.129

##### Combination of Infliximab and Immunomodulators Versus Immunomodulators

Two RCTs including 453 Crohn's disease patients compared a combination of infliximab and immunomodulators with immunomodulators alone and reported on cancer.45 46 One induction trial of Crohn's disease patients naïve to TNF-alpha inhibitors and immunomodulators reported no cancers in the 179 patients taking infliximab and azathioprine and two cancers in the 161 patients taking azathioprine during the 50-week study period.45 A 52-week induction trial of 113 steroid-dependent Crohn's disease patients with luminal disease reported no cancers during the study period, comparing combination infliximab and thiopurines with thiopurines alone.46

##### Other Combinations With Infliximab

Four retrospective trials including 1,069 Crohn's disease patients studied the safety profile of infliximab use at their centers.137,145,147,164 The trials met the inclusion criteria but may have misclassified the cancer cases' concomitant medications. We described this in detail in the mortality section. The trials reported one cancer in patients receiving a triple combination of infliximab, immunomodulators, and corticosteroids, or a combination of infliximab and corticosteroids. One trial reported cancers in three of 51 patients (6 percent) taking infliximab and an immunomodulator and one of 19 patients (5 percent) taking infliximab.145 One study reported one cancer among 30 patients who used adalimumab after infliximab, compared with four cancers among 127 who did not subsequently use adalimumab.145 The other three studies reported eight cancers in patients taking infliximab and an immunomodulator, one cancer in patients taking infliximab with corticosteroids, and five cancers in patients not receiving concomitant medications.137,147,164

##### Natalizumab Versus Placebo

Three RCTs including 1,414 Crohn's disease patients reported on cancer risk comparing natalizumab with placebo (reported in two publications).32 33 A 12-week induction trial reported one basal cell carcinoma in the natalizumab group (1 out of 260) and no cancers in the 250 placebo patients.32 A 12-week induction trial, followed by randomization of the responders to a 48-week maintenance trial, reported no cancers during the induction trial.33 In the maintenance trial, one natalizumab patient (out of 214) and one placebo patient (out of 214) developed cancer.33

##### Combination of Natalizumab With Infliximab Versus Infliximab

One RCT including 79 Crohn's disease patients compared a combination of natalizumab and infliximab with infliximab alone and reported on cancer. The 20-week trial reported that no cancers occurred.35

##### TNF-Alpha Inhibitors Versus No Therapy

A claims-based study, that included 8,581 Crohn's disease patients, reported two solid tumor cancer cases among 92 person-years of exposure to TNF-alpha inhibitors (with or without immunomodulators or corticosteroids), compared with 2,115 cases among 15,673 person-years of no therapy.168 The study reported an adjusted HR of 1.0 (95% CI, 0.7 to 1.3) for TNF-alpha inhibitors (with or without immunomodulators or corticosteroids) compared with no therapy, and an adjusted HR of 1.0 (95% CI, 0.8 to 1.3) for TNF-alpha inhibitors compared with no therapy (HRs adjusted for age, gender, geographic region, health plan, and comorbidity). An unadjusted rate ratio of 0.2 (95% CI, 0 to 0.6) favored TNF-alpha inhibitors (with or without immunomodulators or corticosteroids) over no therapy using the cancer cases and person-time provided.

##### TNF-Alpha Inhibitors Versus Never User of Biologic

A collection of referral centers reported 3 percent of adalimumab or infliximab patients and 3 percent of patients who never used biologics developed cancer over 104 weeks of followup.150

##### Combination of TNF-Alpha Inhibitors, Immunomodulators, and Corticosteroids Versus No Therapy

A claims-based study that included 8,581 Crohn's disease patients reported three cancer cases among 31 person-years of exposure to TNF-alpha inhibitors with immunomodulators and corticosteroids, compared with 2,115 cases among 15,673 person-years of no therapy.168 The study reported an adjusted HR of 0.9 (95% CI, 0.3 to 2.4), comparing the 10 cancers per 100 person-years in the combination TNF-alpha inhibitor, immunomodulators, and corticosteroids group with 13 cancers per 100 person-years in the no therapy group. These estimates are consistent with an unadjusted rate ratio of 0.7 (95% CI, 0.1 to 2.1).

##### Combination of TNF-Alpha Inhibitors and Immunomodulators Versus No Therapy

The same claims-based study reported 20 cancer cases among 162 person-years of exposure to TNF-alpha inhibitor with immunomodulators (with or without corticosteroids), compared with 2,115 cases among 15,673 person-years of no therapy.168 The study reported an adjusted HR of 1.1 (95% CI, 0.7 to 1.8). The corresponding unadjusted rate ratio was 0.9 (95% CI, 0.6 to 1.4).

##### Combination of TNF-Alpha Inhibitors and Corticosteroids Versus No Therapy

The same claims-based study reported 11 cancer cases among 142 person-years of exposure to TNF-alpha inhibitors with corticosteroids (with or without immunomodulators), compared with 2,115 cases among 15,673 person-years of no therapy.168 The study reported an adjusted HR of 0.3 (95% CI, 0 to 2.3). The corresponding unadjusted rate ratio was 0.6 (95% CI, 0.3 to 1.0).

#### Immunomodulators

We summarized the risk of other cancers associated with use of immunomodulators for Crohn's disease in Table 45 (for RCTs) and Figure 16 (for observational studies). We also provided additional details regarding related studies.

Table 45 Summary of the risk of other cancers in randomized controlled trials comparing an immunomodulator alone or in combination with placebo or another treatment in patients with Crohn's disease^*^

Author, Year | Follow-up (Weeks) | IMM | Comparison | # of Cancer Cases in IMM Group | # of Patients in IMM Group | # of Cancer Cases in Comparison Group | # of Patients in Comparison Group
Summers, 1979^56^ | 104 | Azathioprine | Placebo | 0 | 113 | 0 | 178
Summers, 1979^56^ | 104 | Azathioprine | Prednisone | 0 | 113 | 1 | 146
Summers, 1979^56^ | 104 | Azathioprine | Sulfasalazine | 0 | 113 | 0 | 132

IMM = immunomodulator

* We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

Figure 16 Summary of Peto odds ratios of cancer among observational studies comparing an immunomodulator alone or in combination with another treatment in patients with Crohn's disease

ASA = aminosalicylates; AZA = azathioprine; CaCo = case-control study; CI = confidence interval; Comp = comparison; IMM = immunomodulator; NR = not reported; OR = odds ratio; Pro = prospective cohort; Retro = retrospective cohort; STEROID = corticosteroids; THIO = thiopurine; TNF = tumor necrosis factor-alpha inhibitors

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Adjusted OR, 2.1 (95% CI, 1.3 to 3.3)

^‡^ Incidence rate ratio, 0.02 events per person-year (95% CI, 0.005 to 0.07)

^§^ Incidence rate ratio, 0 events per person-year (95% CI, 0 to 1.4)

Figure 16 is a forest plot summarizing Peto odds ratios of cancer among observational studies comparing an immunomodulator alone or in combination with another treatment. Six studies, with seven comparisons are included. The studies and their comparisons are: Farrell 2000, a retrospective study comparing an immunomodulator with a never use of an immunomodulator; Beaugerie 2009, a prospective study comparing a thiopurine with never users of a thiopurine; Fraser 2002, a retrospective study comparing azathioprine with no azathioprine; Campbell 2001, a retrospective study comparing a combination of azathioprine and 5-aminosalicylate acids with azathioprine alone; Armstrong 2010 a case control study comparing an immunomodulator with no immunomodulator; and Marehbian 2009, a retrospective study with two combinations: one was an immunomodulator compared with no TNF-alpha inhibitor, immunomodulator, nor corticosteroid, and the other was a combination of an immunomodulator and corticosteroids compared with no TNF-alpha inhibitor, immunomodulator, nor corticosteroid. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratios are: 2.22 and a 95% confidence interval of 1.00 to 4.90 for Farrell 2000, 1.45 and a 95% confidence interval of 1.15 to 1.84 for Beaugerie 2009, and 1.90 and a 95% confidence interval of 0.70 to 1.69 for Fraser 2002. The results are summarized in the preceding section.

##### Azathioprine Versus Placebo

One RCT including 291 Crohn's disease patients compared azathioprine with placebo and reported on cancer risk.56 The trial did not report any cancers during the 2-year period.

##### Azathioprine Versus Prednisone

One 2-year RCT included 259 Crohn's disease patients in an azathioprine versus prednisone comparison and reported no cancers in 113 azathioprine and one cancer in 146 prednisone patients.56

##### Azathioprine Versus Sulfasalazine

The same 2-year RCT included 245 patients in an azathioprine versus sulfasalazine comparison and reported no cancers in either group.56

##### Combination Azathioprine and Aminosalicylates Versus Azathioprine

A retrospective chart review in 104 Crohn's disease patients compared a combination of azathioprine and aminosalicylates with azathioprine and reported on cancer risk.146 The review required that all patients have at least 6 months of azathioprine use, no side effects to azathioprine, and be in remission to be eligible. The reviews reported one Waldenstrom's macroglobulinemia among 48 patients on a combination of azathioprine and aminosalicylates, compared with no cancers among 56 patients receiving azathioprine without aminosalicylates. The review also reported Waldenstrom's macroglobulinemia in its lymphoma section.

##### Immunomodulators Versus No Therapy

A claims-based study that included 8,581 Crohn's disease patients reported three cancer cases among 911 person-years of exposure to immunomodulators (with or without corticosteroids or TNF-alpha inhibitors), compared with 2,115 cases among 15,673 person-years of no therapy.168 The study reported an adjusted HR of 1.2 (95% CI, 1.0 to 1.4). The corresponding unadjusted rate ratio is 0 (95% CI, 0 to 0.1). The study also reported an adjusted HR of 1.2 (95% CI, 1.0 to 1.4) comparing immunomodulators (with no corticosteroids and no TNF-alpha inhibitor) with no therapy.168

##### Combination of Immunomodulators and Corticosteroids Versus No Therapy

The same claims-based study reported no cancer cases among 19 person-years of exposure to immunomodulators with corticosteroids (with or without TNF-alpha inhibitors), compared with 2,115 cases among 15,673 person-years of no therapy.168 The study reported an adjusted HR of 1.0 (95% CI, 0.7 to 1.4). The corresponding unadjusted rate ratio is not estimable because of the absence of events in the group receiving a combination of immunomodulators and corticosteroids.

#### Corticosteroids

Table 46 summarizes the risk of other cancers in RCTs and observational studies evaluating corticosteroids in patients with Crohn's disease.

Table 46 Summary of the risk of other cancers in randomized controlled trials and observational studies comparing a corticosteroid alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | Study Design | Corticosteroid | Comparison | # of Cancer Cases in Steroid Group | # of Patients in Steroid Group | # of Cancer Cases in Comparison Group | # of Patients in Comparison Group | Unadjusted Relative Measure^*^ (95% CI) | Adjusted Relative Measure (95% CI)
Summers, 1979^56^ | 104 | RCT | Prednisone | Placebo | 1 | 146 | 0 | 178 | (Excluded) | NR
Summers, 1979^56^ | 104 | RCT | Prednisone | Sulfasalazine | 1 | 146 | 0 | 132 | (Excluded) | NR
Marehbian, 2009^168^ | 104 | Retrospective cohort | Steroid | No TNF or IMM or Steroid | NR^†^ | NR | NR^‡^ | NR | IRR, 0 (0 to 0.7) | HR, 1.1 (0.9 to 1.3)

CI = confidence interval; HR = hazards ratio; IMM = immunomodulator; IRR = incidence rate ratio; NR = not reported; RCT = randomized controlled trial; Steroid = corticosteroid; TNF = tumor necrosis factor-alpha inhibitor

* We did not calculate relative measures when there were fewer than five events total in the main intervention and comparison arms.

† There were 0 events during 379 person-years.

‡ There were 2115 events during 15,673 person-years.

##### Prednisone Versus Placebo

One 2-year RCT, that included 324 Crohn's disease patients in a prednisone versus placebo comparison, reported one cancer in 146 patients on prednisone and no cancers in 178 patients taking placebo.56

##### Prednisone Versus Sulfasalazine

The same 2-year RCT that included 278 Crohn's disease patients in a prednisone versus sulfasalzine comparison reported one cancer in 146 patients on prednisone and no cancers in 132 patients taking sulfasalazine.56

##### Corticosteroids Versus No Therapy

A claims-based study, that included 8,581 Crohn's disease patients, reported no cancer cases among 379 person-years of exposure to corticosteroids (with or without immunomodulators or TNF-alpha inhibitors), compared with 2,115 cases among 15,673 person-years of no therapy.168 The study reported an adjusted HR of 1.1 (95% CI, 0.9 to 1.3). The corresponding unadjusted rate ratio is not estimable because of a lack of events in the corticosteroids group. The study also reported a HR comparing corticosteroids (with no immunomodulators and no TNF-alpha inhibitors) with no therapy (adjusted HR, 1.0; 95% CI, 0.8 to 1.3).168

#### Aminosalicylates

Table 47 summarizes the risk of other cancers in the one RCT reporting on cancer risk associated with use of aminosalicylates in patients with Crohn's disease.

Table 47 Summary of the risk of other cancers in a randomized controlled trial comparing an aminosalicylate with placebo in patients with Crohn's disease

Author, Year | Followup (Weeks) | ASA | Comparison | # of Cancer Cases in ASA Group | # of Patients in ASA Group | # of Cancer Cases in Comparison Group | # of Patients in Comparison Group
Summers, 1979^56^ | 104 | Sulfasalazine | Placebo | 0 | 132 | 0 | 178

ASA = aminosalicylates

##### Sulfasalazine Versus Placebo

A 2-year RCT including 310 Crohn's disease patients reported no cancers in the sulfasalazine and placebo groups.56

#### Studies Evaluating Patients With IBD

Seven studies reported other cancers in IBD patients without separating Crohn's disease from ulcerative colitis or indeterminate colitis patients. We provided information about these studies in Appendix F.

#### Studies Reporting Results for Crohn's Disease and IBD

The retrospective chart review that reported a Waldenstrom's macroglobulinemia in a Crohn's disease patient reported no additional cancers among the 82 ulcerative colitis patients who received azathioprine with or without aminosalicylates.146

#### Case-Control Studies Designed To Examine Specific Cancers

Four case-control studies including 3,554 patients examined specific cancers. Two studies included only Crohn's disease patients.143,170 Two studies conducted nested-case control studies using a claims databases.170,171 A study of small bowel cancer risk included only patients with small bowel Crohn's disease.143 A study of colon cancer risk included only patients with colonic IBD.172

##### Comparisons Including TNF-Alpha Inhibitor

A claims database study of TNF-alpha inhibitors and immunomodulators included 1,935 Crohn's disease patients and followed them for a median of 484 days. The study reported on the relationship between the risk of non-melanoma skin cancer and either recent medication use (a pharmacy claim within 90 days of diagnosis) or persistence use (recent medication use plus a pharmacy claim greater than 365 days prior to diagnosis).170 The TNF-alpha inhibitors included infliximab and adalimumab. The immunomodulators included thiopurines, methotrexate, calcineurin inhibitor, and mycophenolate mofetil. Sixty-five percent of non-melanoma skin cancer cases and 86 percent of controls did not have a TNF-alpha inhibitor or immunomodulator claim within 90 days of the index date. Six percent of 387 cases and 1 percent of 1,548 controls were recent users of both TNF-alpha inhibitors and immunomodulators (Medicaid insurance adjusted OR compared with no use of TNF-alpha inhibitors or immunomodulators, 5.9; 95% CI, 3.2 to 10.8). Five percent of 228 cases and 1 percent of 913 controls had persistent use of a TNF-alpha inhibitor and immunomodulator (Medicaid insurance adjusted OR, 6.8; 95% CI, 2.7 to 16.7). Comparing TNF-alpha inhibitor use with no TNF-alpha inhibitor and no immunomodulator use, 4 percent of 387 cases and 2 percent of 1,548 controls were recent users of a TNF-alpha inhibitor (Medicaid insurance adjusted OR, 2.5; 95% CI, 1.3 to 4.7) and 3 percent of 228 cases and 1 percent of 913 controls were persistent users of a TNF-alpha inhibitor (Medicaid insurance adjusted OR, 3.2; 95% CI, 1.2 to 8.5). Comparing TNF-alpha inhibitor use versus no use, cases were more likely to be recent (immunomodulators and Medicaid insurance adjusted OR, 2.1; 95% CI, 1.3 to 3.3) and persistent (immunomodulators and Medicaid insurance adjusted OR, 2.2; 95% CI, 1.1 to 4.5) users of TNF-alpha inhibitor.

##### Comparisons Including Immunomodulators

Four case-control studies including 3,554 patients compared an immunomodulator with other medications.143,170-172 One of these was the claims database study that included 1,935 Crohn's disease patients. This study evaluated the relationship between thiopurine use and non-melanoma skin cancer risk.170 Cases were more likely to be recent (OR adjusted for Medicaid insurance and use of other immunomodulators and TNF-alpha inhibitors, 3.8; 95% CI, 2.9 to 5.2) and persistent (OR adjusted for Medicaid insurance and other immunomodulators and TNF-alpha inhibitors, 4.3; 95% CI, 2.8 to 6.4) users of thiopurines, compared with controls. This study also compared methotrexate with no methotrexate use. Cases were more likely to be recent (OR adjusted for Medicaid insurance and other immunomodulators and TNF-alpha inhibitors, 1.6; 95% CI, 0.6 to 4.3) and persistent (OR adjusted for Medicaid insurance and other immunomodulators and TNF-alpha inhibitors, 2.7; 95% CI, 0.6 to 11.6) users of methotrexate compared with controls, although these associations were not statistically significant.

A case-control study of 35 Crohn's disease patients compared seven small bowel adenocarcinoma cases with controls matched on age, sex, and small bowel Crohn's disease.143 The medical charts for two of seven (29 percent) cases showed at least 6 months of 6-mercaptopurine use, compared with one of 28 controls (4 percent; OR, 10.8; 95% CI, 1.1 to 108.7).

A case-control study of 48 patients with colonic IBD compared thiopurines use with non-use.172 One of 18 colorectal cancer cases and four of 30 controls had thiopurine use in their paper or electronic medical record. The corresponding Peto OR is 0.4 (95% CI, 0 to 4.4). None of the patients in the study had a record of TNF-alpha inhibitor and methotrexate use.

A case-control study using International Classification of Diseases, Ninth Revision, Clinical Modification claim codes, and outpatient pharmacy claims identified 364 colorectal cancer cases and 1,172 controls without a record of colorectal cancer or bowel surgery.171 In the 12 months prior to or on the date of the colorectal cancer diagnosis, 41 of 364 cases (11 percent) and 101 of 1,172 controls (9 percent) had a pharmacy claim for immunomodulators. The study reported a crude OR of 1.4 (95% CI, 0.9 to 2.0), comparing immunomodulator use with no immunomodulator use.

##### Comparisons Including Corticosteroids

Three case-control studies including 1,619 patients compared corticosteroid with other medications.143,171,172 A case-control study of 35 Crohn's disease patients compared prednisone with no prednisone.143 Five of seven cases (71 percent) had a record of prednisone use for at least 6 months prior to small bowel adenocarcinoma diagnosis, compared with 17 of 28 controls (61 percent). The corresponding Peto OR was 1.6 (95% CI, 0.2 to 19.6). The case-control study of 48 IBD patients reported that 15 of 18 colorectal cancer cases (83 percent) and 25 of 30 controls (83 percent) had a record of corticosteroids use.172 The corresponding Peto OR was 1.0 (95% CI, 0.2 to 7.4). A claims-based study of colorectal cancer in IBD reported 28 percent of 364 colorectal cancer cases, and 21 percent of 1,172 controls had a pharmacy claim for corticosteroids in the 12 months prior to or on the date of the colorectal cancer diagnosis.171 The study reported a crude OR of 1.4 (95% CI, 1.1 to 1.9).

##### Comparisons Including Aminosalicylates

Three case-control studies including 1,619 patients reported a comparison of outcomes related to aminosalicylate use.143,171,172 A case-control study of 35 Crohn's disease patients reported four of seven cases (57 percent) had a record of sulfasalazine use for at least 6 months prior to small bowel adenocarcinoma diagnosis, compared with 19 of 28 controls (68 percent).143 The corresponding Peto OR was 0.6 (95% CI, 0.1 to 5.3). A case-control study of 48 IBD patients reported 15 of 18 colorectal cancer cases (83 percent), and 29 of 30 controls (97 percent) had a record of mesalamine use.172 The corresponding Peto OR was 0.2 (95% CI, 0 to 2.4).

A claims-based case-control study of colorectal cancer in IBD reported 43 percent of 364 colorectal cancer cases, and 44 percent of 1,172 controls had a pharmacy claim for aminosalicylates in the 12 months prior to or on the date of the colorectal cancer diagnosis (crude OR, 1.0; 95% CI, 0.8 to 1.2).171 The comparison of aminosalicylates with colorectal cancer risk was the primary aim of the study. They also reported relationships with colorectal cancer risk for the different aminosalicylate formulations (mesalamine OR, 0.9; 95% CI, 0.7 to 1.2; sulfasalazine OR, 1.2; 95% CI, 0.8 to 1.7; and balsalazide OR, 1.3; 95% CI, 0.7 to 2.4). When they performed a test for trend to examine a relationship between number of aminosalicylate prescription claims in the 12 months prior to diagnosis and odds of colorectal cancer, they observed a p-value for trend of borderline statistical significance for any aminosalicylate (P=0.11) and mesalamine (P=0.08) but not sulfasalazine (P=0.27). They did not report a test of trend p-value for balsalazide.

##### Studies Reporting for Crohn's Disease and IBD

A claims-based study of non-melanoma skin cancer reported results for all IBD patients, and also reported results exclusively for Crohn's disease patients.170 The results for thiopurine use versus no thiopurine use in IBD patients were similar in direction for the Crohn's disease patients, (IBD OR, 3.1; 95% CI, 2.1 to 4.5; Crohn's disease OR, 3.9; 95% CI, 2.9 to 5.2), when adjusted for other classes of medications and Medicaid insurance status. The authors stated that because infliximab was approved for ulcerative colitis after the study period ended in June 2005, they did not calculate TNF-alpha inhibitor and combination TNF-alpha inhibitor and immunomodulators versus no immunomodulators ORs for all IBD patients. They also stated that they did not report the methotrexate relationship, because methotrexate use is not indicated for the treatment of ulcerative colitis in the U.S.170

### Infections

Immune suppression caused by medications to treat Crohn's disease or the disease itself might increase the risk of infection. These infections can range from relatively mild to life threatening. Because serious infections, that may be life threatening or associated with hospitalization, have different implications for clinical care and patient quality of life, we have indicated when studies reported serious infections compared with any infection, regardless of severity. We have also indicated when the study considered an infection opportunistic.

Sixty-one studies including 42,008 patients reported on infections (Appendix D, Evidence Table 14). Thirty-eight RCTs including 8,435 patients reported infections as an outcome by comparison of interest. Four prospective studies (n=7,253), 17 retrospective studies (n=23,782), and two case-control studies (n=2,538) reported infections by a comparison of interest. Infections were a primary outcome of interest in 17 studies.

#### Natalizumab

In Figures 17 and 18 we summarize the serious infections and any infections reported by RCTs evaluating natalizumab. In Table 48 we listed the RCTs evaluating natalizumab that reported no opportunistic infections. We also provided additional details regarding related studies.

Figure 17 Summary of Peto odds ratios of serious infections among randomized controlled trials comparing a biologic alone or in combination with placebo or another treatment in patients with Crohn's disease

CI = confidence interval; Comp = comparison; i = induction trial; IFX = infliximab; m = maintenance trial; Main = main intervention; NAT = natalizumab; OR = odds ratio

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

Figure 17 is a forest plot summarizing the Peto odds ratios of serious infections among randomized controlled trials comparing a biologic alone or in combination with placebo or another treatment. Four trials are included. The trials and their comparisons are: the Sandborn 2005 maintenance trial comparing natalizumab with placebo, Targan 2007 comparing natalizumab with placebo, the Sandborn 2005 induction trial comparing natalizumab and placebo, and Sands 2007 comparing a combination of natalizumab and infliximab with infliximab. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratios are: 1.2 and a 95% confidence interval of 0.4 to 4.0 for Sandborn 2005 maintenance trial, 0.3 and a 95% confidence interval of 0.1 to 1.7 for Targan 2007, and 0.7 and a 95% confidence interval of 0.2 to 2.5 for the Sandborn 2005 induction trial. The results are summarized in the preceding section.

Figure 18 Summary of Peto odds ratios of other infections among randomized controlled trials comparing a biologic alone or in combination with placebo or another treatment in patients with Crohn's disease

CI = confidence interval; Comp = comparison; i = induction trial; IFX = infliximab; m = maintenance trial; Main = main intervention; NAT = natalizumab; NR = not reported; OR = odds ratio

Figure 18 is a forest plot summarizing the Peto odds ratios of other infections among randomized controlled trials comparing a biologic alone or in combinations with placebo or another treatment. Four trials are included. The trials and their comparisons are: Sands 2007 comparing a combination of natalizumab and infliximab with infliximab; the Sandborn 2005 maintenance trial comparing natalizumab with placebo; the Sandborn 2005 induction trial comparing natalizumab with placebo; and, Targan 2007 comparing natalizumab with placebo. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in the main intervention. The calculated odds ratio are: 0.9 and a 95% confidence interval of 0.3 to 2.5 for Sands 2007, 1.3 and a 95% confidence interval of 0.9 to 1.9 for the Sandborn 2005 maintenance trial, 1.3 and a 95% confidence interval of 0.9 to 1.7 for the Sandborn 2005 induction trial, and 1.2 and a 95% confidence interval of 0.9 to 1.8 for Targan 2007. The results are summarized in the previous section.

Table 48 Summary of the randomized controlled trials reporting no opportunistic infections when comparing the effectiveness of a biologic alone or in combination with placebo or another treatment in patients with Crohn's disease

Biologic | Comparison | # of Trials Reporting No Events | Range of Followup (Weeks) | # Participants in Biologic Group | # Participants in Comparison Group
Natalizumab | Placebo | 1^32^ | 8 | 260 | 250
Natalizumab + infliximab | Infliximab | 1^35^ | NR | 52 | 27

NR = not reported

##### Natalizumab Versus Placebo

Three natalizumab versus placebo RCTs including 1,414 Crohn's disease patients reported on infections in two publications.32,33

###### Serious Infections

All three trials reported on serious infections.32,33 Serious infections were rare with natalizumab patients (less than 1 to 3 percent) and placebo patients (2 percent).

###### Opportunistic Infections

One RCT including 510 patients reported no opportunistic infections (including PML) during the study period.32

###### Any Infection

Three trials including 1,414 patients reported on any infection.32,33 Infections (including serious) were more common in natalizumab patients (35 to 62 percent) than placebo patients (30 to 56 percent).

##### Combination of Natalizumab and Infliximab Versus Infliximab

One RCT including 79 Crohn's disease patients reported on infections comparing a combination of natalizumab and infliximab with infliximab alone in initial non-responders to infliximab.35

###### Serious Infections

There were no trials that reported serious infections during the study period.35

###### Opportunistic Infections

There were no trials that reported opportunistic infections during the study period.35

###### Any Infection

One trial reported infections in 14 out of 52 patients taking natalizumab and infliximab (27 percent) and eight out of 27 patients taking infliximab (30 percent ).35

#### TNF-Alpha Inhibitors

We did not conduct a meta-analysis of the RCTs comparing TNF-alpha inhibitors with placebo in terms of serious infections, because four out of the five trials had fewer than five events. Figures 19 and 20 summarize the RCTs and observational studies evaluating TNF-alpha inhibitors in terms of serious infections. Figure 21 summarizes the opportunistic infections reported in RCTs evaluating TNF-alpha inhibitors. Figure 22 and Table 49 summarize any infections reported in RCTs and observational studies evaluating TNF-alpha inhibitors. We also provided additional details regarding related studies.

Figure 19 Summary of Peto odds ratios of serious infections among randomized controlled trials comparing a TNF-alpha inhibitor alone or in combination with placebo or another treatment in patients with Crohn's disease

6-Methylpred = 6-methylprednisolone; ADA = adalimumab; AZA = azathioprine; BUDE = budesonide; CI = confidence interval; Comp = comparison; CP = certolizumab pegol; IFX = infliximab; MTX = methotrexate; OR = odds ratio; TNF = tumor necrosis factor-alpha inhibitor

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ The number of events is for serious cases of perianal abscess or fistula.

^‡^ The number of events is for serious cases of pneumonia.

^§^ The number of events is for serious cases of hepatitis C.

Figure 19 is a forest plot type of diagram summarizing the Peto odds ratios of serious infections among randomized controlled trials comparing a TNF-alpha inhibitor alone or in combination with placebo or another treatment. 12 trials, and 17 comparisons, are included. The trials and their comparisons are: Colombel 2010, which had three comparisons: one comparing a combination of azathioprine and infliximab with a combination of azathioprine and placebo, another comparing a combination of infliximab and placebo compared with a combination of azathioprine and placebo, and also a combination of azathioprine and infliximab compared with a combination of infliximab and placebo; D'Haens 2008 has three comparison, one comparing a combination of infliximab and azathioprine with a combination of budesonide and 6-methylprednisolone, and two others comparing a combination of infliximab and azathioprine with a combination of budesonide and 6-methylprednisolone; Colombel 2007 comparing adalimumab with placebo; Schreiber 2007 comparing certolizumab pegol with placebo; Sandborn 2007 has three combinations, one comparing certolizumab pegol with placebo, and the other two comparing adalimumab with placebo; Sands 2004 comparing infliximab with placebo, Hanauer 2002 comparing infliximab with placebo; Schroder 2006 comparing a combination of infliximab and methotrexate with infliximab; Hanauer 2006 comparing adalimumab with placebo; Winter 2004 comparing certolizumab pegol with placebo; and, Schreiber 2005 comparing certolizumab pegol with placebo. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in the main intervention. The calculated odds ratio are: 0.7 and a 95% confidence interval of 0.3 to 1.9 for Colombel 2010 comparing a combination of azathioprine and infliximab with a combination azathioprine and placebo; 0.9 and a 95% confidence interval of 0.3 to 2.3 for Colombel 2010 comparing a combination of infliximab and placebo with azathioprine and placebo, 0.4 and a 95% confidence interval of 0.1 to 1.5 for D'Haens 2006 comparing a combination of infliximab and infliximab with a combination of infliximab and placebo with a combination of budesonide and 6-methylprednisolone; 0.8 and a 95% confidence interval of 0.3 to 2.2 for Colombel 2010 comparing a combination of azathioprine and infliximab with a combination of infliximab and placebo; 0.8 and a 95% confidence interval of 0.3 to 1.9 for Colombel 2007; 2.7 and a 95% confidence interval of 0.7 to 11.0 for Schreiber 2007; 2.2 and a 95% confidence interval of 0.6 to 7.8 for Sandborn 2007 comparing certolizumab pegol and placebo; 0.5 and a 95% confidence interval of 0.2 to 1.4 for Sands 2004; 0.9 and a 95% confidence interval of0.3 to 2.1 for Hanauer 2002. The results are summarized in the previous section.

Figure 20 Summary of Peto odds ratios of serious infections among observational studies comparing a TNF-alpha inhibitor alone or in combination with placebo or another treatment in patients with Crohn's disease

ADA = adalimumab; ASA = aminosalicylates; BIO = biologics; CI = confidence interval; Comp = comparison; IFX = infliximab; IMM = immunomodulator; NR = not reported; OR = odds ratio; Pro = prospective cohort; Retro = retrospective cohort; STEROID = corticosteroids; TNF = tumor necrosis factor-alpha inhibitor

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Adjusted relative risk, 2.2 (95% CI, 1.4 to 3.2)

Figure 20 is a forest plot summarizing the Peto odds of ratios serious infections among observational studies comparing a TNF-alpha inhibitor alone or in combination with placebo or another treatment. Eight studies, with 15 comparisons, are included. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The results are summarized in the previous section.

Figure 21 Summary of Peto odds ratios of opportunistic infections among randomized controlled trials comparing a TNF-alpha inhibitor alone or in combination with placebo or another treatment in patients with Crohn's disease

ADA = adalimumab; CI = confidence interval; Comp = comparison; CP = certolizumab pegol; OR = odds ratio; TNF = tumor necrosis factor-alpha inhibitor

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

Figure 21 is a forest plot summarizing the Peto odds ratios of opportunistic infections among randomized controlled trials comparing a TNF-alpha inhibitor alone or in combination with placebo or another treatment. Four trials are included. The trials and their comparisons are: Colombel 2009, comparing adalimumab with placebo; Sandborn 2007, comparing adalimumab with placebo; Hanauer 2006, comparing adalimumab with placebo; and, Winter 2004, comparing certolizumab pegol with placebo. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratio is: 0.6 and a 95% confidence interval of 0.2 to 2.1 for Colombel 2009. The results are summarized in the previous section.

Figure 22 Summary of Peto odds ratios of other infections among randomized controlled trials comparing a TNF-alpha inhibitor alone or in combination with placebo or another treatment in patients with Crohn's disease

6-methylpred = 6-methylprednisolone; ADA = adalimumab; AZA = azathioprine; BUDE = budesonide; CI = confidence interval; Comp = comparison; CP = certolizumab pegol; GI = gastrointestinal; IFX = infliximab; IMM = immunomodulator; MTX = methotrexate; NR = not reported; OR = odds ratio; TEI = treatment-emergent infections; THIO = thiopurine; TNF = tumor necrosis factor-alpha inhibitor; URI = upper respiratory infection; UTI = urinary tract infection

^*^ There were 18 events in the combination infliximab and thiopurine arm and 16 events in the thiopurine arm.

Figure 22 is a forest plot that summarizes the Peto odds ratios of other infections among randomized controlled trial comparing a TNF-alpha inhibitor alone or in combination with placebo or another treatment. Sixteen trials reported on a variety of outcomes and comparisons. The results are summarized in the preceeding section.

Table 49 Summary of other infections reported in observational studies comparing a TNF-alpha inhibitor alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | TNF-Alpha Inhibitor | Comparison | # of Other Infections in TNF Group | # of Patients in TNF Group | # of Other Infections in Comp Group | # of Patients in Comp Group
Seiderer, 2004^173^ | NR | Infliximab + thiopurine | Infliximab + no thiopurine | 4 | 82 | 0 | 18
Seiderer, 2004^173^ | NR | Infliximab + corticosteroids | Infliximab + no corticosteroids | 0 | 42 | 3 | 58

Comp = comparison; NR = not reported; TNF = tumor necrosis factor-alpha inhibitor

##### Adalimumab Versus Placebo

Four RCT's appearing in five publications included 1,457 Crohn's disease patients and compared infections with adalimumab or placebo.37,38,82,83,95

###### Serious Infections

Four RCTs including 1,457 patients reported on serious infection. Serious infections were rare in adalimumab patients (0 to 4 percent) and placebo patients (0 to 5 percent).37,38,82,83

One of these trials allowed patients to switch medications after 12 weeks and reported on infections separately for patients who maintained randomized therapy and unblinded patients. A maintenance trial of those who achieved remission in a previous trial37 reported no infections in 37 adalimumab patients and 18 placebo patients who stayed on their randomized treatment for the duration of the 52-week period.83 Nine of 221 patients (4 percent) who elected to switch to adalimumab from placebo, increase the adalimumab dose, or discontinue at week 4, experienced a serious infection. A 52-week maintenance trial reported 3 percent of adalimumab and placebo patients experienced serious infections during the study period.82 Another publication of the same trial reported serious infections in 4 percent of adalimumab patients and 5 percent of placebo patients.95 The corresponding Peto OR was 0.8 (95% CI, 0.3 to 1.9). During the adalimumab induction period prior to randomization, serious infections occurred in 1 percent of 854 patients.82

###### Opportunistic Infections

Three RCTs including 1,402 patients reported on opportunistic infections.37,38,82 The two induction trials reported that no opportunistic infections occurred.37,38 A 52-week maintenance trial reported six (1 percent) opportunistic infections in the adalimumab patients compared with five (2 percent) opportunistic infections in the placebo group.82 The corresponding Peto OR was 0.6 (95% CI, 0.2 to 2.1).

###### Any Infection

Three RCTs including 679 patients reported on any infections.37,38,83 Infections were common in adalimumab patients (16 to 57 percent) and placebo patients (16 to 83 percent).

##### Other Combinations With Adalimumab

A prospective study of 112 patients who used adalimumab combined with aminosalicylates, corticosteroids, or immunomodulators reported one serious infection in a patient who used concomitant immunomodulators.161

##### Certolizumab Pegol Versus Placebo

Five RCTs including 1,910 Crohn's disease patients compared certolizumab pegol with placebo and reported on infections.39-42,84

###### Serious Infections

Four RCTs including 1,472 patients reported on serious infections.39-41,84 Serious infections were rare (1 to 3 percent of certolizumab pegol patients and 0 to 1 percent of placebo patients). Two trials, that excluded patients with abscesses related to Crohn's disease, reported gastrointestinal and perianal abscesses as serious infections.40,41

###### Opportunistic Infections

Two RCTs including 384 patients reported on opportunistic infections.40,41 One 12-week induction trial did not report any opportunistic infections.41 Another reported “no increase” in opportunistic infections but did not specify the infections considered.40

###### Any Infection

Five RCTs including 1,910 patients reported on any infections.39-42,84 Infections were common in certolizumab pegol patients (3 to 31 percent) and placebo patients (2 to 23 percent).40-42

An induction trial, followed by maintenance trial, reported on specific infections. Both trials reported on nasopharyngitis. The induction trial reported 13 percent of certolizumab pegol patients and 8 percent of placebo patients had nasopharyngitis (Peto OR, 1.7; 95% CI, 1.0 to 2.8).39 The maintenance trial may have randomized some of these patients; it reported that 12 of 216 certolizumab pegol patients (6 percent) and eight of 212 placebo patients (4 percent) had nasopharyngitis (Peto OR, 1.5; 95% CI, 0.6 to 3.7).84

##### Infliximab Versus Placebo

Five RCTs including 1,130 Crohn's disease patients compared infliximab with placebo and reported on infections.43,44,85-87

###### Serious Infections

Three RCTS including 963 patients reported on serious infections.43,86,87 Serious infections were uncommon in the maintenance trials (3 to 4 percent of infliximab and 4 to 6 percent of placebo patients).86,87 A 12-week trial of a single infusion reported one case of salmonella colitis requiring hospitalization among 83 infliximab patients and one case of abdominal abscess requiring hospitalization among 25 placebo patients.43

###### Opportunistic Infections

No study reported on opportunistic infections.

###### Any Infection

Four RCTs including 1,022 patients reported on any infections.44,85-87 Infections requiring antimicrobial treatment (including serious in infections) were common in the maintenance trials (30 to 34 percent of infliximab patients and 27 to 37 percent of placebo patients).86,87

The other trials reported specific infections in at least 10 percent of patients. An 18-week induction trial including a single infusion reported adverse events occurring in at least 10 percent of the population (63 infliximab patients and 31 placebo patients with fistulizing disease).44 Infectious adverse events included gastrointestinal abscess (seven infliximab patients versus one placebo patient; Peto OR, 2.7; 95% CI, 0.6 to 12.6), and upper respiratory infection (five infliximab patients vs. two placebo patients; Peto OR, 1.6; 95% CI, 0.5 to 8.2).44 A 36-week retreatment trial subsequent to another trial43 reported adverse events occurring in at least 10 percent of any group including 37 infliximab patients and 36 placebo patients.85 Infectious adverse events included bronchitis (six infliximab patients vs. three placebo patients; Peto OR, 2.1; 95% CI, 0.5 to 8.2); pharyngitis (seven infliximab patients vs. one placebo patient; Peto OR, 5.1; 95% CI, 1.2 to 22.0); and upper respiratory infection, which may or may not have included bronchitis and pharyngitis (nine infliximab patients vs. six placebo patients; Peto OR, 1.6; 95% CI, 0.5 to 8.2).85

##### Infliximab Versus Azathioprine

One RCT including 324 Crohn's disease patients compared infliximab with azathioprine and reported on infections.45

###### Serious Infections

The same RCT reported eight serious infections in 163 infliximab patients (5 percent) compared with nine serious infections in 161 azathioprine patients (6 percent).45 The corresponding Peto OR was 0.9 (95% CI, 0.3 to 2.3).

###### Opportunistic Infections

This trial did not report on opportunistic infections.45

###### Any Infection

This RCT reported a serious or non-serious infection in 46 percent of infliximab patients and 45 percent of azathioprine patients. The corresponding Peto OR was 1.0 (95% CI, 0.7 to 1.6).45

##### Combination of Infliximab and Corticosteroids Versus Infliximab

One retrospective study of 71 patients reported no serious infections.163 The study did not report on opportunistic infections or other infections.

##### Combination of Infliximab and Immunomodulators Versus Infliximab

Three RCTs including 607 Crohn's disease patients compared a combination of infliximab and immunomodulators with infliximab and reported on infections.45,47,89 Two observational studies including 128 Crohn's disease patients compared a combination of infliximab and immunomodulators with infliximab and reported on infections.163,174

###### Serious Infections

Two RCTs including 527 patients reported on serious infections.45,47 The trials reported serious infections in less than 5 percent of patients in any study arm.

Two observational studies including 128 Crohn's disease patients reported on serious infections. A study of the early experience with infliximab at several centers reported one case of pneumocystis carinii pneumonia among 42 patients on infliximab and immunomodulator (thiopurines, methotrexate, or mycophenolate mofetil), and one episode of sepsis among 15 users of infliximab without an immunomodulator.174 The other study reported no serious infections in either the infliximab combined with immunomodulators group, or the infliximab group that never used immunomodulators.163

###### Opportunistic Infections

None of the RCTs reported on opportunistic infections.

###### Any Infection

All three RCTs including 607 patients reported and included serious and non-serious infections.45,47,89 Infections were common in patients who used infliximab combined with an immunomodulator (30 to 55 percent) and infliximab alone (25 to 46 percent).

##### Other Combinations With Infliximab

Five retrospective studies including 1,267 Crohn's disease patients met the inclusion criteria but the studies might have misclassified the concomitant medications (as described in the mortality section). Four studies evaluated the safety profile of infliximab use at their centers,137,145,164,175 and one study focused specifically on the role of concomitant immunomodulators on outcomes.147

###### Serious Infections

Four studies including 1,152 patients reported on serious infections in five manuscripts.137,138 145,164,175 The four retrospective studies reported serious infections in patients who received (at baseline) either a triple combination of infliximab, immunomodulators, and corticosteroids; a combination of infliximab and immunomodulators; a combination of infliximab and corticosteroids; or infliximab alone. The studies reported serious infections in 0 to 7 percent of patients receiving the combination of infliximab, immunomodulator, and corticosteroid; 3 to 18 percent of patients receiving infliximab and an immunomodulator; 0 to 9 percent of patients receiving infliximab and corticosteroids; and 0 to 16 percent of patients receiving only infliximab. A previous report on 500 patients from one center reported on outcomes for the first 100 patients using infliximab.138 The report included six “significant” infections in five of the six patients using concomitant immunomodulators (with or without corticosteroids) and two of the six patients using concomitant corticosteroids (with or without immunomodulators).138 The study of 157 patients also reported on 30 patients who received adalimumab after infliximab.145 Of the 30 adalimumab patients, two experienced sepsis-related complications.

###### Opportunistic Infections

Two studies including 657 patients reported on opportunistic infections.137,145 One study (157 patients) reported no opportunistic infections.145 The other study (500 patients) considered three non-serious varicella-zoster infections “probably” opportunistic.137 The study treated two of these patients with a combination of infliximab, azathioprine, and corticosteroids and treated the other with a combination of infliximab and azathioprine.

###### Any Infection

Four studies including 970 patients reported on any infection in five manuscripts.137,138,145,147,175 The two retrospective studies included 157 and 500 Crohn's disease patients and reported infections (respectively) in 16 and 3 percent of patients receiving the combination of infliximab, immunomodulator, and corticosteroid; 33 and 9 percent of patients receiving infliximab and an immunomodulator; 6 and 13 percent of patients receiving infliximab and corticosteroids; and 26 and 14 percent of patients receiving only infliximab.137,145 The reported infections included serious infections. A previous study on 500 patients from the center reported on the infliximab outcomes among the first 100 patients and did not report other infections.138 The study of 157 patients also reported on 30 patients who received adalimumab after infliximab.145 Of the 30 adalimumab patients, seven patients (23 percent) had an infection.

A retrospective study with a mean followup of 29 months reported one pneumonia in 127 patients receiving infliximab and an immunomodulator, compared with no infections in 71 patients receiving infliximab without concomitant immunomodulators (this came from a database that included most of the patients treated with infliximab at the center).175 A followup study, with a median followup of 9 years, reported two “atypical” infections in 53 patients receiving infliximab with no concomitant thiopurine use, compared with no infections among those with concomitant thiopurine use.147 The infections reported were necrotizing pneumonia and methicillin-resistant Staphylococcus aureus skin abscess.

##### Combination of Infliximab and Immunomodulators Versus Immunomodulators

Two RCTs including 340 Crohn's disease patients compared the combination of infliximab and immunomodulators with immunomodulators alone and reported on infections.45 46

###### Serious Infections

The two studies reported serious infections in less than 5 percent of patients in any study arm.45 46

###### Opportunistic Infections

Neither of the RCTs reported on opportunistic infections.

###### Any Infection

Infections were common in all study arms (32 to 42 percent of infliximab combined with thiopurines patients and 29 to 45 percent of thiopurines patients).45,46

##### Combination of Infliximab and Immunomodulators Versus Corticosteroids

A 104-week open-label trial including 129 Crohn's disease patients compared a combination of infliximab and immunomodulators with corticosteroids and reported on infections.48

###### Serious Infections

Six percent of the combination of infliximab and azathioprine or methotrexate patients had a serious infection, compared with 13 percent of patients on prednisone or budesonide.48

###### Opportunistic Infections

This RCT did not report on opportunistic infections.

###### Any Infection

The trial reported 77 infectious events in 65 patients on infliximab and azathioprine or methotrexate, compared with 80 infectious events in 64 patients on prednisone or budesonide.48

##### TNF-Alpha Inhibitor Versus No TNF-Alpha Inhibitor

One prospective study and two retrospective observational studies including 15,045 Crohn's disease patients reported on infections comparing patients who had used a TNF-alpha inhibitor with those who had not used a TNF-alpha inhibitor or never used a biologic.131,150,168

###### Serious Infections

Two observational studies including 6,464 patients reported on serious infections.131,150 An observational study (with 2 mean years of followup) reported serious infections (undefined) in 2 percent of 3,179 infliximab users, compared with 1 percent of non-users during the study period. The study reported an OR of 1.0 (95% CI, 0.6 to 1.5) when comparing infliximab with no infliximab (excluding infliximab used in the 6-month period during which the infection occurred); this is after adjusting for age, sex, race, disease location, severity of Crohn's disease, duration of followup and possibly other medication use. The relative rate comparing number of infections by person-years of exposure (unadjusted for potential confounders) was 2.2 (95% CI, 1.4 to 3.2). A 104-week prospective study reported 10 serious infections requiring hospitalization among patients who used adalimumab or infliximab, and no serious infections among those who never used a biologic.150

###### Opportunistic Infections

A claims-based study that included 8,581 Crohn's disease patients reported on opportunistic infections, candidiasis, and tuberculosis together.168 The study reported 11 of these infections in 292 infliximab person-years, compared with 305 in 15,673 person-years with no associated Crohn's disease pharmacy claims. The study reported a HR of 2.0 (95% CI, 1.1 to 3.7) comparing infliximab (with or without corticosteroids or immunomodulators) with no therapy, adjusted for age, gender, geographic region, health plan, and comorbidity. They also reported an adjusted HR of 2.1 (95% CI, 1.1 to 3.8), comparing infliximab alone (without corticosteroids or immunomodulators) with no therapy.

###### Any Infection

The study also reported four additional infections that the authors did not specifically identify as serious.168 For herpes simplex, herpes zoster, and encephalopathy, encephalitis, or meningitis; the unadjusted rate ratios and adjusted hazard ratios ranged from 0.9 to 1.7 without statistical significance. There was an increased risk of sepsis among infliximab users, compared with those without therapy. There were 48 sepsis events reported in 292 person-years of infliximab use, compared with 1,833 events among 15,673 person-years of no therapy (adjusted HR comparing infliximab [with or without corticosteroids and immunomodulators] with no therapy, 1.5; 95% CI, 1.1 to 2.0; HR for infliximab alone vs. no therapy, 1.5; 95% CI, 1.1 to 2.0).

##### Combination of TNF-Alpha Inhibitors, Immunomodulators, and Corticosteroids Versus No Therapy

The same claims-based study compared a triple combination of TNF-alpha inhibitors, immunomodulators, and corticosteroids with no therapy; the study reported on opportunistic and other specific infections.168

###### Opportunistic Infections

The study reported two opportunistic infections among 31 person-years of exposure to combination therapy with TNF-alpha inhibitors, immunomodulators, and corticosteroids, compared with 305 opportunistic infections among 15,673 person-years of no therapy.168 The study reported an adjusted HR of 3.6 (95% CI, 0.9 to 14.6), comparing triple combination therapy with no therapy.

###### Any Infection

The study also reported four additional infections that the authors did not specifically identify as serious. The study compared 31 person-years of triple combination therapy of infliximab, immunomodulators, and corticosteroids with 15,673 person-years of no therapy over an average of 2 years per person. The study did not identify claims associated with herpes simplex in any of the triple therapy patients, compared with 134 in the no therapy patients.168 The study reported one herpes zoster infection in the triple therapy group, compared with 123 infections in the no therapy group (unadjusted rate ratio, 4.1; 95% CI, 0.1 to 23.3). The study reported nine claims for sepsis in the triple therapy group, compared with 1,833 claims in the no therapy group (study reported adjusted HR, 2.4; 95% CI, 1.2 to 4.7). The study reported four encephalopathy, encephalitis, or meningitis infections in the triple therapy group, compared with 499 infections in the no therapy group (unadjusted rate ratio, 4.1; 95% CI, 1.1 to 1.4).

##### Combination of TNF-Alpha Inhibitors and Immunomodulators Versus No Therapy

The same claims-based study compared a combination of TNF-alpha inhibitors and immunomodulators with no therapy and reported on opportunistic and specific other infections.168

###### Opportunistic Infections

The study reported 15 opportunistic infections among 162 person-years of exposure to combination therapy with TNF-alpha inhibitors and immunomodulators (with or without corticosteroids), compared with 305 opportunistic infections among 15,673 person-years of no therapy.168 The corresponding unadjusted rate ratio was 4.8 (95% CI, 2.6 to 8.0).

###### Any Infection

The study reported three herpes simplex infections among the patients receiving a TNF-alpha inhibitor and immunomodulator and 134 infections among patients receiving no therapy. The corresponding rate ratio was 2.2 (95% CI, 0.4 to 6.5). The study reported four herpes zoster infections among patients receiving a TNF-alpha inhibitor and immunomodulator, compared with 123 infections among patients receiving no therapy (unadjusted rate ratio, 3.1; 95% CI, 0.8 to 8.3). The study reported sepsis claims in 23 patients receiving the combination therapy and 1,833 patients receiving no therapy (adjusted HR, 1.9; 95% CI, 0.8 to 1.8). The study reported encephalopathy, encephalitis, or meningitis claims in 12 patients receiving the combination therapy and 499 patients receiving no therapy (unadjusted rate ratio, 2.3; 95% CI, 1.2 to 4.1).168

##### Combination of TNF-Alpha Inhibitor and Corticosteroids Versus No Therapy

The same claims-based study compared no therapy with a combination of TNF-alpha inhibitors and corticosteroids and reported on opportunistic and specific other infections.168

###### Opportunistic Infections

The study reported two opportunistic infections among 142 person-years of exposure to combination therapy with TNF-alpha inhibitors and corticosteroids (with or without immunomodulators), compared with 305 opportunistic infections among 15,673 person-years of no therapy.168 The corresponding unadjusted rate ratio was 0.7 (95% CI, 0.1 to 2.6).

###### Any Infection

The study reported one herpes simplex infection in the group receiving a TNF-alpha inhibitor and corticosteroids, compared with 134 infections in the no therapy group (unadjusted rate ratio, 0.8; 95% CI, 0 to 4.7). The study reported herpes zoster claims in three patients receiving the combination therapy and 123 patients receiving no therapy (unadjusted rate ratio, 2.7; 95% CI, 0.5 to 8.1). The study reported sepsis claims in 27 patients receiving the combination therapy and 1,833 patients receiving no therapy. The study reported an adjusted HR for sepsis of 2.8 (95% CI, 1.2 to 6.5) that differed in magnitude from the unadjusted rate ratio of 1.6 (95% CI, 1.1 to 2.4). The study reported encephalopathy, encephalitis, or meningitis in six patients receiving the combination therapy and 499 patients receiving no therapy (unadjusted rate ratio 1.3; 95% CI, 0.5 to 2.9).

##### Other Combinations With TNF-Alpha Inhibitors

A retrospective study reported no serious infections requiring hospitalization in the 44 people who used TNF-alpha inhibitors without concomitant corticosteroids and immunomodulators. Eight percent of patients on TNF-alpha inhibitors combined with corticosteroids, 2 percent of patients on TNF-alpha inhibitors combined with immunomodulators, and 2 percent of patients on TNF-alpha inhibitors combined with corticosteroids and immunomodulators had serious infections.165

#### Immunomodulators

Table 50 summarizes the risk of serious infections in observational studies evaluating immunomodulators in patients with Crohn's disease. Figure 23 and Table 51 summarize the risk of any infection in RCTs and observational studies evaluating immunomodulators in patients with Crohn's disease. We also provided additional details regarding related studies.

Table 50 Summary of the risk of serious infections in observational studies comparing an immunomodulator alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | Design | IMM | Comparison | # of Serious Infections in IMM Group | # of Patients in IMM Group | # of Serious Infections in Comparison Group | # of Patients in Comparison Group | Unadjusted OR (95% CI) | Adjusted OR (95% CI)
Lichtenstein, 2006^131^ | 99 | Prospective cohort | IMM | No IMM | 58 | 3478 | 48 | 2775 | 1.0 (0.7 to 1.4) | 0.8 (0.5 to 1.2)

CI = confidence interval; IMM = immunomodulator; OR = odds ratio

Figure 23 Summary of Peto odds ratios of other infections among randomized controlled trials comparing an immunomodulator alone or in combination with placebo or another treatment in patients with Crohn's disease

AZA = azathioprine; BUDE = budesonide; CI = confidence interval; Comp = comparison; IMM = immunomodulator; IV = intravenous; LRI = lower respiratory infection; MTX = methotrexate; NR = not reported; OR = odds ratio; PRED = prednisone; PREDL = prednisolone; SUL = sulfasalazine; URI = upper respiratory infection

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

Figure 23 is a forest plot summarizing the Peto odds ratios of other infections among randomized controlled trials comparing an immunomodulator alone or in combination with placebo or another treatment. 10 outcomes are defined with various trials and treatment comparisons. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The outcome of viral lower respiratory infection has one comparison from the Sandborn 1999 trial comparing a combination of intravenous and oral azathioprine with oral azathioprine. The odds ratio is 0.9 and a 95% confidence interval of 0.3 to 2.9. The upper respiratory infection outcome has one comparison which is Mantzaris 2009 comparing azathioprine with budesonide. The odds ratio is 0.3 and a 95% confidence interval of 0.7 to 2.8. The any infections outcome has 6 comparisons. Five are Summers 1979, including comparisons of azathioprine with prednisone, two comparisons of azathioprine with placebo, and two comparisons of azathioprine with sulfasalazine, as well as Feagan 2000 comparing methotrexate with placebo. The odds ratios for any infections ranged from 0.3 to 2.9. All confidence intervals crossed 1 except Summers 1979 comparing azathioprine with prednisone, and that confidence interval was 0.1 to 0.6. The total abscess outcome has 6 comparisons, all from Summer 1979, which are two comparing azathioprine with prednisone, two comparing azathioprine with placebo, and two comparing azathioprine with sulfasalazine. Three were excluded, and the other three odds ratios ranged from 0.7 to 3, with confidence intervals all crossing 1. The perianal abscess outcome has four comparisons. Three comparisons are from Summers 1979, the first comparing azathioprine with placebo, then azathioprine with sulfasalazine, and the third comparing a combination of azathioprine and prednisone with a combination of placebo and prednisone. The odds ratios of the first two comparisons are 0.5 and 0.6, respectively, and both have 95% confidence intervals that cross 1. The Reinisch 2008 trial compared a combination of azathioprine and prednisone with a combination of placebo and prednisone and was excluded from the odds ratio calculation. The nasopharyngitis has one comparison, Reinisch 2008 comparing a combination of azathioprine and prednisone with a combination of placebo and prednisone. The odds ratio was 1.3 and a 95% confidence interval of 0.3 to 5.1. The influenza outcome has one comparison, Feagan 1996 comparing a combination of methotrexate and prednisone with a combination of placebo and prednisone. The odds ratio is 0.9 and a 95% confidence interval of 0.3 to 2.6. The outcome of pneumonia appears in Sandborn 1999 comparing a combination of intravenous and oral azathioprine with oral azathioprine. This was excluded from odds ratio calculation. The intra-abdominal abscess outcome has one comparison which is Ewe 1993 comparing a combination of azathioprine and prednisolone with a combination of placebo and prednisolone. This was excluded from odds ratio calculation. Finally, the outcome titled other abscess has six comparisons, all from Summers 1979, which are two comparisons of azathioprine with prednisone, two comparisons of azathioprine with placebo, and two comparisons of azathioprine with sulfasalazine. All comparisons were excluded from odds ratio calculation. The results are summarized in the previous section.

Table 51 Summary of the risk of other infections in observational studies comparing an immunomodulator alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | Immunomodulator | Comparison | # of Other Infections in IMM Group | # of Patients in IMM Group | # of Other Infections in Comparison Group | # of Patients in Comparison Group
Maher, 2009^176^ | NR | Azathioprine | Never azathioprine | NR^*^ | 12 | NR^*^ | 60
Shah, 2008^156^ | NR | Azathioprine + mesalamine | Azathioprine + never mesalamine | 2 | 104 | 2 | 95

IMM = immunomodulator; NR = not reported

* There were two events among 12 patients in the azathioprine group and seven events among 60 patients in the never azathioprine group.

##### Azathioprine Versus Corticosteroids

Two RCTs including 454 Crohn's disease patients compared azathioprine with corticosteroids and reported on infections.102,177

###### Serious Infections

One RCT including 259 patients reported on serious infections.177 The study termed serious infections a “disaster” if the patient required hospitalization or suffered a disability for at least 3 months, or “serious” if the patient had to withdraw from the study or needed treatment. During induction, two of 59 patients on azathioprine (3 percent) and two of 85 patients on prednisone (2 percent) experienced a serious infection.177 Seven percent of both groups had a serious infection during the maintenance period.

###### Opportunistic Infections

Neither of the RCTs reported on opportunistic infections.

###### Any Infection

Two RCTs including 454 patients reported on any infection. The study reported non-serious infections during induction in 8 percent of patients on azathioprine and 32 percent of patients on prednisone.177 During maintenance, the studies reported infections in 31 percent of patients on azathioprine and 13 percent of patients on prednisone. A 1.5-year maintenance trial comparing azathioprine with budesonide reported infections in 66 percent of azathioprine and 36 percent of budesonide patients.102 The majority of infections were upper respiratory or herpes infections.

##### Azathioprine Versus Sulfasalazine

One RCT including 245 Crohn's disease patients compared azathioprine with sulfasalazine and reported on infections.177

###### Serious Infections

During the induction period, 3 percent of patients on azathioprine and 0 percent of patients on sulfasalazine had serious infections.177 During maintenance therapy, 7 percent of patients on azathioprine and no patients on sulfasalazine had a serious infection.

###### Opportunistic Infections

This RCT did not report on opportunistic infections.

###### Any Infection

The study reported non-serious infections during induction in 8 percent of patients on azathioprine and 14 percent of patients on sulfasalazine.177 During maintenance therapy, the study reported infections in 31 percent of patients on azathioprine and 54 percent of patients on sulfasalazine.

##### Combination of Immunomodulators and Corticosteroids Versus Corticosteroids

Three RCTs including 263 Crohn's disease patients compared a combination of immunomodulators and corticosteroids with corticosteroids alone and reported on infections.51,54,63

###### Any Infections

Three RCTs including 263 patients reported on any infections.51,54,63 A 4-month induction trial comparing a combination of azathioprine and prednisolone with prednisolone alone reported no infections in the 42 patients.54 A 7-month induction trial reported adverse events that occurred in at least 10 percent of the study population.51 The trial reported nasopharyngitis in seven of 52 patients (13 percent) receiving azathioprine and prednisone and three of 28 patients (11 percent) receiving prednisone. A 16-week induction trial reported influenza in 11 percent of patients on methotrexate and prednisone compared with 13 percent of patients on prednisone.63 The trial reported pneumonia in one patient taking methotrexate and prednisone and no patients taking prednisone.63 None of the RCTs reported on serious or opportunistic infections.

##### Immunomodulators Versus Placebo

Three RCTs including 463 Crohn's disease patients compared azathioprine with placebo and reported on infections.56 59 105 One study included an induction and maintenance phase comparing oral azathioprine with placebo.56 Some patients participated in induction and maintenance, whereas some patients in remission at enrollment only participated in the maintenance phase. We considered serious infections those where patients were hospitalized, suffered a disability of at least 3 months, had to withdraw from the study or needed treatment. Another study compared a single infusion of azathioprine or placebo followed by oral azathioprine in both groups.59 A 40-week methotrexate trial included patients who were in steroid-free remission from a previous trial63 or who responded to methotrexate within 16 to 24 weeks.105

###### Serious Infections

Two studies including 367 patients reported on serious infections.105,177 One study reported serious infections in 3 percent of the azathioprine and 4 percent of placebo patients during induction, and 7 percent of azathioprine and 2 percent of placebo patients during maintenance.177 The second study, a methotrexate trial, reported one infection-related severe adverse event in a placebo patient.105

###### Opportunistic Infections

No study reported on opportunistic infections for this comparison.

###### Any Infection

Three studies including 463 patients reported on any infection.59 105 177 One study reported infections in 8 percent of the azathioprine patients and 13 percent of the placebo patients during the 17-week induction phase, compared with 31 percent of azathioprine patients and 19 percent of placebo patients in the 104-week maintenance phase.177 A 16-week study that compared a single infusion of azathioprine with placebo to induce remission combined with oral azathioprine in both groups reported no pneumonia cases in the 51 azathioprine patients, compared with two pneumonia cases in the 45 placebo patients.59 The trial reported viral lower respiratory infections in six azathioprine patients (12 percent) compared with two placebo patients (4 percent). A methotrexate trial reported two flu-like illnesses in both the methotrexate group (5 percent) and the placebo group (5 percent).105

##### Immunomodulators Versus No Immunomodulators

One prospective study including 6,290 Crohn's disease patients compared immunomodulators with no immunomodulators and reported on infections.131

###### Serious Infections

Two percent of patients using immunomodulators and 2 percent of patients not using immunomodulators had a serious infection. The study reported an OR of 0.8 (95% CI, 0.5 to 1.2), comparing immunomodulators with no immunomodulators, adjusted for age, sex, race, disease location, severity of Crohn's disease, duration of followup, and possibly other medications. The authors did not include in the analysis the medication exposure during the 6-month time period when the infection occurred. This prospective study did not report on opportunistic or any other infections.

##### Immunomodulators Versus No Therapy

A claims-based study that included 8,581 Crohn's disease patients reported opportunistic infections, candidiasis, and tuberculosis together.168 The study reported 17 of these infections in 911 person-years associated with claims for immunomodulator use, compared with 305 in 15,673 person-years with no claims for medical treatment of Crohn's disease. The study reported an HR of 1.1 (95% CI, 0.6 to 1.8), comparing immunomodulators (with or without infliximab or corticosteroids) with no therapy, adjusted for age, gender, geographic region, health plan, and comorbidity. The study also reported an adjusted HR of 1.1, comparing immunomodulators alone (without infliximab or corticosteroids) with no therapy (95% CI, 0.6 to 1.8).

###### Any Infection

The study also reported four additional infections that were not specifically identified by the authors as serious. There were 911 immunomodulator person-years compared with 15,673 no therapy person-years.168 The comparison between immunomodulators and no therapy did not produce any statistically significant associations for herpes simplex, herpes zoster, sepsis, encephalopathy, encephalitis, or meningitis. The HRs ranged from 0.6 to 1.0.

##### Combination of Immunomodulators With Corticosteroids Versus No Therapy

The same claims-based study reported opportunistic infections, candidiasis, and tuberculosis together.168 The study reported two of these infections in 19 person-years of followup on a combination of immunomodulator and corticosteroid, compared with 305 infections in 15,673 person-years of followup without any claims for medical treatment of Crohn's disease. The study reported a HR of 4.8 (95% CI, 2.7 to 8.3), comparing a combination of immunomodulators and corticosteroids (with or without infliximab) with no therapy, adjusted for age, gender, geographic region, health plan, and comorbidity. The corresponding unadjusted rate ratio was 5.4 (95% CI, 0.7 to 19.7).

###### Any Infection

The study also reported four additional infections that were not specifically identified by the authors as serious. The study had 19 person-years of followup on patients receiving an immunomodulator and corticosteroid, compared with 15,673 person-years of followup on patients receiving no therapy.168 The reported infections included herpes simplex (zero in the combination group vs. 134 in the no therapy group), herpes zoster (zero in the combination group vs. 123 in the no therapy group), sepsis (six in the combination group vs. 1,833 in the no therapy group; the adjusted HR for sepsis, comparing a combination of immunomodulators and corticosteroids [with or without infliximab] with no therapy was 1.2; 95% CI, 0.8 to 1.8; the unadjusted rate ratio was 2.7; 95% CI, 1.0 to 5.9), and encephalopathy, encephalitis, or meningitis (three in the combination group vs. 499 in the no therapy group; the unadjusted rate ratio for encephalopathy, encephalitis, or meningitis was 5.0; 95% CI, 1.0 to 14.6).

#### Corticosteroids

Table 52 summarizes the risk of serious infections in studies evaluating corticosteroids in patients with Crohn's disease. Figure 24 and Table 53 summarize the risk of any infection in RCTs and observational studies evaluating corticosteroids in patients with Crohn's disease. We also provided additional details regarding related studies. We did not identify any RCT or observational study that evaluated corticosteroids in patients with Crohn's disease and reported on opportunistic infections.

Table 52 Summary of the risk of serious infections in observational studies comparing a corticosteroid alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | Design | Corticosteroid | Comparison | # of Serious Infections in Steroid Group | # of Patients in Steroid Group | # of Serious Infections in Comparison Group | # of Patients in Comparison Group | Unadjusted OR (95% CI) | Adjusted OR (95% CI)
Lichtenstein, 2006^131^ | 99 | Prospective cohort | Prednisone | No prednisone | 61 | 2142 | 45 | 4111 | 2.9 (1.9 to 4.3) | 2.2 (1.5 to 3.3)

CI = confidence interval; OR = odds ratio; Steroid = corticosteroid

Figure 24 Summary of Peto odds ratios of other infections among randomized controlled trials comparing a corticosteroid alone or in combination with placebo or another treatment in patients with Crohn's disease

BUDE = budesonide; CI = confidence interval; Comp = comparison; NR = not reported; OR = odds ratio; PRED = prednisone; steroid = corticosteroid; UTI = urinary tract infections

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ The number of patients with urinary tract infections was reported to be higher in the budesonide twice daily group.

Figure 24 is a forest plot summarizing the Peto odds ratios of other infections among randomized controlled trials comparing a corticosteroid alone or in combination with placebo or another treatment. Seven outcomes are defined with various trials and treatment comparisons. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The first outcome, infections and infestations, has one comparison which is budesonide versus mesalamine. The odds ratio 1.3, with a 95% confidence interval of 0.67 to 2.34. The next outcome, respiratory infection, has one comparison which is Tremaine 2002 comparing budesonide with placebo. The odds ratio is 0.43 and a 95% confidence interval of 0.12 to 1.57. The next outcome, any infections, has five comparisons. Four comparisons are from Summers 1979, one comparing prednisone with placebo, two comparing prednisone with placebo, two comparing prednisone to sulfasalazine. The fifth of any infections outcome is Singleton 1979 comparing a combination of sulfasalazine and prednisone with a combination of prednisone and placebo. The odds ratios for any infections ranged from 0.33 to 2.88. Only one had a 95% confidence interval that crossed 1, which was 0.28 to 1.56 for Summers 1979 comparing prednisone with placebo. The perianal abscess outcome has two comparisons, both Summers 1979, which are comparing prednisone with placebo and comparing prednisone with sulfasalazine. The odds ratio could only be calculated for the first of the two and it was 0.23 and a 95% confidence interval of 0.04 to 1.16. The total abscess outcome has four comparisons, which are all Summers 1979. The comparisons are two of prednisone compared with placebo and one of prednisone compared with sulfasalazine. The two comparisons of prednisone with placebo have calculated odds ratios and they are 0.57 and a 95% confidence interval of 0.10 to 3.40 and 0.37 and a 95% confidence interval of 0.08 to 1.68. The urinary tract infection outcome has one comparison, which is Campieri 1997 comparing a combination of budesonide and placebo with a combination of prednisolone with placebo. There is no odds ratio. The other abscess outcome has four comparisons, all from Summers 1979, which include two comparing prednisone with placebo and two comparing prednisone with sulfasalazine. None of the comparisons has odds ratios. The results are summarized in the previous section.

Table 53 Summary of the risk of other infections in observational studies comparing a corticosteroid alone or in combination with placebo or another treatment in patients with Crohn's disease

Author, Year | Followup (Weeks) | Design | Corticosteroid | Comparison | # of Other Infections in Steroid Group | # of Patients in Steroid Group | # of Other Infections in Comparison Group | # of Patients in Comparison Group | Unadjusted OR (95% CI)
Goldstein, 1967^142^ | NR | Retrospective cohort | Corticosteroid | Never corticosteroid | 95 | 430 | 17 | 124 | 1.7 (1.0 to 2.8)

CI = confidence interval; NR = not reported; OR = odds ratio; steroid = corticosteroid

##### Corticosteroids Versus Placebo

Two RCTs including 362 Crohn's disease patients compared corticosteroids with placebo and reported on infections.65,177 They did not report on opportunistic infections.

###### Serious Infections

One RCT including 302 patients reported on serious infections.177 The study reported serious infections during the induction period in 2 percent of patients on prednisone and 4 percent of patients on placebo.177 During the maintenance trial, 7 percent of patients on prednisone and 2 percent of patients on placebo had a serious infection.177

###### Any Infection

Two trials including 362 patients reported on any infection.65 177 The study reported non-serious infections during the induction period in 32 percent of patients on prednisone and 13 percent of patients on placebo.177 During the maintenance trial 13 percent of patients on prednisone and 19 percent of patients on placebo had a nonserious infection.177 A trial comparing budesonide with placebo reported common adverse events. The trial reported respiratory infections in 6 percent of patients on budesonide and 12 percent of patients on placebo (Peto OR, 0.4; 95% CI, 0.1 to 1.6).65 The trial reported flu-like disorder in 6 percent of budesonide patients and 6 percent of placebo patients.

##### Corticosteroids Versus No Corticosteroids

One prospective study including 6,253 Crohn's disease patients compared corticosteroids with no corticosteroids and reported on infections.131

###### Serious Infections

The trial reported serious infections in 3 percent of patients on prednisone taken at least 6 months prior to the infection and 1 percent of patients not taking prednisone.131 The study reported a demographics and medication adjusted OR of 2.2 (95% CI, 1.5 to 3.3). The study did not report on opportunistic or other infections.

##### Corticosteroids Versus No Therapy

A claims-based study that included 8,581 Crohn's disease patients reported opportunistic infections, candidiasis, and tuberculosis together.168 The study reported 25 of these infections in 379 person-years of followup for corticosteroid use, compared with 305 infections in 15,673 person-years of followup without therapy for Crohn's disease. The study reported a HR of 3.2 (95% CI, 2.1 to 4.8), comparing corticosteroids (with or without immunomodulators and infliximab) with no therapy, adjusted for age, gender, geographic region, health plan, and comorbidity. The HR for corticosteroids only, compared with no therapy, was also 3.2 (95% CI, 2.1 to 4.8).

###### Any Infection

The study also reported on four additional infections that the authors did not specifically identify as serious. The study reported 379 person-years of followup for corticosteroid users and 15,673 person-years of followup for the no therapy group.168 The reported infections included herpes simplex (three in the corticosteroid group vs. 134 in the no therapy group; the HR for corticosteroids only was 0.9; 95% CI, 0.2 to 2.8); herpes zoster (nine in the corticosteroid group vs. 123 in the no therapy group; the HR for corticosteroids only was 3.1; 95% CI, 1.6 to 6.2); sepsis (72 in the corticosteroid group vs. 1,833 in the no therapy group; the adjusted HR comparing corticosteroids [with or without immunomodulators and infliximab] with no therapy was 1.6; 95% CI, 1.3 to 2.0; the HR for corticosteroids only was 1.6; 95% CI, 1.3 to 2.0); and encephalopathy, encephalitis, or meningitis (34 in the corticosteroid group vs. 499 in the no therapy group; the unadjusted rate ratio for corticosteroids only was 2.6; 95% CI, 1.8 to 3.7).

##### Corticosteroids Versus Aminosalicylates

Three RCTs including 525 Crohn's disease patients compared corticosteroids with aminosalicylates and reported on infections.74,113,177

###### Serious Infections

One trial including 159 patients reported on serious infections. The study reported serious infections during the induction period in 2 percent of patients on prednisone and 0 percent of patients on sulfasalazine.177 During the maintenance trial, 7 percent of patients on prednisone and 0 percent of patients on sulfasalazine had a serious infection.177

###### Any Infection

Three trials including 525 patients reported on any infection.74,113,177 One study reported non-serious infections during the induction period in 32 percent of patients on prednisone and 14 percent of patients on sulfasalazine.177 During the maintenance trial, 13 percent of patients on prednisone and 29 percent of patients on sulfasalazine had a non-serious infection.177 A RCT comparing 29 patients on budesonide with 28 patients on mesalamine reported 19 infections in budesonide patients and 16 infections in mesalamine patients.113 The infections reported included upper respiratory tract infections and urinary tract infections. A larger trial of budesonide compared with aminosalicylates reported 16 percent of budesonide and 13 percent of aminosalicylates patients had an infection.74

##### Combination of Prednisone and Sulfasalazine Versus Sulfasalazine

One RCT including 89 Crohn's disease patients reported on infections.75

###### Any Infection

The 8-week induction trial reported 44 percent of patients on prednisone and 72 percent of patients on sulfasalazine had an infection75). It did not report serious infections and opportunistic infections.

#### Aminosalicylates

Figure 25 summarizes the risk of infection in the one RCT evaluating infections associated with use of aminosalicylates in patients with Crohn's disease.

Figure 25 Summary of Peto odds ratios of other infections in a randomized controlled trial comparing an aminosalicylate alone or in combination with placebo or another treatment in patients with Crohn's disease

ASA = aminosalicylate; CI = confidence interval; Comp = comparison; Main = main intervention; OR = odds ratio; SUL = sulfasalazine

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

Figure 25 is a forest plot summarizing the Peto odds ratios of other infections among randomized controlled trials comparing an aminosalicylate alone or in combination with placebo or another treatment. 4 outcomes are defined with various trials and treatment comparisons. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. All of the comparisons come from Summers 1979 comparing sulfasalazine with placebo. The first outcome, any infections, has two comparisons and one was excluded from odds ratio calculation while the other had an odds ratio of 1.05 and a 95% confidence interval of 0.41 to 2.67. The next outcome, perianal abscess, has an odds ratio of 0.62 and a 95% confidence interval of 0.15 to 2.55. The next outcome, total abscess, has two comparisons. The odds ratio for the first is 0.62 and a 95% confidence interval of 0.15 to 2.55 and the other is excluded. The other abscess outcome has two comparisons, and both are excluded from odds ratio calculation. The results are summarized in the previous section.

##### Sulfasalazine Versus Placebo

One RCT included 159 Crohn's disease patients and reported on infections.177

###### Serious Infections

The trial reported serious infections in zero of 74 patients (0 percent) on sulfasalazine and three of 55 patients (5 percent) on placebo during the induction period.177 During maintenance therapy, the trial reported serious infections in zero of 61 patients (0 percent) on sulfasalazine and two of 101 patients (2 percent) on placebo.

###### Any Infection

The trial reported non-serious infections during the induction period in 14 percent of patients on sulfasalazine and 13 percent of patients on placebo.177 During the maintenance trial, 29 percent of patients on sulfasalazine and 19 percent of patients on placebo had an infection. This RCT did not report on opportunistic infections.

#### Studies Evaluating Patients With Crohn's Disease and IBD

One study reported results for Crohn's disease and all IBD patients.150 In both groups, the study reported more infections in patients who used adalimumab or infliximab, compared with patients who had never used biologics.

#### Studies Evaluating Patients With IBD

Eight studies reported infections in IBD patients without separating Crohn's disease from ulcerative colitis or indeterminate colitis patients. We provided details about these studies in Appendix F.

#### Case-Control Studies Designed To Examine Specific Infections

Two case-control studies including 2,538 IBD patients examined specific infections. One study reported on opportunistic infections139 and the other on herpes zoster.135 Researchers nested the case-control studies within a large primary care database covering multiple centers135 and a single-center.139 Both studies may have patients that contributed to other studies using these data sources.133,134,136-138

##### Combinations Including Infliximab

The single-center case-control study included 300 IBD patients and reported on specific infections associated with combination therapy including infliximab.139

###### Infliximab Versus No IBD Medication

The single-center case-control study cross-referenced the system's diagnostic index for inpatient and outpatient IBD patients with a viral, fungal, or bacterial opportunistic infection.139 The study required microbiologic, pathologic, or physician consensus to confirm infection. The study analyzed and matched each of the first 100 consecutive infection cases diagnosed between 1998 and 2003 with two controls (patients who did not have an opportunistic infection). The study matched patients by type of IBD, sex, geographic region, and duration of visits for IBD at the center. Three of 100 opportunistic infection cases (3 percent) had used infliximab alone while being treated at the center, compared with two of 200 controls (1 percent). Compared with no use of mesalamine, corticosteroids, immunomodulators, and infliximab, the age and matching factor adjusted OR was 11.1 (95% CI, 0.8 to 148). The study did not provide the percent of cases and controls that did not use an IBD medication. One patients developed Epstein-Barr virus lymphoma, but the study did not provide the medication history. The authors also reported that no patient died as a result of their opportunistic infection.

###### Combination of Infliximab, Thiopurines, and Corticosteroids Versus No IBD Medication

The single-center case-control study reported five of 100 opportunistic infection cases (5 percent), compared with zero of 200 matched controls (0 percent), used a triple combination of infliximab, thiopurines, and corticosteroids.139

###### Combination of Infliximab and Thiopurines Versus No IBD Medication

The single-center case-control study reported one of 100 opportunistic infection cases (1 percent), compared with five of 200 matched controls (2 percent), used a combination of infliximab and thiopurines.139 Compared with no IBD medication use, the age and matching factor adjusted OR was 1.6 (95% CI, 0.1 to 19).

##### Combinations Including Immunomodulators

Two case-control studies including 2,538 IBD patients reported on specific infections associated with combination therapy including immunomodulators.135,139

###### Thiopurines Versus No IBD Medication

The single-center case-control study reported that 20 of 100 opportunistic infection cases (20 percent), compared with 31 of 200 matched controls (15 percent), used thiopurines alone. Compared with no IBD medication, the age and matching factor adjusted OR was 3.4 (95% CI, 1.5 to 7.5).139

A case-control study of herpes zoster infections looked at IBD patients within a multi-center general practice database.135 The study matched controls to cases on sex, year of birth, and duration of followup (prior to the case's herpes zoster diagnosis date). The study matched up to four controls that did not have herpes zoster during the followup to each case. Herpes zoster cases had 4 times higher odds of having a prescription for thiopurines alone, versus no IBD medication, in the 30 days prior to the index date, compared with controls (OR, 4.1; 95% CI, 1.9 to 8.7). When the study adjusted corticosteroids and mesalamine in the model (instead of excluding them), the OR was 3.1 (95% CI, 1.7 to 5.6). When the study considered thiopurine use 31 to 90 days before herpes zoster index date, the odds of infection with thiopurine use were no longer higher (OR, 0.6; 95% CI, 0.2 to 1.8).

###### Combination of Thiopurines and Corticosteroids Versus No IBD Medication

The single-center case-control study reported that 16 of 100 opportunistic infection cases (16 percent), compared with six of 200 matched controls (3 percent), used a combination of infliximab and thiopurines.139 Compared with no IBD medication use, the age and matching factor adjusted OR was 17.5 (95% CI, 4.5 to 68). The multi-center case-control study reported herpes zoster cases had 3 times higher odds of having a prescription for thiopurines alone, versus no IBD medication, in the 30 days prior to the index date, compared with controls (OR, 3.0; 95% CI, 1.2 to 7.3).135

##### Combinations Including Corticosteroids

Two case-control studies including 2,538 IBD patients reported on specific infections associated with combination therapy including corticosteroids.135,139

###### Corticosteroids Versus No IBD Medication

The single-center case-control study reported that 16 of 100 opportunistic infection cases (15 percent), compared with 27 of 200 matched controls (14 percent), used corticosteroids alone, compared with no IBD medication (the age and matching factor adjusted OR was 2.2, 95% CI, 1.0 to 4.9).139 The multiple center case-control study reported herpes zoster cases had 60 percent higher odds of having a prescription for thiopurines alone, versus no IBD medication, in the 30 days prior to the index date, compared with controls (OR, 1.6; 95% CI, 1.1 to 2.4).135

##### Combinations Including Aminosalicylates

One multiple center case-control study including 2,238 IBD patients reported on specific infections associated with combination therapy including aminosalicylates.135

###### Mesalamine Versus No Mesalamine

The case-control study reported that herpes zoster patients did not have an increased odds of having a prescription for mesalamine, compared with controls, in the 30 days prior to the index date (OR, 0.9; 95% CI, 0.7 to 1.2).135

### Tuberculosis

Tuberculosis is of special concern in Crohn's disease because the treatments suppress the immune system. The U.S. Food and Drug Administration has mandated a warning on adalimumab, infliximab, and certolizumab pegol regarding the risk of tuberculosis.178-180 Nine RCTs (n=3,295), two prospective studies (n=733), and five observational studies (n=2,655) reported on the risk of tuberculosis in patients receiving treatment for Crohn's disease (Appendix D, Evidence Table 14). Four of the RCTs excluded patients with a prior history of tuberculosis or initiating treatment prior to randomization. None of the RCTs described active assessment of tuberculosis specifically.

No RCTs of natalizumab, immunomodulators, corticosteroids, or aminosalicylates reported tuberculosis as an outcome. One study randomized patients to sulfasalazine, prednisone, or azathioprine, and included isoniazid as part of the treatment regimen in patients randomized to prednisone because of the known increased risk of tuberculosis associated with prednisone.56

Table 54 summarizes the reported rates of tuberculosis in studies of the treatment of Crohn's disease. We also provided additional details regarding related studies.

Table 54 Summary of reported rates of tuberculosis in randomized controlled trials^*^ comparing the safety of therapies for the management of Crohn's disease

Author, Year | Design, Duration N With CD New Users Only (Y/N) | Comparison, Dose | Specific Aim (Y/N) | Ascertainment of Tuberculosis During Study Tuberculosis Testing Before Enrollment | Concomitant Medications | Tuberculosis Results
Hanauer, 2002^86^ | RCT, 52 wk 573 N | Infliximab vs. placebo | N | Not specified N | ASA Steroids IMM Antibiotics | 1/385 (<1%) vs. 0/188 (0%)
Colombel, 2010^45^ | RCT, 52 wk 503 Y | Infliximab vs. azathioprine vs. infliximab + azathioprine | N | Not specified Y | ASA Steroids Antibiotics NR | 0/161 (0%) vs. 0/163 (0%) vs. 1/179 (1%)
Colombel, 2009^95^ | RCT, 52 wk 778 N | Adalimumab vs. placebo | N | Not specified Y | ASA Steroids IMM Antibiotics NR | 2/517 (<1%) vs. 0/261 (0%)
Sandborn, 2007^83^ | RCT, 52 wk 55 N | Adalimumab vs. placebo | N | Not specified Y | ASA Steroids IMM Antibiotics | 0/37 (0%) vs. 0/18 (0%)
Sandborn, 2007^38^ | RCT, 4 wk 325 N | Adalimumab vs. placebo | N | Not specified Y | | 0/159 vs. 0/166
Hanauer, 2006^37^ | RCT, 4 wk 299 Y | Adalimumab vs. placebo | N | Not specified Y | ASA Steroids IMM Antibiotics | 0/225 (0%) vs. 0/74(0%)
Schreiber, 2007^84^ | RCT, 18 wk 668 N | Certolizumab pegol vs. placebo | N | Not specified Y | ASA Steroids IMM Antibiotics | 1/216 (<1%) vs. 0/212 (0%)
Schreiber, 2005^40^ | RCT, 12 wk 292 N | Certolizumab pegol vs. placebo | N | Not specified Y | | 0/219 vs. 0/73
Winter, 2001^41^ | RCT, 12 wk 92 N | Certolizumab pegol vs. placebo | N | Not specified Y | | 0/68 vs. 0/24

ASA = aminosalicylates; CD = Crohn's disease; IBD = inflammatory bowel disease; IMM = immunomodulators; N = no; NR = not reported; RCT = randomized controlled trial; Steroids = corticosteroids; vs. = versus; wk = weeks; Y = yes

* Four observational studies reported on tuberculosis. Two cases among 743 infliximab users compared with no cases among 666 never users of biologic.153 No cases among 757 patients treated with combinations of medications with infliximab or infliximab alone.137,145,173

#### Adalimumab Versus Placebo

Four RCTs37,38,82,83 including 1,447 patients compared adalimumab with placebo. One of those studies82 reported two cases of tuberculosis, one patient receiving adalimumab 40 mg weekly and one patient receiving adalimumab 40 mg every other week, compared with no cases of tuberculosis in the placebo group. The other three studies reported no incident cases of tuberculosis. One study excluded patients with untreated tuberculosis within 3 months.38

#### Certolizumab Pegol Versus Placebo

Three RCTs including 812 Crohn's disease patients compared certolizumab pegol with placebo and reported on tuberculosis.40,41,84 A maintenance trial after induction response reported one tuberculosis case in the certolizumab pegol group (less than 1 percent of 216 patients) during 26 weeks of followup despite having excluded purified protein derivative positive patients from the study.84 The trials reported no other tuberculosis cases.40,41

#### Infliximab Versus Placebo

One RCT86 including 573 patients evaluated infliximab compared with placebo. The trial detected one incident case of tuberculosis in an infliximab patient.

#### Other Combinations With TNF-Alpha Inhibitors

An induction trial45 including 503 Crohn's disease patients compared infliximab, azathioprine, and the combination of infliximab and azathioprine. The trial reported one incident case of tuberculosis in the group receiving infliximab and azathioprine.

Two prospective studies (n=733) and five retrospective studies (n=2,655) reported on tuberculosis.132,137,145,153,161,165,173 Six studies compared combinations of medications with a TNF-alpha inhibitor and reported no tuberculosis cases.132,137,145,161,165,173 One retrospective study reported two tuberculosis cases among 743 infliximab users, compared with no cases among 666 non-users.153

### Infusion- and Injection-Site Reactions

Infusion and injection-site reactions can include a wide range of symptoms (from local irritation or pain to anaphylaxis) that occur during or shortly after an infusion. This definition is generally consistent (when reported) in the studies we included. Other types of reactions can occur a few days to a few weeks after medication administration, including hypersensitivity-type reactions, delayed infusion reactions, and serum sickness. We did not address these longer-term reactions in this review. In some cases, the study authors did not define the symptoms and timing of the infusion or injection-site reactions; we included these studies in this review.

Twenty-two RCTs including 6,809 patients reported infusion reactions as an outcome by comparison group, one of which addressed infusion reactions as a primary outcome of interest (Appendix D, Evidence Table 14).88 Four prospective studies, with 1,067 patients, and 10 retrospective studies, with 2,972 patients, reported on infusion reactions. Three observational studies mentioned active ascertainment as a means of identifying infusion reactions.138,161,181 All retrospective studies relied on chart reviews to identify infusion reactions. Many of the prospective and retrospective studies specifically stated or implied that patients were pre-treated with medications at the infusion center to prevent infusion reactions. Most RCTs did not report pre-treating patients with medications to prevent infusion reactions.

#### Natalizumab

Figure 26 summarizes the data on infusion- and injection-site reactions in RCTs evaluating natalizumab in patients with Crohn's disease. We also provided additional details regarding related studies.

Figure 26 Summary of Peto odds ratios of infusion- and injection-site reactions among randomized controlled trials comparing natalizumab to placebo in patients with Crohn's disease

CI = confidence interval; comp = comparison; NAT = natalizumab; OR = odds ratio

Figure 26 is a forest plot summarizing the Peto odds ratios of infusion- and injection-site reactions among randomized controlled trials comparing a biologic alone or in combination with another treatment. Three trials are included. The trials and their comparisons are: Feagan 2007 comparing natalizumab with placebo; Sandborn 2005 comparing natalizumab with placebo; and Targan 2007 comparing natalizumab with placebo. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratios are: 0.8 and a 95% confidence interval of 0.4 to 1.6 for Feagan 2007, 1.5 and a 95% confidence interval of 0.9 to 2.5 for Sandborn 2005, and 1.3 and a 95% confidence interval of 0.7 to 2.5 for Targan 2007. The results are summarized in the previous section.

##### Natalizumab Versus Placebo

Three RCTs including 1,414 Crohn's disease patients reported infusion reactions within 2 hours of the start of infusion in patients receiving natalizumab, compared with placebo. These appeared in two publications.32,33 During the induction trials, the trials reported infusion reactions in 9 to 11 percent of natalizumab and 7 to 8 percent of placebo patients.32,33 Researchers re-randomized 228 responders from one of these trials for a 48-week maintenance trial.33 They reported any adverse event occurring during or within 2 hours of infusion in 7 percent of natalizumab users and 8 percent of placebo users.

##### Combination of Natalizumab and Infliximab Versus Infliximab

One 20-week RCT including 79 non-responders to infliximab randomized patients to continued infliximab alone or natalizumab and infliximab. Three of 52 patients taking natalizumab and infliximab had a non-serious hypersensitivity reaction during or within 120 minutes of infusion, compared with zero of 27 patients taking only infliximab.35

#### TNF-Alpha Inhibitors

For studies that we combined in Key Questions 1 and 2 we tried to conduct meta-analyses separately for induction and maintenance RCTs comparing TNF-alpha inhibitors with placebo in terms of infusion- and injection-site reactions. However, we were unable to do so because of statistical heterogeneity (I-squared, 82 percent for induction trials and 87 percent for maintenance trials). Figures 27 and 28 summarize the data on infusion- and injection-site reactions in RCTs and observational studies evaluating TNF-alpha inhibitors in patients with Crohn's disease. We also provided additional details regarding related studies.

Figure 27 Summary of Peto odds ratios of infusion- and injection-site reactions among randomized controlled trials comparing a TNF-alpha inhibitor alone or in combination with another treatment in patients with Crohn's disease

ADA = adalimumab; AZA = azathioprine; CI = confidence interval; comp = comparison; CP = certolizumab pegol; IFX = infliximab; OR = odds ratio; THIO = thiopurine; TNF = tumor necrosis factor-alpha inhibitor

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Infusion and injection site reactions were defined as any adverse event occurring within 1 hour of infusion/injection.

^‡^ Infusion and injection site reactions were not defined in the study.

^§^ Infusion and injection site reactions were defined as any adverse event that occurred at the infusion/injection site and was temporarily related to the infusion/injection.

^║^ Infusion and injection site reactions were defined as any adverse event occurring within 2 hours of infusion/injection.

Figure 27 is a forest plot summarizing Peto odds ratios of infusion- and injection-site reactions among randomized controlled trials comparing a TNF-alpha inhibitor alone or in combination with another treatment. Sixteen trials are included, including 19 comparisons. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratio are: 0.9 and a 95% confidence interval of 0.4 to 2.3 for Colombel 2010 comparing a combination of infliximab and azathioprine with azathioprine, 3.0 and a 95% confidence interval of 1.5 to 6.1 for Colombel 2010 comparing infliximab with azathioprine, 0.3 and a 95% confidence interval of 0.3 to 0.6 for Colombel 2010 comparing a combination of infliximab and azathioprine with infliximab, 1.5 and a 95% confidence interval of 0.3 to 9.2 for Van Assche 2008, 2.3 and a 95% confidence interval of 1.5 to 3.7 for Hanauer 2002, 3.2 and a 95% confidence interval of 1.2 to 8.4 for Sands 2004, 2.0 and a 95% confidence interval of 1.4 to 2.9 for Colombel 2009, 1.1 and a 95% confidence interval of 0.7 to 2.3 for the first Sandborn 2007 comparing adalimumab with placebo, 2.0 and a 95% confidence interval of 1.1 to 3.6 for Hanauer 2006, 0.2 and a 95% confidence interval of 0.1 to 0.4 for Schreiber 2007, 0.2 and a 95% confidence interval of 0.1 to 0.4 for Sandborn 2007 comparing certolizumab pegol with placebo, and 1.7 and a 95% confidence interval of 0.5 to 6.2 for Mantzaris 2009, and 4.41 and a 95% confidence interval of 2.05 to 9.48 for Sandborn 2011. The rest of the comparisons were excluded from odds ratio calculation.

Figure 28 Summary of Peto odds ratios of infusion- and injection-site reactions among observational studies comparing a TNF-alpha inhibitor alone or in combination with another treatment in patients with Crohn's disease

ADA = adalimumab; ASA = aminosalicylate; CI = confidence interval; comp = comparison; CP = certolizumab pegol; IFX = infliximab; IMM = immunomodulator; MTX = methotrexate; NR = not reported; OR = odds ratio; Pro = prospective study; Retro = retrospective study; Steroid = corticosteroids; THIO = thiopurine; TNF = tumor necrosis factor-alpha inhibitor

^*^ We did not calculate odds ratios when there were fewer than five events total in the main intervention and comparison arms.

^†^ Adjusted odds ratio, 0.7 (95% CI, 0.4 to 1.1).

^‡^ Adjusted odds ratio, 0.3 (95% CI, 0.2 to 0.9).

Figure 28 is a forest plot type diagram summarizing Peto odds ratios of infusion- and injection-site reactions among observational studies comparing a TNF-alpha inhibitor alone or in combination with another treatment. Seven studies are included, including 15 comparisons. When there were at least 5 events total in the main intervention and comparison groups, we calculated a Peto odds ratio with a 95% confidence interval. The information presented in the plot shows the odds ratio with a 95% confidence interval when we were able to calculate it, number of weeks, number of events in comparison group, total number in the comparison, number of events in the main intervention, and total number in main intervention. The calculated odds ratio are: 0.6 and a 95% confidence interval of 0.4 to 1.1 for Keshavarzian 2007, 0.5 and a 95% confidence interval 0.3 to 0.9 for Moss 2008, 0.3 and a 95% confidence interval 0.1 to 0.6 for Vermeire 2007 comparing a combination of infliximab and methotrexate with infliximab, 0.3 and a 95% confidence interval 0.2 to 0.7 for Vermeire 2007 comparing a combination of infliximab and thiopurines with infliximab, 0.6 and a 95% confidence interval 0.2 to 2.1 for Kinney 2003 comparing a combination of infliximab and methotrexate with infliximab, 0.6 and a 95% confidence interval 0.2 to 1.7 for Kinney 2003 comparing a combination of infliximab and thiopurines with infliximab, 1.4 and a 95% confidence interval 0.5 to 3.7 for Vermeire 2007 comparing a combination of infliximab and thiopurines with a combination of infliximab and methotrexate, and 0.9 and a 95% confidence interval 0.2 to 3.8 for Kinney 2003 comparing a combination of infliximab and methotrexate and a combination of infliximab and thiopurines and 0.29 with a 95% confidence interval of 0.09 to 0.92 comparing infliximab + immunomodulator with infliximab + no immunomodulator for Lee 2011 and 1.36 with a 95% confidence interval of 0.33 to 5.57 comparing infliximab + corticosteroids with infliximab + no corticosteroid for Lee 2011. The Seiderer 2004 and Lichtiger 2010 comparisons were excluded from odds ratio calculation.

##### Adalimumab Versus Placebo

Four RCTs including 1,457 Crohn's disease patients compared adalimumab with placebo and reported injection reactions. In two induction trials, injection-site reactions were more common in adalimumab (11 to 29 percent) and placebo (10 to 16 percent) patients.37,38

A 52-week maintenance trial of 55 patients who achieved remission during induction, reported injection-site reactions in one of 37 patients on adalimumab and two of 18 patients on placebo.83 Those who the trial did not randomize for the maintenance study received adalimumab without blinding. Twenty-six of 221 (12 percent) patients who entered open-label adalimumab therapy, or were not randomized, had an injection-site reaction.83 The publications that studied maintenance and induction reported different numbers of patients randomized in the induction trial (n=299 and n=276).

A 52-week maintenance trial of responders from a 4-week induction period reported injection-site reactions in 26 percent of patients on adalimumab and 14 percent of patients on placebo who re-initiated adalimumab after week 12 (blinding maintained).95 Another publication of this trial reported injection-site reactions during the randomized followup in 5 percent of patients on adalimumab and less than 1 percent of the patients on placebo.82 The publications did not define injection-site reactions.

##### Other Combinations With Adalimumab

A prospective cohort of 673 patients, treated with adalimumab with or without concomitant aminosalicylates, corticosteroids, or immunomodulators, reported no injection-site reactions at 18 weeks.161

##### Certolizumab Pegol Versus Placebo

Five RCTs including 1,910 Crohn's disease patients compared certolizumab pegol with placebo and reported infusion or injection-site reactions.39-41,84 The duration of the four induction trials ranged from 6 to 26 weeks. Reactions occurred in 0 to 11 percent of certolizumab pegol and 0 to 14 percent of placebo patients.39-42 The Peto OR ranged from 0.2 to 6.4.^39,40,42^

A maintenance trial of 428 patients who responded to certolizumab pegol induction39 reported any local reaction to infusion in six out of 216 patients on certolizumab pegol (3 percent) and 31 out of 212 patients on placebo (15 percent ), during the 18-week followup.84 The corresponding Peto OR was the same as the induction OR (0.2; 95% CI, 0.1 to 0.4).

##### Infliximab Versus Placebo

Four RCTs including 1,022 patients compared infliximab with placebo and reported infusion reactions.44,85-87 Infusion reactions, defined as an adverse event during or within 2 hours of infusion, occurred in 6 percent of infliximab and 0 percent of placebo patients, during an induction trial.44

A 36-week trial85 compared retreatment with infliximab or placebo among 73 responders to a single induction dose in a previous 12-week trial.43 The trial reported an acute infusion reaction with dyspnea in one of 36 infliximab patients. The trial did not report infusion reactions in 36 patients on placebo, although it is unclear if infusion reactions were a possible safety outcome for placebo patients. The trial corresponding to the induction period reported infusion reactions only for those who received two doses of infliximab and only during the second infusion (two of 29 patients).43

A 40-week maintenance trial, of 282 responders and non-responders to a 14-week induction period with infliximab for fistulizing Crohn's disease, compared infliximab with placebo.87 They reported infusion reactions during or within 1 hour of infusion in 9 percent of patients on infliximab and 3 percent of patients on placebo, during the randomized period. During induction (among patients randomized for maintenance therapy), 7 percent of patients on infliximab and 8 percent of patients on placebo had an infusion reaction (the trial did not randomize nine of 306 given induction because of adverse events; the trial did not report the adverse events). At 22 weeks, placebo patients were eligible to crossover to 5 mg/kg intravenous every 8 weeks infliximab treatment; and patients receiving 5 mg/kg of infliximab were eligible to have the dose increased to 10 mg/kg (the trial maintained blinding after crossover). During crossover, 9 percent of those who had a dose increase to 10 mg/kg experienced an infusion reaction, compared with 23 percent of patients who crossed over to infliximab from placebo.

A 52-week maintenance trial, of 573 responders and non-responders to a 2-week induction period of a single infliximab dose, compared infliximab with placebo and reported adverse events during or within 1 hour of infusion.86 The trial reported infusion reactions in 21 percent of infliximab patients and 9 percent of placebo patients, during the maintenance period (the trial did not report reactions during the initial infusion).

##### Infliximab Versus Azathioprine

One RCT including 324 Crohn's disease patients compared infliximab with azathioprine and reported on infusion reactions.45 Seventeen percent of patients taking infliximab and 6 percent of patients taking azathioprine experienced an adverse event during or within 1 hour of infusion.

##### Other Combinations With Infliximab

Four retrospective studies including 1,152 Crohn's disease patients met the inclusion criteria, but the studies may have misclassified the concomitant medications (as described previously in the mortality section). The studies evaluated the safety profile of infliximab use at their centers.137,145,164,175 A retrospective study reported infusion reactions that resulted in medication discontinuation in 5 percent of 127 patients taking infliximab and an immunomodulator, compared with 13 percent of 71 patients receiving infliximab without concomitant immunomodulators, as recorded in a database that included most of the patients treated with infliximab at the center.175 The other studies reported infusion reactions in 2 to 5 percent of patients receiving a triple combination of infliximab, immunomodulators, and corticosteroids, 4 to 20 percent of patients receiving the combination of infliximab and immunomodulator, 0 to 7 percent of patients receiving the combination of infliximab and corticosteroid, and 5 to 21 percent of patients receiving only infliximab.137,145,164 In a previous report from one of these centers, 19 infusion reactions occurred in the first 100 patients given infliximab.138 However, we noted a discrepancy between the two reports from this center. One article reported concomitant medications in 18 of 19 infusion reactions among the first 100 patients,138 but the other article reported concomitant medications in only 17 of 19 infusion reactions among the first 500 patients.137

##### Combination of Infliximab and Immunomodulators Versus Infliximab

Three RCTs including 468 Crohn's disease patients and three retrospective studies (n=1,025), compared a combination of infliximab and immunomodulators with infliximab and reported infusion reactions.45,88,89 A 50-week induction trial compared an infliximab-azathioprine combination with infliximab among patients who were naïve to TNF-alpha inhibitors, azathioprine, 6-mercaptopurine, and methotrexate.45 They reported adverse events during or within 1 hour of infusion in 5 percent of 179 patients taking infliximab and azathioprine and 17 percent of 163 patients taking infliximab.45

A 104-week induction trial, of blinded physicians and unblinded steroid-dependent luminal Crohn's disease patients, reported severe infusion reactions in zero of 23 patients taking infliximab and azathioprine and one of 23 patients taking infliximab and hydrocortisone.88 The group taking infliximab and azathioprine included only azathioprine-naïve patients whereas the infliximab group included both azathioprine-naïve patients as well as those who had previously taken azathioprine for less than a month (but stopped because of intolerance or severe adverse events). The infliximab group received a pre-infusion dose of hydrocortisone whereas the infliximab and azathioprine group did not.

A 104-week open-label retreatment trial of non-fistulizing Crohn's disease patients reported three unspecified infusion reactions in the 40 patients taking infliximab and an immunomodulator (it is possible that these reactions occurred in the same person), and two infusion reactions in the 40 patients taking infliximab.89

One prospective and three retrospective observational studies including 1,025 patients reported on infusion reactions.148,154,162,182 The prospective study154 included patients receiving infliximab without concomitant immunomodulators. The study occurred in 2000 and 2001, before the authors reported that concomitant immunomodulators appeared to be associated with a decreased risk of infusion reactions and changed their practice pattern.183 During 2002 and 2003, a study treated patients with infliximab and concomitant azathioprine, 6-mercaptopurine, or methotrexate.154 The study gave luminal disease patients a single induction infusion, and fistulizing disease patients a three-dose induction regimen (at 0, 2, and 6 weeks). If clinicians felt the patients lost response or had an acute flare, they treated patients with infliximab and considered them at risk of infusion reaction. Infusion reactions in retreated patients occurred in 16 percent of 115 patients taking infliximab and an immunomodulator, compared with 40 percent of 59 patients taking infliximab without an immunomodulator. The Peto OR was similar for both the combination of infliximab and a thiopurine (OR, 0.3; 95% CI, 0.2 to 0.7) and the combination of infliximab and methotrexate (OR, 0.3; 95% CI, 0.1 to 0.6), compared with infliximab.

The retrospective studies reported infusion reactions in 11 to 18 percent of infliximab combined with immunomodulators, compared to 22 to 25 percent in patients not receiving a concomitant immunomodulators.148,162,182,184 The Peto OR favored infliximab combined with immunomodulators to decrease infusion reactions in all studies. We did not perform a meta-analysis because of the different time periods of followup, definitions of infusion reaction, and immunomodulators allowed.

##### Combination of Infliximab and Immunomodulators Versus Immunomodulators

Two RCTs45,46 including 452 Crohn's disease patients reported infusion reactions in users of infliximab and an immunomodulator, compared with users of an immunomodulator alone.

A 52-week induction trial in steroid-dependent, luminal Crohn's disease patients reported a severe infusion reaction in one of 57 patients taking infliximab and a thiopurine, and zero of 56 patients taking a thiopurine alone.46 A 50-week induction trial compared infliximab and azathioprine with azathioprine alone among patients who were naïve to TNF-alpha inhibitors, azathioprine, 6-mercaptopurine, and methotrexate.45 The trial reported adverse events during or within 1 hour of infusion in 5 percent of patients taking infliximab and azathioprine, and 6 percent of patients taking azathioprine.45

##### Combination of Infliximab and Thiopurines Versus Combination of Infliximab and Methotrexate

Two observational studies including 291 Crohn's disease patients compared a combination of infliximab and azathioprine with a combination of infliximab and methotrexate and reported infusion reactions.154,162 A prospective study of retreated patients reported infusion reactions by type of concomitant immunomodulators. Infusion reactions occurred in 18 percent of patients taking infliximab and azathioprine, compared with 14 percent of patients taking infliximab and methotrexate.154 A retrospective study of 1 year mean followup reported infusion reactions in 14 percent of patients taking infliximab and a thiopurine, and 13 percent of patients taking infliximab and methotrexate.162

#### Immunomodulators

##### Azathioprine Versus Placebo

One RCT including 96 patients evaluated infusion reactions (not defined) following a single infusion of azathioprine 40 mg/kg, compared with placebo.59 The trial reported infusion reactions in 11 of 51 patients receiving azathioprine (22 percent) and one of 45 patients receiving placebo (2 percent). The corresponding Peto OR was 5.8 (95% CI, 1.7 to 19.2).

#### Studies Evaluating Patients With IBD

Four studies reported infusion- and injection-site reactions in IBD patients without separating Crohn's disease patients from ulcerative colitis or indeterminate colitis patients. We provided details about these studies in Appendix F.

### Bone Fractures

We did not identify any studies comparing biologics, immunomodulators, or aminosalicylates in terms of the risk of bone fracture. Three studies including 1,032 patients with at least one corticosteroids group reported bone fractures (Table 55; Appendix D, Evidence Table 14).127,185,186 Two of these studies excluded patients who had used medications for preventing fractures or osteoporosis,187 such as bisphosphonates; hormone replacement therapy; and certain doses of calcium, fluoride or Vitamin D supplements, within 6 or 24 months of the study.127,185 One of the studies that made these exclusions recruited patients with osteoporosis.127

Table 55 Summary of the risk of bone fracture in studies comparing the safety of therapies for the management of Crohn's disease

Author, Year | Design, Duration N CD/IBD New Users Only / Specific Aim (Y/N) | Comparison, Dose Source for Non-RCTs | Assessment of Bone Fracture | Surveillance Blinded Assessments (Y/N) | Concomitant Medications | Bone Fracture Results
Schoon, 2005^185^ | RCT, 2y 271 CD N / Y | Budesonide, 9 mg qd vs. prednisolone, 40 mg qd | Vertebrae with a height reduction of >20% as measured by X-ray and traumatic fractures | Active Y | ASA, IMM, vitamin D and calcium supplementation | 2/137 (2%) vs. 3/134 (2%)
Siffledeen, 2007^127^ | Cross-sectional 207 CD N / Y | Steroid use vs. no steroid use in past year Questionnaire | Vertebrae with a height reduction of >20% and a loss of surface area >10% in the presence of a biconcave, crush, or wedge deformity as measured by DXA scan | Active Y | NR | 25/105 (24%) vs. 17/102 (17%)
Bernstein, 2003^186^ | Case-control 116 CD N / Y | Steroid use in two years prior to fracture vs. no steroid use in two years prior to fracture Electronic pharmacy record | ICD-9 codes 805, 807.0, 807.1, 813 and 820 representing fractures at the hip, spine, ribs or wrist | NA | NR | 7/13 (54%) vs. 23/103 (22%)
Goldstein, 1967^142^ | Retrospective cohort, NR 554 IBD N / N | Steroid non-user vs. steroid user Chart review | Pathologic fractures recorded in patient chart | Passive NR | NR^*^ | 0/124 (0%) vs. 6/430 (1%)

ASA = aminosalicylates; CD = Crohn's disease; DXA = dual energy x-ray absorptiometry; IBD = inflammatory bowel disease; ICD-9 = International Classification of Diseases, Ninth Revision; IMM = immunomodulators; mg = milligrams; N = no; NA = not applicable, secondary database analysis; NR = not reported; qd = once daily; RCT = randomized controlled trial; vs. = versus; y = year; Y = yes

* Concomitant medication use other than aminosalicylates was deemed unlikely because the last point of data collection was 1965.

#### Budesonide Versus Prednisolone

One 2-year RCT (n=271) specifically compared the risk of vertebral fractures between budesonide and prednisolone in ileal or ileocolonic uncomplicated Crohn's disease.185 The study found a similar percentage of vertebral or traumatic fractures in both study groups (2 percent). The authors also reported that 14 percent of patients had non-symptomatic vertebral fractures at baseline.

#### Corticosteroids Versus No Corticosteroids

A cross-sectional study of 207 Crohn's disease patients compared questionnaire-reported use of corticosteroids in the year prior to a dual-energy X-ray absorptiometry (DXA) scan with no reported use of corticosteroids in the prior year.127 Seventeen percent of 102 non-users had a vertebral fracture, compared with 24 percent of 105 corticosteroid users. The study reported a Pearson correlation coefficient P-value of 0.27 for this comparison. A case-control study of Crohn's disease patients reported seven out of 13 cases of hip, spine, rib, or wrist fracture had used corticosteroid within 2 years of injury (54 percent), compared with 23 corticosteroid users among 103 controls (22 percent).186

#### Studies Evaluating Patients With IBD

One retrospective cohort reported on bone fractures in the treatment of IBD without separating Crohn's disease from ulcerative colitis or indeterminate colitis (see Appendix F).

#### Studies Reporting Results for Crohn's Disease and IBD

A case-control study reported similar rates of bone fracture for all IBD patients (30 percent of 40 cases of bone fracture were corticosteroid users, compared with 22 percent of 276 controls; the unadjusted OR was 1.8; 95% CI, 0.6 to 3.7).186

### Study Quality

We rated many of the studies containing data relevant to Key Question 3 as low quality for assessing the question of patient safety because they did not report on the specific safety outcomes that we sought to assess in this review. In many cases, the studies did not report their primary exposure-outcome relationship sufficiently and did not account for confounding and selection bias in the safety analyses. Another common reason we rated studies as poor quality was the inability to adjust for confounders because of the small number of events, even if all other reporting and bias adjustment categories were sufficient.

Of the prospective and retrospective observational studies, we rated all as poor quality except eight. We rated seven studies good quality and one study fair quality. Of the nine included case-control studies, we rated four good quality and five poor quality (see Appendix D, Tables 15 and 16).

## Key Question 4 Effectiveness of Therapies Used To Prevent Post-Operative Recurrence as Pertains to Patient-Reported Outcomes

### Studies Included

We included two studies with 120 participants, in KQ4--an RCT and a prospective cohort study (Appendix D, Evidence Tables 17-20).188,189 These studies considered comparisons with azathioprine and mesalamine; no evidence is available for this KQ with regard to other agents.

### Study Design and Population Characteristics

#### Randomized Controlled Trial

The RCT was a 1-year, double-blind, double-dummy, randomized trial which took place in 21 gastroenterology centers in Austria, the Czech Republic, Germany, and Israel.188 The study participants were 78 adults with Crohn's disease who had undergone resection with ileocolonic anastomosis in the preceding 6 to 24 months without subsequent clinical recurrence. The participants had a CDAI score less than 200, but with moderate or severe endoscopic recurrence. The study drugs were azathioprine 2.0-2.5 mg/kg/day (N=41) or mesalamine 4 g/day (N=37) over 1 year.

The mean age in the groups was 35.5 years for azathioprine and 36.0 for mesalamine. Fifty-nine percent of the azathioprine group and 54 percent of the mesalamine group were male. Proportions of continuous, recurrent, and unknown course were similar in the two groups. Mean baseline IBDQ in the two groups was 191 and 175 for azathioprine and mesalamine, respectively.

#### Observational Study

The observational study189 was a prospective cohort study with 42 participants, which investigated the influence of azathioprine on postoperative recurrence in a subgroup of Crohn's disease patients considered to have aggressive disease. In a nested case-control study, controls were patients selected to treatment but intolerable to azathioprine or 6-mercaptopurine; the study compared their postoperative course with that of patients receiving and tolerating the drugs postoperatively.

Twenty-eight participants received azathioprine, compared with 14 controls. The participants receiving azathioprine had a median age of 34.5 years (range, 17 to 71 years); the controls had a median age of 38.0 years (range, 19 to 64 years). Of patients receiving azathioprine, three (10 percent) were smokers, compared with none of the controls. The duration of disease among participants receiving azathioprine was a median of 13 years (range, 0 to 34 years); among controls it was a median of 12.5 years (range, 0 to 36 years). Fourteen (50 percent) of the azathioprine recipients and six (43 percent) of the controls had perianal disease. Median followup among azathioprine recipients and controls was 85.1 months (range, 23 to 139 months) and 78.7 months (range, 25.4 to 140 months), respectively.

### Study Results

#### Randomized Controlled Trial

The RCT used the IBDQ as its patient-reported outcome.188 The change in mean IBDQ score from baseline (azathioprine, 191; mesalamine, 175) to last on-treatment visit (azathioprine, 200; mesalamine, 180) was similar in both treatment arms (change in the azathioprine group, 9; standard deviation, 17.7, change in the mesalamine group, 5; standard deviation, 27.4; P=0.4565, two-sided Wilcoxon test).

#### Observational Study

The prospective cohort used as its patient-reported outcome the patients' assessment of general health according to a visual analogue scale (VAS) integrated over time.189 The VAS used runs from 0 to 100, where 0 is the worst possible score and 100 corresponds to perfect health. The authors stated that “repeated observations on the VAS …were integrated over time as a way of describing the patients' condition during the study period.”189 The study did not offer any more details.

The study did not find any difference between the groups in perceived health over time, as evaluated on the VAS. In the azathioprine group, the mean VAS integrated over time was 65.4 (range, 0 to 99.4); in the control group it was 55.5 (range, 14.6 to 98.6). The study rated this difference as not statistically significant, although it did not provide any measures of variation.

### Study Quality and Limitations

#### Randomized Controlled Trial

The risk of bias for the RCT188 is low. However, one should give consideration to the fact that the study was industry-funded and that industry investigators were among the co-authors. The study did not provide any information on what role industry played in design or analysis. Consistency is unclear, given that this is a single study. With regard to directness, this study is direct. The study is precise. In summary, the quality of this study is high.

#### Observational Study

The risk of bias for this study is moderate to high,189 given its small sample size and uncontrolled nature; in addition, it is unclear whether the study blinded participants to their treatment assignment, and whether the study authors (in “integrating” the VAS over time [about which no detail was given]), were blinded to the participants' treatment group. Consistency is unclear given that this is a single study. With regard to directness, this study is direct. We could not determine the precision given the lack of information. In summary, the quality of this study is low. Limitations of this study include the lack of information on variation and statistical procedures used in integrating the VAS, and that the study selected a measure of patient outcome not used in other studies (e.g., the SF-36 or IBDQ).

## Pediatric Results

Few studies compared the efficacy or safety of Crohn's disease treatments in the pediatric population (younger than 18 years old).

Five randomized controlled trials (RCTs) compared the efficacy of therapies, alone or in combination, to induce or maintain remission in children with Crohn's disease. No other RCTs that included participants less than 18 years of age reported results separately for the pediatric population.

Nine studies reported the comparative safety of therapies alone or in combination in children with Crohn's disease. Of these nine studies, the majority studied height or weight change as their primary outcomes of interest. Five additional studies included both children and adults, but did not report results separately for the pediatric population.

### Key Question 1 Effectiveness of Therapies To Induce Remission in Children

#### Key Points

##### Disease Activity Scales

- The combination therapy 6-mercaptopurine and prednisone was more effective than prednisone alone in reducing remission after 1 month of treatment in children with Crohn's disease (relative risk [RR], 1.18; 95% confidence interval [CI], 0.95 to 1.47). (strength of evidence [SOE]: Low)
- Budesonide and prednisolone did not differ in inducing remission at week eight in children with Crohn's disease (RR, 0.77; 95% CI, 0.49 to 1.22). (SOE: Moderate)
- Combination therapy with prednisone and mesalamine and combination therapy with budesonide and mesalamine did not differ in inducing remission at week 12 in children with Crohn's disease (RR, 0.95; 95% CI 0.47 to 1.92). (SOE: Low)
- We did not find any studies addressing the comparative effectiveness of other therapies alone or in combination to induce remission in children with Crohn's disease. (SOE: Insufficient)

##### Reduction of Steroids

- The drug 6-mercaptopurine was more effective than placebo in reducing the need for corticosteroids in children with Crohn's disease (observed-to-expected ratio of days on prednisone, 0.73 for the 6-mercaptopurine group, and 1.34 for the placebo group; P < 0.001). (SOE: Low)
- We found insufficient evidence to determine the comparative effectiveness of other therapies alone or in combination to reduce the need for corticosteroids in children with Crohn's disease. We did not find any studies evaluating the effects of biologics, azathioprine, methotrexate, corticosteroids, or aminosalicylates on the reduction of steroids in children.

##### Mucosal Healing, Hospitalization, Surgery, Fistula Response, and Patient-Reported Outcomes

- We found insufficient evidence to determine the comparative effectiveness of therapies alone, or in combination, with respect to mucosal healing, hospitalization, surgery, fistula response, and patient-reported outcomes, in children with Crohn's disease. No studies evaluating those outcomes in children met our inclusion criteria.

Table 56 summarizes the evidence grades and specific conclusions for each comparison. Details of the evidence grades are in Appendix D, Table 21.

Table 56 Key findings and strength of evidence comparing pharmacologic therapies for the management of Crohn's disease to induce remission in children

Comparison | Disease Activity Scale | Mucosal Healing | Hospitalizations | Surgeries | Reduction of Steroids | Fistula Response | Patient-Reported Outcomes
6-Mercaptopurine and prednisone vs. prednisone alone | Favors 6-mercaptopurine and prednisone; Low | Insufficient | Insufficient | Favors 6-mercaptopurine; Low | Insufficient | Insufficient | Insufficient
Prednisone and mesalamine vs. budesonide and mesalamine | Neither drug combination favored; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Budesonide vs. prednisolone | Neither drug favored; Mod | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient

Note: We defined the strength of the evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Mod = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

We graded all other comparisons and outcomes as insufficient since there were no eligible studies.

#### Study Design and Population Characteristics

Three RCTs compared the effectiveness of therapies alone or in combination to induce remission in children with Crohn's disease (Appendix D, Evidence Tables 22 and 23).190-192 None of these RCTs were crossover studies and none had a run-in period. All three RCTs were multi-centered studies (one in the United States, one in Europe, and one in Israel). The total length of followup was 8 weeks, 12 weeks, and 18 months.

All three RCTs included pediatric patients exclusively, totaling 136 children. All three studies reported the mean age of the children was 13.3 years (range: 13.0 to 13.9 years). One study (48 children) reported the mean disease duration was 0.7 years.190 Eighty-six of the 136 children were male (63 percent, range: 60 to 69 percent). One study reported race, listing 51 of 55 children (93 percent) as white.192

Age, disease location, disease severity, and baseline disease activity were comparable in the RCTs. Two of the three studies reported disease location.190,192 Twenty-five of 103 children (24 percent, range: 9 to 42 percent) had ileal disease, 65 of 103 children (63 percent, range: 50 to 75 percent) had ileocolonic disease, 12 of 103 children (12 percent, range: 6 to 16 percent) had colonic disease, and zero of 103 children had perianal disease. All three studies reported disease severity.190-192 The mean baseline Pediatric Crohn's Disease Activity Index (PCDAI) score was consistent with moderate-to-severe disease in all three studies (range, 29.1 to 45.7]).193 One study (48 children) reported the Crohn's Disease Activity Index (CDAI) and Harvey-Bradshaw index (HBI).190 The mean CDAI score was 255 and mean baseline HBI score was 7.5. None of these studies reported on smoking status, age at diagnosis, disease behavior, baseline Inflammatory Bowel Disease Questionnaire (IBDQ) score, or C-reactive protein (CRP) level.

Other inclusion criteria were similar for the three studies. Individual studies further restricted their patients on disease location, disease duration, and medications allowed prior to and during the study. One study, comparing budesonide with prednisolone,190 included children with disease of the ileum or ascending colon exclusively. One study, comparing a combination of prednisone and mesalamine with a combination of budesonide and mesalamine,191 only included children with a disease duration of at least 2 months; while another study, comparing a combination of 6-mercaptopurine and prednisone with prednisone alone, included children with a disease duration of less than 8 weeks.192 Two studies191,192 did not allow children any additional treatment during the study. The third study190 allowed children to continue taking additional aminosalicylates or antibiotics as long as they received a constant dose for the 30 days prior to randomization of budesonide or prednisolone.

#### Disease Activity Measures

All three RCTs used disease activity scales to measure remission (Appendix D, Evidence Table 24).190-192 The disease activity scales were the PCDAI, CDAI, and HBI. We summarized the absolute disease activity scores in Table 57. None of these studies provided a measure of variability, thereby limiting our ability to comment of the effectiveness of these therapies on affecting these indexes.

Table 57 Summary of absolute disease activity scores in studies comparing the effectiveness of medications in inducing remission in children with Crohn's disease

Author, Year | Length of Followup | Main Intervention (Dose), N | Comparison (Dose), N | Baseline Activity Score | Final Activity Score
Markowitz, 2000^192^ | 1 mo | 6-Mercaptopurine (1.5 mg/kg daily) + prednisone taper, 27 | Placebo + prednisone taper, 28 | 7.7 vs. 7.4 (mean HBI) | NR
Escher, 2004^190^ | 8 wks | Budesonide (9 mg daily × 8 wks, then 6 mg daily × 4 wks), 22 | Prednisolone (1 mg/kg daily × 4 wks, then tapering for 8 wks), 24 | 39 vs. 45 (mean PCDAI) | 149 vs. 97 (mean CDAI)
Levine, 2003^191^ | 12 wks | Budesonide (3 mg q 8 hours × 8 wks, then tapered wks 9-10, discontinued after 10 wks) + mesalamine, (3-4 g daily wks 11-12), 19 | Prednisone (40 mg daily × 2 wks, then tapered wks 3-10, discontinued after 10 wks) + mesalamine (3-4 g daily wks 11-12), 14 | 29.3 vs. 28.9 (mean PCDAI) | -9.3 vs. -13.4 (change in PCDAI)

CDAI = Crohn's Disease Activity Index; HBI = Harvey-Bradshaw Index; mg = milligram; mg/kg = milligrams per kilogram; mo = month; NR = not reported; PCDAI = Pediatric Crohn's Disease Activity Index; wks = weeks

##### Combination of 6-Mercaptopurine and Prednisone Versus Prednisone Alone

One RCT randomized 55 children to a combination of 1.5 mg/kg per day of 6-mercaptopurine and prednisone or prednisone alone with a scheduled taper, and evaluated inactive disease (defined as total HBI score less than 3).192 After 1 month of treatment, 93 percent of 27 children in the combination group and 79 percent of 28 children in the prednisone alone group had inactive disease.

##### Budesonide Versus Prednisolone

One RCT assessed remission (defined as CDAI less than or equal to 150) in 18 children with active Crohn's disease (CDAI greater than 150). The study randomized the children to 9 mg per day of budesonide taper or 1 mg/kg per day of prednisolone taper.190 The study saw remission at 8 weeks in 12 of 22 children (55 percent) in the budesonide treatment group, and 17 of 24 children (71 percent) in the prednisolone treatment group. The remission rate difference between the two groups was 16 percent (95% CI, 13 to 45 percent, P=0.25).

##### Combination of Budesonide and Mesalamine Versus Combination of Prednisone and Mesalamine

One RCT examined remission within 12 weeks (defined as PCDAI of less than or equal to 10) in 33 pediatric patients with mild-to-moderate Crohn's disease (PCDAI 12.5 to 40).191 The percent of children in remission did not differ between the two treatment groups at 4, 8, or 12 weeks. At 12 weeks, nine of 19 children (47 percent) receiving 9 mg per day budesonide taper with mesalamine, and seven of 14 children (50 percent) receiving 40 mg per day prednisone taper with mesalamine, were in remission.

#### Mucosal Healing

We did not find any studies conducted among children with active Crohn's disease that evaluated mucosal healing.

#### Hospitalizations

We did not find any studies conducted among children with active Crohn's disease that evaluated hospitalization rates.

#### Surgeries

No study of children with Crohn's disease reported surgeries as an outcome of interest. One study of children with Crohn's disease did comment that four children who withdrew from the study (one patient from the 6-mercaptopurine and prednisone group and three children from the placebo and prednisone group) required surgery after withdrawal.192

#### Reduction of Steroids

##### 6-Mercaptopurine Versus Placebo

One RCT of pediatric patients with Crohn's disease192 looked at the reduction of corticosteroids as an outcome of interest among children. The study randomized the children to a combination of 6-mercaptopurine and prednisone or prednisone alone (Appendix D, Evidence Table 24). The study increased, decreased, or did not change prednisone dosage based on the patient's change in partial HBI score. Children in the 1.5 mg/kg per day 6-mercaptopurine group required fewer days of prednisone treatment than the children in the placebo group, with an observed-to-expected ratio of days on prednisone of 0.73 for the 6-mercaptopurine group, and 1.34 for the placebo group (P < 0.001). Both groups required comparable time to initially wean off prednisone, with the children in the 6-mercaptopurine group requiring a median of 121 days (95% CI, 117 to 143 days), and the children in the placebo group requiring a median of 131 days (95% CI, 120 to 178 days, P > 0.05).

#### Fistula Response

None of the studies looked at fistula response as an outcome of interest among children with active Crohn's disease.

#### Patient-Reported Outcomes

We did not find any studies evaluating patient-reported outcomes as an outcome of interest among children with active Crohn's disease.

#### Study Quality

Of the studies on treatment of children with Crohn's disease, two studies190 192 had good quality and one study191 had poor quality (Appendix D, Evidence Table 25). The two good-quality studies had an adequate allocation sequence and concealment, adequate blinding, and complete outcome data. The other study was unclear about the allocation sequence and concealment, blinding technique, and completeness of outcome data. Only one of the studies reported pharmaceutical support and company involvement in the design, conduct, or reporting of the trial.190

### Key Question 2 Effectiveness of Therapies To Maintain Remission in Children

#### Key Points

##### Disease Activity Scales

- Among those who achieved remission with induction infliximab, maintenance infliximab was more effective than episodic therapy at maintaining remission at week 50 in children with Crohn's disease (RR, 1.35; 95% CI, 0.84 to 2.18). (SOE: Low)
- Mesalamine and placebo did not differ in maintaining remission at 1 year in children with Crohn's disease (RR, 0.90; 95% CI, 0.67 to 1.21). (SOE: Low)
- We found insufficient evidence to determine the comparative effectiveness of other therapies alone or in combination to maintain remission in children with Crohn's disease. We did not find any studies evaluating the effectiveness of thiopurines, methotrexate, corticosteroids, or sulfasalazine in children with Crohn's disease.

##### Surgeries

- Mesalamine and placebo did not differ in maintaining remission and avoiding surgeries at year one in children with Crohn's disease (no events observed in either arm). (SOE: Low)
- We found insufficient evidence to determine the comparative effectiveness of other therapies alone or in combination in maintaining remission and avoiding surgeries in children with Crohn's disease. We did not find any studies evaluating the effectiveness of biologics, thiopurines, methotrexate, corticosteroids, or sulfasalazine in children with Crohn's disease.

##### Mucosal Healing, Hospitalization, Reduction of Steroids, Fistula Response, and Patient-Reported Outcomes

- We found insufficient evidence to determine the comparative effectiveness of therapies alone or in combination in maintaining remission with respect to mucosal healing, hospitalizations, reduction of steroids, fistula response, and patient-reported outcomes in children with Crohn's disease. We did not find any studies evaluating the effectiveness of biologics, thiopurines, methotrexate, corticosteroids, or aminosalicylates in children with Crohn's disease.

Table 58 summarizes the evidence grades and specific conclusions for each comparison. Details of the evidence grades are in Appendix D, Table 21.

Table 58 Key findings and strength of evidence comparing pharmacologic therapies for the management of children with Crohn's disease to maintain remission

Comparison | Disease Activity Scale | Mucosal Healing | Hospitalizations | Surgeries | Reduction of Steroids | Fistula Response | Patient-Reported Outcomes
Infliximab (maintenance vs. episodic therapy) | Maintenance therapy favored; Low | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient
Mesalamine vs. placebo | Neither drug favored; Low | Insufficient | Insufficient | Neither drug favored; Low | Insufficient | Insufficient | Insufficient

Note: We defined the strength of the evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Mod = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

We graded all other comparisons and outcomes as insufficient since there were no eligible studies.

#### Study Design and Population Characteristics

Two RCTs compared the effectiveness of therapies alone or in combination to maintain remission in children with Crohn's disease (Appendix D, Evidence Tables 22 and 23).194,195 One study evaluated mesalamine versus placebo,194 while another compared infliximab maintenance therapy versus episodic (or on-demand) therapy.195

One study, examining mesalamine versus placebo, took place in Europe at multiple centers; the length of follow-up was 1 year.194 This RCT included 122 pediatric patients (18 years and younger) diagnosed with Crohn's disease before the age of 16 years. The mean age was 11.8 years. Seventy-three of 122 children (58 percent) were male. The mean disease duration was 0.8 years. Only children with active Crohn's disease were eligible (defined as HBI score greater than or equal to 5 or erythrocyte sedimentation rate (ESR) greater than or equal to 25 mm at 1 hour). The mean baseline HBI was 0.8, indicating that the study included the majority of children, based on ESR value. All disease activity levels were included in this study. However, the study excluded children if they had documented previous use of thiopurines or methotrexate. Disease locations were 12 percent ileal, 69 percent ileocolonic, and 19 percent colonic. Combining all disease locations, 32 percent of children also had perianal involvement. The study did not report smoking status, age at diagnosis, race, disease behavior, baseline IBDQ score, or CRP level.

One open-label randomized study, examining different strategies of infliximab, took place in Europe at multiple centers; the length of follow-up was 1 year.195 The study population included 40 patients enrolled between 2002 and 2005. The study included patients if they were between 7-17 years of age with moderate-to-severe Crohn's disease, based on HBI greater than or equal to 5 and an ESR of greater than 20 mm/hour. Patients had to have prior resistance to thiopurines or methotrexate, as well as corticosteroids. The study prohibited prior anti-TNF use. All patients received induction dosing of infliximab 5 mg/kg intravenous at 0, 2, and 6 weeks. The study randomized those who achieved remission by week eight to receive maintenance infliximab at 5 mg/kg every 8 weeks (Group A), or episodic (or on-demand) infliximab for patients who relapsed (Group B). The study defined remission as an HBI less than 5, ESR less than 20 mm/h, fistula closure [where applicable], and weaning completely from steroids. It defined relapse as an HBI greater than or equal to 5 and incomplete fistula closure.

The mean age at diagnosis was 13.9, and mean duration of disease was 3.0 years. Twenty-two patients (55 percent) were male. Twenty-seven patients had nonstricturing, nonpenetrating disease, while 13 had penetrating disease. At inclusion, all but four patients were on steroids, 37 were on a thiopurine, and three were on methotrexate. Baseline HBI was 7.6. A total of 34 patients went into clinical remission after induction dosing, and the study randomized 31 to maintenance, versus on-demand therapy. The study did not provide baseline characteristics for the randomized patients.

#### Disease Activity Measures

##### Infliximab Maintenance Versus Episodic Therapy

One RCT195 examined clinical relapse at 50 weeks after randomization. The rate of remission at 50 weeks was 83 percent in the maintenance group and 61 percent in the episodic group (P < 0.001). The rate of relapse over the course of the study was three of 13 (23 percent) and 11 of 12 (92 percent), respectively (not intention-to-treat analysis). Notably, almost all patients in the episodic arm received infliximab at some point during the study (mean of 3.4 infusions compared to six infusions in the maintenance arm), although at a later point in time (mean of 150 days after randomization).

##### Mesalamine Versus Placebo

One RCT194 examined clinical relapse at 1 year (defined as HBI score of greater than or equal to 5) in 122 pediatric patients with active Crohn's disease. The study randomized the patients after induction treatment (Appendix D, Evidence Table 24). The difference in relapse was not meaningful between children receiving 50 mg/kg per day of mesalamine and children receiving placebo. The 1-year relapse rate was 34 of 60 children (57 percent) receiving mesalamine, and 39 of 62 children (63 percent) receiving placebo. The average time without relapse was 8.6 months in the mesalamine group and 7.9 months in the placebo group, and was not clinically or statistically different between the two groups.

#### Mucosal Healing

Neither study looked at mucosal healing as an outcome of interest.

#### Hospitalizations

Neither study looked at hospitalizations as an outcome of interest.

#### Surgeries

##### Mesalamine Versus Placebo

One RCT194 examined surgery for acute complications as an outcome of interest. At 1 year, the study reported no surgeries for children in either the 1 mg/kg per day mesalamine treatment group or the placebo group.

#### Reduction of Steroids

Neither study looked at reduction of steroids as an outcome of interest.

#### Fistula Response

Neither study looked at fistula response as an outcome of interest.

#### Patient-Reported Outcomes

Neither study looked at patient-reported outcomes as an outcome of interest.

#### Study Quality

The overall quality of one RCT194 was fair (Appendix D, Evidence Table 25). The study had adequate allocation sequence and concealment and adequate blinding, but the completeness of outcome data was unclear. The authors reported no conflict of interest.

The overall quality of one RCT195 was poor. The study had adequate allocation sequence, but there was no blinding built into the study and outcome data was unclear with regard to relapse rates. The authors reported their conflicts of interest.

### Key Question 3 Safety of Therapies in Children

#### Key Points

##### Mortality, Lymphoma, Other Cancers, Tuberculosis, Infusion- and Injection-Site Reactions, and Bone Fractures

- We found insufficient evidence to determine the comparative safety of therapies alone or in combination in children with Crohn's disease. We did not find any studies reporting on mortality, lymphoma or other cancers, tuberculosis, infusion- and injection-site reactions, or bone fractures.

##### Serious Infections

- Infliximab maintenance therapy and episodic therapy did not differ in minimizing serious infections at 1 year in children with Crohn's disease (no events reported). (SOE: Low)
- Placebo was safer than 6-mercaptopurine in minimizing serious infections at 18 months in children with Crohn's disease (RR, 3.1; 95% CI, 0.1 to 73.1). (SOE: Low)
- We found insufficient evidence to determine the comparative safety of other therapies alone or in combination to minimize serious infections in children with Crohn's disease. We found no studies evaluating other biologics, azathioprine, methotrexate, corticosteroids, or aminosalicylates in terms of serious infections among children with Crohn's disease.

##### Other Infections

- Infliximab maintenance therapy and episodic therapy did not differ in minimizing other infections at 1 year in children with Crohn's disease. (SOE: Low).
- Budesonide was safer than prednisone in minimizing other infections at week eight in children with Crohn's disease (RR, 0.2; 95% CI 0.01 to 3.8). (SOE: Low)
- Budesonide and mesalamine combination therapy was safer than prednisone and mesalamine combination therapy in minimizing other infections at week 12 in children with Crohn's disease (RR, 0.3; 95% CI, 0.01 to 5.7). (SOE: Low)
- Prednisolone was safer than budesonide in minimizing other infections in children with Crohn's disease (RR, 2.4; 95% CI 0.2 to 24.4). (SOE: Moderate)
- We found insufficient evidence to determine the comparative safety of other therapies alone or in combination to minimize other infections in children with Crohn's disease.
- We did not find any studies evaluating other biologics, thiopurines, methotrexate, or aminosalicylates in children with Crohn's disease.

##### Height Change

- Maintenance infliximab was more effective than episodic infliximab in allowing growth at 1 year in children with Crohn's disease (z-score increased from -1.5 to -0.6 in the maintenance arm vs. -1.4 to -1.0 in the episodic arm). (SOE: Low)
- 6-mercaptopurine and placebo did not differ at 6, 12, and 18 months in allowing growth in children with Crohn's disease (6.8 cm vs. 5.3 cm after 18 months, respectively, P=0.3). (SOE: Low)
- Prednisone was more effective than placebo in allowing growth in children with Crohn's disease. (SOE: Low)
- Prednisone and budesonide did not differ in allowing growth at 6 months in children with Crohn's disease (change in height percentile, 0.25 vs. -2.35 for budesonide and prednisone, respectively; P=0.1). (SOE: Low)
- We found insufficient evidence to determine the comparative safety of other therapies alone or in combination to allow growth in children with Crohn's disease. We did not find any studies evaluating the effects of other biologics, azathioprine, methotrexate, or aminosalicylates in children with Crohn's disease.

##### Weight Change

- Maintenance infliximab was more effective than episodic infliximab in allowing weight gain at 1 year in children with Crohn's disease (weight gain, 4.3 kg vs. -0.1 kg; P < 0.001). (SOE: Low)
- Infliximab was more effective than placebo in allowing weight gain in children with Crohn's disease (fat mass to height z-score beta-coefficient, 0.29; 95% CI, 0.06 to 0.52). (SOE: Low)
- Methotrexate was more effective than placebo in allowing weight gain in children with Crohn's disease (fat mass to height z-score beta-coefficient, 0.30; 95% CI, 0.04 to 0.56). (SOE: Low)
- Prednisone was more effective than placebo in allowing weight gain in children with Crohn's disease (fat mass to height z-score beta-coefficient, 0.69; 95% CI, 0.12 to 1.26). (SOE: Low)
- Prednisone was more effective than budesonide in allowing weight gain after 8 weeks in children with Crohn's disease (weight gain, 4.6 vs. 2.5 kg for prednisone and budesonide, respectively; P < 0.05). (SOE: Low)
- We found insufficient evidence to determine the comparative safety of other therapies alone or in combination to allow weight gain in children with Crohn's disease. We did not find any studies evaluating the effects of natalizumab, adalimumab, certolizumab pegol, thiopurines, or aminosalicylates on weight in children with Crohn's disease.

Table 59 summarizes the evidence grades and specific conclusions for each comparison. Details of the evidence grades are in Appendix D, Table 21.

Table 59 Key findings and strength of evidence comparing pharmacologic therapies for the management of children with Crohn's disease in terms of safety

Comparison | Mortality | Lymphoma, Cervical Cancer, and Other Cancers | Serious Infections | Tuberculosis | Other Infections | Infusion- and Injection-Site Reactions | Bone Fractures | Height Change | Weight Change
Infliximab vs. placebo | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Favors infliximab; Low
Infliximab (maintenance vs. episodic therapy) | Insufficient | Insufficient | Neither favored; Low | Insufficient | Neither favored; Low | Insufficient | Insufficient | Maintenance infliximab favored; Low | Maintenance infliximab favored; Low
6-Mercaptopurine and prednisone vs. prednisone alone | Insufficient | Insufficient | Neither drug combination favored; Low | Insufficient | Insufficient | Insufficient | Insufficient | Neither drug combination favored; Low | Insufficient
Methotrexate vs. placebo | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Favors methotrexate; Low
Prednisone vs. placebo | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient | Conflicting evidence; Low | Favors prednisone; Low
Budesonide vs. prednisone | Insufficient | Insufficient | Insufficient | Insufficient | Neither drug favored; Low | Insufficient | Insufficient | Neither drug favored; Low | Favors prednisone; Low
Budesonide and mesalamine vs. prednisone and mesalamine | Insufficient | Insufficient | Insufficient | Insufficient | Neither drug combination favored; Low | Insufficient | Insufficient | Insufficient | Insufficient
Budesonide vs. prednisolone | Insufficient | Insufficient | Insufficient | Insufficient | Neither drug favored; Mod | Insufficient | Insufficient | Insufficient | Insufficient

Note: We defined the strength of the evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Mod = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

We graded all other comparisons and outcomes as insufficient since there were no eligible studies.

#### Study Design and Population Characteristics

Nine studies compared the safety of therapies alone or in combination in children with Crohn's disease (Appendix D, Evidence Tables 22 and 23). Four studies were RCTs.190-192,195 Two studies were prospective cohort studies,196,197 and three studies were retrospective cohort studies.198-200 One of the RCTs had a run-in period where both arms received induction infliximab; none of the RCTs were crossover studies. The studies took place in various countries (two in the United States, one in Canada, four in Europe, and two in Israel), and five studies were multi-centered trials.190-192,195,198 The length of followup ranged from 8 weeks to 43 months.

The nine studies included pediatric patients exclusively, totaling 573 children. The mean age of children ranged from 12.7 to 13.9 years in seven studies (351 children).190-192,195,196,198,199 The mean disease duration ranged from 0.6 to 3.0 years in three studies (166 children).190,195,199 All nine studies reported the percent of male patients, which ranged from 33 to 100 percent. Two studies reported race; 51 of 55 children (93 percent) were white in one study,192 and eight of 78 children (10 percent) were black in another study.199 Two studies (72 children) reported the mean age at diagnosis, which ranged from 7.0 to 13.9 years.196,197

Five studies reported Crohn's disease characteristics as disease location, severity, and baseline disease activity.190,192,197,199,200 The studies reported disease location for 333 children as follows: 14 percent (range: 3 to 42 percent) had ileal disease, 71 percent (range: 21 to 84 percent) had ileocolonic disease, 12 percent (range: 6 to 16 percent) had colonic disease, and 8 percent (range: 0 to 36 percent) had perianal disease. One study reported disease behavior; 27 patients had nonstricturing, nonpenetrating disease, while 13 had penetrating disease.195 Seven studies reported disease severity190-192,195,197-199 for 337 children as follows: 11 percent (range: 0 to 83 percent) had mild disease, 50 percent (range: 0 to 100 percent) had mild-to-moderate disease, less than 1 percent (range: 0 to 6 percent) had moderate disease, 37 percent (range: 0 to 100 percent) had moderate-to-severe disease, and less than 1 percent (range: 0 to 12 percent) had severe disease. Five studies reported a mean baseline PCDAI score ranging from 27.6 to 45.7^190-192,198,199^ for 334 children. One study reported the mean baseline CDAI was 255 for 48 children.190 Two studies reported the mean baseline HBI score was 7.5-7.6, in 95 children.192,195 None of these studies reported on smoking status, baseline IBDQ score, or CRP level.

The inclusion criteria were mostly the same among the studies except in regards to disease severity. All studies included mostly children, with a maximum age of 22 years. Five studies used Crohn's disease severity for inclusion;190,192,195,198,201 the studies determined severity using physician assessment, PCDAI, CDAI, and HBI. Eight studies included only children with Crohn's disease; one study included children with inflammatory bowel disease.197 One study excluded girls;196 all others included both sexes.

Three studies, examining 6-mercaptopurine and prednisone192 and corticosteroids,190,191 excluded children who had previously used thiopurines. Two studies, measuring growth,199,200 excluded children who had an illness or were taking any other medications that could affect growth or development.

#### Mortality

No studies meeting our inclusion criteria reported on the outcome of mortality in children with Crohn's disease.

#### Cancer

No studies meeting our inclusion criteria reported on cancer rates in children with Crohn's disease.

#### Serious Infections

##### Infliximab Maintenance Versus Episodic Therapy

One RCT of 40 children reported on serious infections.195 Over the course of 1 year, none of the children in either arm developed a serious infection.

##### Combination of 6-Mercaptopurine and Prednisone Versus Prednisone Alone

One RCT of 55 children reported on serious infections (Table 60; Appendix D, Evidence Table 24).192 Over the course of the 18-month study, one of 27 children, receiving 1.5 mg/kg per day of 6-mercaptopurine and prednisone taper, developed an intra-abdominal abscess. None of 28 children receiving a prednisone taper alone developed a serious infection.

Table 60 Summary of the evidence comparing pharmacologic therapies for the management of children with Crohn's disease in terms of serious infections

Comparison | Type of Infection | Type of Studies | Number of Studies | Results | Conclusions | Strength of Evidence
Infliximab (maintenance vs. episodic therapy) | Serious infection | RCT | 1 | 0/18 maintenance 0/13 episodic | Neither favored | Low
6-Mercaptopurine and prednisone vs. prednisone alone | Intra-abdominal abscess | Randomized controlled trial | 1 | 1/27 6-mercaptopurine 0/28 placebo | Neither favored | Low

RCT = randomized controlled trial

Note: We defined the strength of the evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Mod = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

#### Tuberculosis

No studies meeting our inclusion criteria reported on tuberculosis rates in children with Crohn's disease.

#### Other Infections

Four studies of 241 children with Crohn's disease190,191,195,198 reported other infections during the course of their study (Table 61; Appendix D, Evidence Table 24). All but one study195 compared some combination of corticosteroids. Two studies191,198 of 153 patients reported herpetic infections, all three of which occurred only in patients taking prednisone; none occurred in patients taking budesonide. One study190 on pharyngitis (48 patients) reported that two cases of pharyngitis in 22 patients in the budesonide treatment group, and one case in 26 patients in the prednisone treatment group.

Table 61 Summary of the evidence comparing pharmacologic therapies for the management of children with Crohn's disease in terms of other infections

Comparison | Type of Infection | Type of Studies | Number of Studies | Results | Conclusions | Strength of Evidence
Budesonide vs. prednisolone | Pharyngitis | RCT | 1^190^ | 2/22 budesonide 1/26 prednisone | Not statistically significant | Moderate
Budesonide vs. prednisone | Herpetic infection | Retrospective cohort study | 1^198^ | 0/62 budesonide 2/58 prednisone | Neither favored | Low
Combination budesonide + mesalamine vs. combination prednisone + mesalamine | Herpetic infection | RCT | 1^191^ | 0/19 budesonide + mesalamine 1/14 prednisone + mesalamine | Neither favored | Low

RCT = randomized controlled trial

Note: We defined the strength of the evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Mod = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

##### Infliximab Maintenance Versus Episodic Therapy

One study195 of 40 pediatric patients reported that there was no difference in infections (viral upper airway infections, gastroenteritis, herpes simplex lip infection, axillary bacterial abscess) between maintenance versus episodic therapy groups. They study did not provide a breakdown by treatment group.

##### Budesonide Versus Prednisolone

One RCT190 of 48 pediatric patients with mild-to-moderate Crohn's disease, treated children with either budesonide or prednisolone. Over the 8-week course of the study, one of the 26 children in the 1 mg/kg per day prednisolone taper treatment group developed pharyngitis, compared with two of the 22 children in the 9 mg per day budesonide taper treatment group.

##### Budesonide Versus Prednisone

One retrospective cohort study198 of 120 pediatric patients with mild-to-moderate Crohn's disease, reviewed records of patients treated with either prednisone or budesonide. The study found two of the 58 children in the prednisone treatment group developed herpetic infections, compared with zero of the 62 children in the budesonide treatment group. There was no difference in herpetic infection rates between the two groups.

##### Combination of Budesonide and Mesalamine Versus the Combination of Prednisone and Mesalamine

One RCT,191 of 33 pediatric patients with mild-to-moderate Crohn's disease, treated children with either 3 to 4 g per day of mesalamine and a 40 mg-per-day prednisone taper, or 3 to 4 g per day of mesalamine and a 9 mg-per-day budesonide taper. Over the 12-week course of the study, one of 14 children in the mesalamine and prednisone treatment group developed a herpetic infection, compared with zero of 19 children in the mesalamine and budesonide treatment group. There was no difference in herpetic infection rates between the two groups.

#### Infusion- and Injection-Site Reactions

No studies meeting our inclusion criteria reported infusion- or injection-site reactions in children with Crohn's disease.

#### Bone Fractures

No studies meeting our inclusion criteria reported bone fractures in children with Crohn's disease.

#### Height Change

Seven studies of 492 children reported on the effects on height (Table 62; Appendix D, Evidence Table 24).

Table 62 Summary of the evidence comparing pharmacologic therapies for the management of children with Crohn's disease in terms of height change

Comparison | Height Measure | Type of Studies | Number of Studies | Results | Conclusions | Strength of Evidence
Infliximab (maintenance vs. episodic therapy) | Height z-score | RCT | 1^195^ | +0.9 maintenance +0.4 episodic | P < 0.001 | Low
Infliximab (maintenance vs. episodic therapy) | Linear growth (cm) | RCT | 1^195^ | 6.9 maintenance 4.3 episodic | P < 0.015 | Low
6-Mercaptopurine vs. placebo | Linear growth (cm) | Randomized controlled trial | 1^192^ | 6.8 6-mercaptopurine 5.3 placebo | P=0.3 | Low
Prednisone vs. placebo | Linear growth over 2 years (cm) | Prospective cohort study | 1^196^ | 9.1 prednisone 10.3 placebo | NR | Low
Prednisone vs. placebo | Height (cm) | Retrospective cohort study | 1^200^ | NR | P=0.005 | Low
Prednisone vs. placebo | HSDS | Prospective cohort study | 1^197^ | +0.00 prednisone +0.13 placebo | No difference | Low
Prednisone vs. placebo | HVSDS | Prospective cohort study | 1^197^ | +0.78 prednisone +1.25 placebo | No difference | Low
Corticosteroids vs. placebo | Height z-score | Retrospective cohort study | 1^199^ | Beta-coefficient = -0.63; 95% CI, -1.00 to -0.28 | P=0.0005 | Low
Budesonide vs. prednisone | Change in height percentile | Retrospective cohort study | 1^198^ | +0.25 budesonide -2.35 prednisone | P=0.1 | Low

cm = centimeter; HSDS = height standard deviation score; HVSDS = height velocity standard deviation score; NR = not reported

Note: We defined the strength of the evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Mod = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

##### Infliximab Maintenance Versus Episodic Therapy

One RCT of 40 children,195 comparing z-score for height and absolute height gain, randomized patients who went into remission after induction infliximab to receive maintenance dosing of infliximab versus episodic dosing for patients who relapse. The study followed patients for 50 weeks after randomization. Patients in the maintenance arm improved their z-score from -1.5 to -0.6, compared with an improvement from -1.4 to -1.0 in the episodic therapy group (P < 0.001). Absolute height gain was 6.9 and 4.3 cm, respectively.

##### Combination of 6-Mercaptopurine and Prednisone Versus Prednisone Alone

One RCT of 55 children192 compared the linear growth of children treated with 1.5 mg/kg per day of 6-mercaptopurine and prednisone taper versus those who were treated with a prednisone taper alone. This study found no significant difference in linear growth between the two groups at 6, 12, or 18 months. From 0 to 6 months, the 6-mercaptopurine group (n=26) grew an average of 3.4 cm, and the placebo group (n=25) grew an average of 1.9 cm (P=0.06). From 6 to 12 months, the 6-mercaptopurine group (n=23) grew an average of 0.7 cm, and the placebo group (n=24) grew an average of 1.3 cm (P=0.4). From 12 to 18 months, the 6-mercaptopurine group (n=23) grew an average of 2.8 cm, and the placebo group (n=24) grew an average of 2.3 cm (P=0.5). Overall, from 0 to 18 months, the 6-mercaptopurine group (n=23) grew an average of 6.8 cm, and the placebo group (n=24) grew an average of 5.3 cm (P=0.3).

##### Prednisone Versus Placebo

Four studies196,197,199,200 of 277 children found mixed results when comparing the effect of prednisone versus placebo on linear growth in children. One study found children who had taken prednisone were shorter than those who had not taken prednisone, one study found that children who had taken prednisone were taller than those who had not taken prednisone, and two studies found no difference in height between children who had taken prednisone and those who had not.

One prospective cohort study of 17 children196 compared the linear growth of nine boys with Crohn's disease who were treated with alternate day prednisone (0.3 mg per kg) for longer than 3 months, with eight boys with Crohn's disease who had not been treated with alternate day prednisone for longer than 3 months. At the end of 2 years, both groups showed similar linear growth.

One retrospective cohort study200 looked at 135 children with an early onset of Crohn's disease. This study asked adults about their growth and medication use (men with onset of symptoms before age 22 years, and women with onset of symptoms before age 18 years). Eight children had received corticosteroids before puberty and 19 children had received corticosteroids during puberty. Children who had received corticosteroids during puberty were significantly shorter than those who had not (P=0.005). This study also found that children with disease onset during puberty who had received corticosteroids were significantly shorter than those with disease onset during puberty that had not received corticosteroids (P=0.03).

One prospective cohort study197 looked at 47 pediatric patients with either Crohn's disease (n=18) or ulcerative colitis (n=29). This study found no significant difference in height standard deviation score (HSDS) or the height velocity standard deviation score (HVSDS) between those children who had received prednisone, compared with those children who had not received prednisone. The HSDS for children treated with prednisone was -0.50 at diagnosis, -0.47 after 1 year, -0.24 after 2 years, -0.10 after 3 years, and +0.00 after 4 years. The HSDS for children not treated with prednisone was -0.20 at diagnosis, -0.31 after 1 year, -0.13 after 2 years, -0.09 after 3 years, and +0.13 after 4 years. The HVSDS for children treated with prednisone was -1.20 at diagnosis, +0.29 after 1 year, +0.87 after 2 years, +1.47 after 3 years, and +0.78 after 4 years. The HVSDS for children not treated with prednisone was -0.01 at diagnosis, -0.26 after 1 year, +0.63 after 2 years, +0.16 after 3 years, and +1.25 after 4 years.

One prospective cohort study199 looked at 78 patients (ages 5 to 21 years) with Crohn's disease of varied severity and reported on height. This study performed a subgroup analysis on the 46 children who had completed four study visits, and found that children who had taken corticosteroids had a significantly lower height z-score than children who had not taken corticosteroids.

##### Budesonide Versus Prednisone

One retrospective cohort study198 compared the post-remission linear growth of 41 of 120 children whose records included height measures. The children had mild-to-moderate Crohn's disease and had received either prednisone or budesonide for at least 2 weeks. This study found no significant difference in the change of height percentile at 6 months between those children who had taken prednisone, compared with those children who had taken budesonide.

#### Weight Change

Two studies198,199 of 198 children reported on the outcome of weight (Table 63; Appendix D, Evidence Table 24).

Table 63 Summary of the evidence comparing pharmacologic therapies for the management of children with Crohn's disease in terms of weight change

Comparison | Weight Measure | Type of Studies | Number of Studies | Results | Conclusions | Strength of Evidence
Infliximab vs. placebo | Lean mass – height z-score | Case-control study | 1^199^ | Beta-coefficient, 0.30; 95% CI, 0.02 to 0.58 | P < 0.05 | Low
Infliximab vs. placebo | Fat mass – height z-score | Case-control study | 1^199^ | Beta-coefficient, 0.29; 95% CI, 0.06 to 0.52 | P < 0.05 | Low
Infliximab (maintenance vs. episodic therapy) | Weight gain (kg) | RCT | 1^195^ | 4.3 maintenance -0.1 episodic | P < 0.05 | Low
Methotrexate vs. placebo | Fat mass – height z-score | Case-control study | 1^199^ | Beta-coefficient, 0.30; 95% CI, 0.04 to 0.56 | P < 0.05 | Low
Corticosteroids vs. placebo | Fat mass – height z-score | Case-control study | 1^199^ | Beta-coefficient, 0.69; 95% CI, 0.12 to 1.26 | P < 0.05 | Low
Budesonide vs. prednisone | Weight gain (kg) | Retrospective cohort study | 1^198^ | +2.54 kg budesonide +4.6 kg prednisone | P < 0.05 | Low

CI = confidence interval; kg = kilogram; RCT = randomized controlled trial

Note: We defined the strength of the evidence as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Mod = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable.

##### Infliximab Versus Placebo

One prospective cohort study of 78 children with Crohn's disease of varied severity199 reported on the interaction of body mass and height. This study performed a subgroup analysis on the 46 children who had completed four study visits, and found that children who had taken infliximab had a significantly higher lean mass–height z-score than children who had not taken infliximab. This study also found that children who had taken infliximab had a significantly higher fat mass–height z-score than children who had not taken infliximab.

##### Infliximab Maintenance Versus Episodic Therapy

One RCT of 40 children,195 comparing absolute weight gain, randomized patients who went into remission after induction infliximab to receive maintenance dosing of infliximab versus episodic dosing for patients who relapsed. Patients were followed for 50 weeks after randomization. Patients in the maintenance arm had an absolute mean weight gain of 4.3 +/- 5.4 kg, compared to -0.1 +/- 5.7 kg in the episodic therapy group (P < 0.001).

##### Methotrexate Versus Placebo

The above cohort study199 also reported that children who had taken methotrexate had a significantly higher fat mass–height z-score than children who had not taken methotrexate.

##### Corticosteroids Versus Placebo

The above cohort study199 also reported that children who had taken corticosteroids had a significantly higher fat mass–height z score than those who had not taken corticosteroids.

##### Budesonide Versus Prednisone

One retrospective cohort study of 120 children198 looked at pediatric patients with mild-to-moderate Crohn's disease. This study looked at weight loss or gain in children who had received treatment with either prednisone or budesonide. After reviewing patient records, they found that those children who had received prednisone gained significantly more weight than those children who had received budesonide after 8 weeks.

#### Study Quality

For serious infections (intra-abdominal abscess), the quality of the one RCT192 was good due to adequate allocation sequence and concealment, adequate blinding, and complete outcome data (Appendix D, Evidence Table 25). A pharmaceutical company supported this study.192

For other infections (herpetic infections), the quality of one RCT191 was poor because the allocation sequence and concealment, blinding technique, and completeness of outcome data were unclear. The quality of the retrospective cohort study198 was fair due to good descriptions of outcomes, interventions, and patient characteristics.

For other infections (pharyngitis), the quality of one study202 was good due to adequate allocation sequence and concealment, adequate blinding, and complete outcome data.

For height change, seven studies192,195-200 had variable quality. The quality of one RCT192 was good due to adequate allocation sequence and concealment, adequate blinding, and complete outcome data. One RCT195 had poor quality because of absence of blinding. Two cohort studies198,199 had fair quality due to good descriptions of outcomes and patient characteristics. Two other cohort studies196,200 had poor quality due to study population selection bias. A pharmaceutical company supported one study.192

For weight change, two cohort studies198,199 had fair quality with good descriptions of outcomes and patient characteristics. The one RCT195 had poor quality because of absence of blinding.