# Methods

A patient with Crohn's disease nominated this topic because she was frustrated by the lack of consensus among physicians about her treatment options after surgical resection. Her experience reflects the general lack of consensus about pharmacologic therapies for the management of Crohn's disease. Our Evidence-based Practice Center established a team and a work plan to develop this evidence report. The project involved recruiting Key Informants and technical experts, formulating and refining the Key Questions (KQs), performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence, and submitting the report for peer review and public comment.

## Topic Development

At the beginning of the project, we recruited a panel of Key Informants to give input on the selection and refinement of the KQs. The Key Informants included a patient with Crohn's disease, clinician-investigators having experience in research on treatment of Crohn's disease, and a pharmaceutical company representative. Our draft KQs appeared on the Agency for Healthcare Research and Quality (AHRQ) Web site for public comment in March 2010.

Assessing input from Key Informants, representatives of AHRQ, and public comments, we developed the KQs that we listed in the Scope and Key Questions section of the Introduction. The final KQs focus on the comparative effectiveness and safety of individual and combined therapies for Crohn's disease (including biologics, immunomodulators, corticosteroids, and aminosalicylates) in terms of: (1) induction of remission, (2) maintenance of remission, (3) adverse effects, and (4) patient-reported outcomes after surgical resection.

We drafted a protocol to address our KQs. We then recruited a panel of technical experts, which included the Key Informants, an epidemiologist, and a pediatric gastroenterologist. With input from the Technical Expert Panel and representatives from AHRQ, we finalized the protocol.

## Search Strategy

We searched the following databases for primary studies for the dates shown in parentheses: MEDLINE^®^ (1966 through June 2011), Embase^®^ (1974 through June 2011), and the Cochrane Central Register of Controlled Trials (Issue 2, 2011). We developed a search strategy for MEDLINE, accessed via PubMed, based on an analysis of the medical subject heading (MeSH) terms and text words of key articles identified a priori (Appendix A).

To identify additional studies, we reviewed the following material from the Evidence-based Practice Center's Program's Scientific Resource Center:

- Medical and/or statistical reviews of adalimumab, certolizumab pegol, infliximab, natalizumab, hydrocortisone, prednisone, prednisolone, and mesalamine from the Food and Drug Administration (FDA) Web site,
- Health Canada Product Monographs for adalimumab, certolizumab pegol, infliximab, natalizumab, azathioprine, 6-mercaptopurine, methotrexate, hydrocortisone, and 6-methylprednisolone,
- Public registries of clinical trials, including the Clinical Study Results Web site (www.clinicalstudyresults.org) and ClinicalTrials.gov (www.clinicaltrials.gov).

We also reviewed the reference lists of each included article and relevant review articles.

To assess the risk of two serious rare complications of treatment for Crohn's disease, hepatosplenic T-cell lymphoma and primary multifocal leukoencephalopathy, we supplemented the primary search strategy by also searching for cases reported to the FDA's Adverse Event Reporting System.

We downloaded the results of the searches and imported into ProCite^®^ version 5 (ISI ResearchSoft, Carlsbad, Calif.). We scanned for exact article duplicates, author/title duplicates, and title duplicates using the duplication check feature in ProCite^®^. From ProCite, we uploaded the articles to DistillerSR (Evidence Partners, Ottawa, Ontario, Canada), a Web-based software package developed for systematic review data management. We used this database to track the search results at the levels of title review, abstract review, article inclusion/exclusion, and data abstraction.

## Study Selection

Two independent reviewers conducted title scans. To eliminate the title at this level, both reviewers had to agree that it was ineligible (Appendix B, Title Review Form). If they disagreed, we promoted the article to the next level. We designed the title review to capture as many studies as possible that potentially reported on the efficacy or safety of therapies for the management of Crohn's disease.

Two investigators reviewed abstracts independently, and we excluded articles if both investigators agreed that the article met one or more of the exclusion criteria (see inclusion and exclusion criteria listed in Table 5 and the Abstract Review Form in Appendix B). We resolved differences between investigators regarding abstract inclusion or exclusion through consensus adjudication.

Table 5 Inclusion and exclusion criteria for identifying eligible studies

Category | Inclusion Criteria | Exclusion Criteria
Population and condition | - Included studies of human subjects of all ages with Crohn's disease; - Sensitivity analysis for KQ3 included patients with any inflammatory bowel disease | - Excluded studies if they included only pregnant women
Interventions | - Included studies evaluating a Crohn's disease medication of interest (see Table 1) or combination of medications of interest compared with each other or with placebo
Comparisons | - Included studies that had a comparison group, where the comparison was either a medication or combination of medications of interest or placebo | - Excluded studies that compared a medication of interest to a medication not of interest (such as antibiotics or fish oil supplements); - Excluded studies that only evaluated the same medication given at different times or at different doses
Outcomes | - Included the following outcomes for KQ1 and KQ2: Crohn's Disease Activity Index (CDAI), mucosal healing, hospitalizations, surgery, corticosteroid reduction, fistula response, and patient-reported outcomes representing quality of life; - Included the following harms of medications for KQ3: mortality, lymphomas, cervical cancer, other cancers, tuberculosis, serious infections, other infections, infusion and injection-site reactions, bone fractures, and, in children, height and weight as indicators of growth; - Included the following patient-reported outcomes for KQ4: generic and disease-specific quality of life indices (e.g., IBDQ), and days of work or school missed | - Excluded studies that did not apply to the KQs
Type of study | - Included studies with any sample size from any year that met all other criteria; - Included only RCTS for KQ1 and KQ2; - Included all study designs with a comparison group, for KQ3 and KQ4, including: RCTs, prospective and retrospective cohorts, crossover studies, case-control studies and cross-sectional studies; - Included all study types (including case reports) for hepatosplenic T-cell lymphoma and progressive multifocal leukoencephalopathy because these outcomes are very rare and frequently fatal | - Excluded articles not written in English, articles with no original data (reviews, editorials, comments, letters), and abstract-only publications

IBDQ = Inflammatory Bowel Disease Questionnaire; KQ = Key Question; RCT = randomized controlled trial

When reviewers promoted articles on the basis of abstract review, additional independent investigators determined if they should be included for data abstraction (Appendix B, Article Review Form). We resolved differences regarding article inclusion through consensus adjudication. A third reviewer audited a random sample of abstract and article reviews to ensure consistency in the reviewing process.

To evaluate induction and maintenance of remission (KQ1 and KQ2), we included only randomized controlled trials (RCTs). Both placebo-controlled and head-to-head trials were eligible. We did not include trials that only examined the same medication administered at different time points or at different dosages. We chose clinically important and patient-centered outcomes of interest for KQ1 and KQ2.

To evaluate the safety of treatment (KQ3), we included RCTs and observational studies. We chose specific safety outcomes based on the severity of the outcome, impact on quality of life, and potential for safety to differ by medication class. We selected clinical outcomes a priori for inclusion. All RCTs that reported on safety were eligible. Observational studies were eligible if they reported a relevant comparison group with clear numerators and denominators for each group or an effect estimate or p-value for a safety outcome by medication use. Because of the rarity and severity of hepatosplenic T-cell lymphoma and progressive multifocal leukoencephalopathy, we included all study types (including case reports) for these outcomes.

A rigorously conducted systematic review19 had recently assessed the efficacy and safety of medications to maintain remission of Crohn's disease after intestinal resection. Instead of duplicating that work, we limited the focus of KQ4 to the comparative effects of medications on patient-reported outcomes as reported in RCTs and observational studies. The previous review did not include these outcomes.

## Data Abstraction

We used a systematic approach for extracting data to minimize the risk of bias in this process. We created and pilot tested standardized forms for data extraction. By creating standardized forms for data extraction, we sought to maximize consistency in identifying all pertinent data available for synthesis.

For all articles, reviewers extracted information on general study characteristics (e.g., study design, study period, and followup), study participants (e.g., age, sex, race/ethnicity, duration of Crohn's disease, smoking status, disease severity, and disease location), eligibility criteria, interventions (e.g., route of administration and dosing), outcome measures and the method of ascertainment, and the results of each outcome (including measures of variability).

For KQ1, KQ2, and KQ4, we abstracted data on the following time points: (1) first time point after randomization or study start; (2) 12 to 16 weeks after randomization or study start; (3) 48 to 54 weeks after randomization or study start; and (4) last prespecified time point. For KQ3, we abstracted data for the last reported time point only.

We abstracted information on subgroup analyses to understand how disease characteristics could modify the relationship between medications and remission. We considered the following characteristics for subgroup analyses a priori because these characteristics are most clinically relevant: elevated baseline markers of inflammation (including C-reactive protein rates), baseline mucosal lesions, medications used at randomization (baseline), prior medication exposure, disease duration, disease location, and prior Crohn's disease-related surgery. We only reported on studies that performed and reported a statistical test for interaction.

Study investigators double reviewed each article for data abstraction. We abstracted all information into the DistillerSR database (Evidence Partners, Ottawa, Canada). The second reviewer confirmed the first reviewer's data abstraction within DistillerSR for completeness and accuracy. We formed reviewer pairs to include personnel with both clinical and methodological expertise. Reviewers abstracted relevant data from figures when they were not available in text or table format. Reviewers entered comments into the system whenever applicable. We used the DistillerSR database to maintain the data, as well as to generate Excel files, which we used to create detailed evidence tables and summary tables.

## Quality Assessment

We used study quality assessment to help us understand differences in results between studies. We used different quality assessment tools for RCTs and observational studies. For RCTs, we based the dual independent review of article quality on the Cochrane Collaboration's Risk of Bias Tool20 and supplemented with items from the Evidence-based Practice Center Program's “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”21 The quality assessment for RCTs included items on: (1) adequate allocation sequence generation, (2) adequate allocation concealment, (3) blinding, (4) incomplete outcome data, (5) other potential threats to validity, (6) pharmaceutical support, (7) company involvement in the design, conduct, or reporting of the study, (8) loss to followup, and (9) an overall rating of the quality assessment. We assessed the overall study quality in the following manner:

- Good (low risk of bias). These studies had the least bias, and we considered the results valid. These studies adhered to the commonly held concepts of high quality, including the following: a clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
- Fair. These studies were susceptible to some bias, but not enough to invalidate the results. They did not meet all the criteria required for a rating of good quality because they had some deficiencies, but no flaw was likely to cause major bias. The study may have been missing information, making it difficult to assess limitations and potential problems.
- Poor (high risk of bias). These studies had significant flaws that might have invalidated the results. They had serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.21

For observational studies, we selected quality concepts from the Downs and Black quality checklist22 and added items from the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”21 We assessed observational studies based on the following criteria: (1) clear description of main outcome to be measured, (2) clear description of patient characteristics, (3) clear description of interventions of interest, (4) clear description of the distributions of principal confounders, (5) recruitment of the different intervention groups from the same population, (6) handling of loss to followup, (7) adequate adjustment for confounding, (8) pharmaceutical support, (9) company involvement in the design, conduct, or reporting of the study, and (10) overall study quality. We assessed the overall study quality as “good” if the responses for items 1 to 7 were all “yes”; “fair” if most of the responses to items 1 to 4 were “yes” and all of the responses to items 5 to 7 were “yes”; and “poor” if none of the responses to items 1 to 4 were “yes” or any of the responses to items 5 to 7 were “no” or “unable to determine.”

Reviewers resolved differences in study quality through consensus adjudication. We reported only the adjudicated quality scores.

## Applicability

Throughout the report, we discuss the applicability of the bodies of evidence in terms of the degree to which the study population (e.g., age, race, disease severity), interventions (e.g., dosing, frequency, duration), comparisons, outcomes, timings, and settings are typical of the treatment of individuals with Crohn's disease.

## Data Analysis and Synthesis

For each KQ, we created a set of detailed evidence tables containing all information abstracted from eligible studies. We conducted meta-analyses when there were sufficient data (at least three trials) and when studies were sufficiently homogenous with respect to the population characteristics, intervention, comparison, outcome, timing, and setting. When possible for KQ1 (induction of remission), we decided to conduct meta-analyses at the following clinically relevant time points:

- 2 to 4 weeks (using the earliest available time point)
- 12 to 16 weeks (using earliest available time point)
- Last reported time point

For KQ2 (maintenance of remission), we conducted meta-analyses at these time points:

- 48 to 54 weeks
- Last reported time point

For KQ3 (adverse effects), the meta-analyses used the last reported time point available from at least three studies.

For studies amenable to pooling with meta-analyses, we calculated pooled relative risks using a DerSimonian and Laird random effects model.23 We identified heterogeneity among the trials in all the meta-analyses using: (1) a chi-squared test with a significance level of alpha less than or equal to 0.10, and (2) an I-squared statistic with a value greater than 50 percent indicating substantial heterogeneity.24 We did not report the pooled result if we found substantial heterogeneity. We conducted sensitivity analyses by omitting one study at a time to assess the influence of any single study on the pooled estimate. For all meta-analyses, we conducted formal tests for publication bias using Begg's25 and Eggers tests,26 including an evaluation of the asymmetry of funnel plots for each comparison of interest. We conducted all meta-analyses using STATA (Intercooled, version 9.2, StataCorp, College Station, Texas).

When we were unable to pool trials for an outcome, we calculated and displayed risk ratios with 95 percent confidence intervals for the individual studies. For KQ1 and KQ2, we considered a difference to be clinically meaningful when there was an absolute difference of 10 percentage points in the outcome between the groups compared, even when the difference was not statistically significant (p-value less than 0.05). Similarly, we did not report statistically significant relationships unless there was a clinically meaningful difference. For the Crohn's Disease Endoscopic Index of Severity, we defined a clinically meaningful difference as an absolute difference in change from baseline of greater than 5 points.27 For the Inflammatory Bowel Disease Questionnaire (the most commonly employed outcome for patient-reported outcomes), we used an absolute difference in change from baseline of 17 points or greater.28 We considered a clinically significant reduction in corticosteroids to be a between-group difference of 10 mg in the average daily dose. Since there is no reference standard, we chose a 10 mg difference because it represents at least a 25 percent reduction in a typical steroid dose and patients are often tapered in 5 mg increments. In terms of adverse effects, when a study did not report an effect estimate, we calculated a Peto odds ratio if the combined number of events in each arm was greater than 5.^29,30^ We also calculated incidence rate ratios for person-time data when the authors did not report an effect estimate, or when the reported effect estimate appeared to contradict the reported events per person-time. We did not specify a standard for a clinically meaningful difference in the adverse events because the absolute rate was rare for most of the adverse events.

## Grading the Strength of Evidence

At the completion of our review, we graded the best available evidence addressing KQ1 through KQ4 by modifying the evidence grading scheme recommended by the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”31 We applied evidence grades to the bodies of evidence for each outcome of each intervention comparison by population (e.g., adult or pediatric). If necessary, we created separate evidence grades by time point.

We assessed the potential for bias by ranking study designs with RCTs higher than observational studies. We also evaluated the consistency, directness, and precision of the effects. We rated the body of evidence as “consistent” if most of the studies showed the same direction of effect. We rated the consistency of a single study as “unknown,” without downgrading the strength of evidence. We rated the body of evidence as “direct” if most studies directly measured the outcome of interest. We based our evaluation of precision on the clinically meaningful difference.

We classified the strength of evidence pertaining to KQ1 through KQ4 into four grades:

- “high” grade (indicating high confidence that the evidence reflects the true effect and further research is very unlikely to change our confidence in the estimate of the effect)
- “moderate” grade (indicating moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of the effect and may change the estimate)
- “low” grade (indicating low confidence that the evidence reflects the true effect and further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate)
- “insufficient” grade (evidence is unavailable; no studies observed)

We gave a high grade for strength of evidence to comparisons that included RCTs and a moderate grade to studies that did not include RCTs. For each domain (risk of bias, consistency, directness, precision, and other limitations) that was not optimal (moderate/high risk of bias, inconsistent, indirect, imprecise, or other limitations), we downgraded strength of evidence one level.

## Peer Review and Public Commentary

We invited experts in adult and pediatric gastroenterology and individuals representing stakeholder and user communities to provide external peer review of this comparative effectiveness review. AHRQ and an associate editor also provided comments. AHRQ posted the draft report on its Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a “disposition of comments report” that will be made available 3 months after AHRQ posts the final comparative effectiveness review on the AHRQ Web site.