# Introduction

## Background

### Description of Disease

Crohn's disease is a type of inflammatory bowel disease. Other types of inflammatory bowel disease include ulcerative colitis and indeterminate colitis. Current medical science defines Crohn's disease as chronic full thickness inflammation that can occur anywhere in the gastrointestinal tract, but most often affects the small bowel and colon. Typical symptoms of Crohn's disease include abdominal pain, chronic diarrhea, and gastrointestinal bleeding. Crohn's disease affects between 400,000 and 600,000 North Americans.1 Ten percent of Crohn's disease patients are children under the age of 17.^2^

Crohn's disease is an inappropriate immune response to intestinal microbes that is genetic in origin.3 Key symptoms include focal ulcerations or acute and chronic inflammation, detected through endoscopy and biopsy, respectively.

The activity of Crohn's disease fluctuates over time. One study estimated that during the first 7 years after diagnosis, 20 percent of Crohn's disease patients will have active disease at least once each year, 67 percent will fluctuate between years of active disease and years in remission, and 13 percent will have no relapses after the initial disease episode.4

Crohn's disease frequently leads to complications that require surgical intervention. One of the most common complications of Crohn's disease is fibrotic narrowing of the intestines (stricture), which can lead to obstruction, collections of pus in the abdomen or around the rectum (abscess), and spontaneous rupture of the bowel contents through the skin or other organs (fistula). In a study based on a cohort from Olmsted County, Minn., half of all patients had experienced at least one intestinal complication within 10 years of diagnosis.5 Two studies based on the same cohort reported that half of patients required at least one surgical resection within 10 years of diagnosis.5

### Interventions To Treat Crohn's Disease

Dr. Burrill Crohn's initial description of this disease suggested that it could be cured with wide surgical resection. Research has since proven this to be false.6 The current accepted treatment is to administer medications designed to stop the intestinal inflammation and prevent further complications. Physicians refer to patients who no longer have inflammation as being in remission. To maintain remission, patients must continue to use these drugs. However, in spite of the success of this form of treatment, some patients relapse with renewed disease activity and an increase of symptoms. We show these disease states in Figure 1.

Figure 1 Crohn's disease activity changes over time

Figure 1 depicts Crohn's disease activity over time. Crohn's disease activity can be described as no activity, mild activity, and severe-to-moderate activity. Remission is when there is no disease activity. Induction is when disease activity moves from severe-to-moderate to no disease activity. Relapse is when disease activity becomes severe-to-moderate after a period of remission.

There are four major classes of medications physicians have used to induce and maintain remission: biologics, immunomodulators, corticosteroids, and aminosalicylates. The aminosalicylate, sulfasalazine, and corticosteroids emerged in the mid-1900s. Immunomodulators (such as 6-mercaptopurine, azathioprine, and methotrexate) came out in the 1970s, although the use of these medications was not routine until the 1990s.7 The Food and Drug Administration (FDA) approved the first biologic tumor necrosis factor-alpha (TNF-alpha) inhibitor, infliximab, for Crohn's disease in 1998. Additional FDA-approved biologics include the TNF-alpha inhibitors adalimumab and certolizumab pegol, and the cellular adhesion molecule alpha-4 integrin inhibitor natalizumab.8

Table 1 summarizes the Crohn's disease medications (biologics, immunomodulators, corticosteroids, and aminosalicylates) their mechanisms of action, and FDA approval status. Table 2 summarizes the black box warnings for safety for these medications.

Table 1 List of medications used for treatment of Crohn's disease

Class | Generic Name | United States Trade Name | Route | Half-Life | Mechanism of Action | FDA Approved for CD in Adults | FDA Approved for CD in Children
Biologic | Adalimumab | Humira | Subcutaneous | 10-18 days | TNF-alpha inhibitor | Yes | No
Biologic | Certolizumab pegol | Cimzia | Subcutaneous | ∼14 days | TNF-alpha inhibitor | Yes | No
Biologic | Infliximab | Remicade | Intravenous | 7.7-9.5 days | TNF-alpha inhibitor | Yes | Yes
Biologic | Natalizumab | Tysabri | Intravenous | 7-15 days | Prevents attachment of inflammatory immune cells to intestinal cell layers | Yes | No
Immunomodulator | Azathioprine | Azasan; Imuran | Oral, intravenous | 5- hours | Purine synthesis inhibitor | No | No
Immunomodulator | 6-mercaptopurine | Purinethol | Oral | 1-2 hours | Purine synthesis inhibitor | No | No
Immunomodulator | Methotrexate | Methotrexate | Intravenous, oral | 3-15 hours | Dihydrofolate reductase inhibitor | No | No
Corticosteroid | Prednisone, prednisolone, 6-methylpredisolone, hydrocortisone, budesonide | Cortef, Entocort | Oral, topical, intravenous | 8-54 hours | Binds glucocorticoid receptors in cytoplasm, where it upregulates anti-inflammatory genes | No^*^ | No
Aminosalicylate | Mesalamine | Asacol, Canasa, Pentasa, Lialda, Rowasa | Oral, rectal | 2-15 hours | Unknown | No | No
Aminosalicylate | Sulfasalazine | Azulfidine | Oral | 5-10 hours | Unknown | No | No

CD = Crohn's disease; FDA = Food and Drug Administration; TNF = tumor necrosis factor; U.S. = United States

* Budesonide is approved by the Food and Drug Administration for mild to moderate Crohn's disease.

Table 2 Black box warnings listed on the prescribing information sheets of medications to treat Crohn's disease

Class | Generic Name | Boxed Warning
Biologic | Adalimumab | - Malignancies (lymphoma and other malignancies, some fatal); - Hepatosplenic T-cell lymphoma; - Serious infections (hospitalization, death, tuberculosis, bacterial sepsis, invasive fungal infections, opportunistic infections)
Biologic | Certolizumab pegol | - Malignancies (lymphoma and other malignancies, some fatal); - Serious infections (hospitalization, death, tuberculosis, bacterial sepsis, invasive fungal infections, opportunistic infections)
Biologic | Infliximab | - Malignancies (lymphoma and other malignancies, some fatal); - Hepatosplenic T-cell lymphoma; - Serious infections (hospitalization, death, tuberculosis, bacterial sepsis, invasive fungal infections, opportunistic infections)
Biologic | Natalizumab | - Progressive multifocal leukoencephalopathy
Immunomodulator | Azathioprine | - Malignancies (post-transplant lymphoma and hepatosplenic T-cell lymphoma)
Immunomodulator | Methotrexate | - Fetal death and/or congenital anomalies; - Reduced elimination in patients with impaired renal function, ascites, or pleural effusions; - Unexpectedly severe (sometimes fatal) bone marrow suppression, aplastic anemia, and gastrointestinal toxicity; - Hepatotoxicity, fibrosis, and cirrhosis; - Lung disease; - Diarrhea and ulcerative stomatitis; - Malignant lymphomas; - Tumor lysis syndrome; - Severe, occasionally fatal, skin reactions; - Potentially fatal opportunistic infections; - Soft tissue necrosis and osteonecrosis
Immunomodulator | 6-mercaptopurine | No black box warnings
Corticosteroid | Prednisone, prednisolone, 6-methylpredisolone, hydrocortisone, budesonide | No black box warnings
Aminosalicylate | Sulfasalazine | No black box warnings
Aminosalicylate | Mesalamine | No black box warnings

### Current Controversies in the Treatment of Crohn's Disease

One of the Institute of Medicine's priorities for comparative effectiveness research is to compare algorithms for Crohn's disease treatment that introduce biologics at different time points in the disease course.9 Another treatment that warrants study is the use of biologics in combination with immunomodulators. Some research has suggested that improved long-term outcomes result from using immunomodulators and biologics early (“top-down therapy”), as opposed to using them after a patient has undergone prolonged steroid therapy (“step-up therapy”) (Figure 2).10 Science needs to weigh the benefits of this early treatment approach against the risks of increased immunosuppression, including lymphoma,11 and the expense and harms of over-treating patients who will not receive an intestinal resection (40 percent) and patients who will not have aggressive, disabling disease (70 percent).1 The major challenge and focus of current research is to arrest the natural progression of disease while minimizing adverse events and interventions, such as surgeries.12

Figure 2 Treatment pyramid for patients with Crohn's disease

Figure 2 is the treatment diagram. It shows a triangle, with the four classes of medications going down. These medication classes from top to bottom are biologics, immunomodulators, corticosteroids, and aminosalicylates. Step-up therapy goes from the bottom of the triangle up. Top-down therapy goes from the top of the triangle down.

### Treatment Guidelines and Meta-Analyses on the Management of Crohn's Disease

When evidence-based research is sparse, treatment guidelines for the management of Crohn's disease often combine evidence-based medicine with expert panel review. In the United States, the American College of Gastroenterology, the American Gastroenterological Association, and the American Society of Colon and Rectal Surgeons publish management guidelines for Crohn's disease.8 13-18 The treatment guidelines point to controversial areas in need of future research including: treatments to achieve long-term remission; the benefits and harms of step-up versus top-down treatment strategies; and optimizing the use of biologic agents, given that other treatments are effective at managing disease for large number of patients. This report addresses these aims.

### Previous Systematic Reviews

Meta-analyses have compared individual medications with placebo but few have compared medications to each other. There are 43 high-quality meta-analyses for Crohn's disease that have compared biologics, immunomodulators, corticosteroids, and aminosalicylates with placebo. Eighteen of these are from the Cochrane Collaboration.

A recent high-quality meta-analysis of randomized control trials published through February 2009 examined the efficacy of treatments after surgical resection, but did not report on the quality of life effects.19 Few meta-analyses reported quality of life, although quality of life remains a high priority topic for patients.

The central question for patients and their caretakers is the comparison of medications to each other at relevant time points in the natural progression of disease. This report focuses on these questions and includes the comparison of combinations of medications.

## Scope of the Evidence Report and Key Questions

As displayed in Figure 3, the purpose of this review is to give clinicians a comprehensive comparison of the effectiveness and safety of biologics, immunomodulators, corticosteroids, and aminosalicylates in the treatment of Crohn's disease. The specific Key Questions (KQs) of interest are:

KQ1: What is the comparative effectiveness of therapies alone or in combination used to induce remission in adults and children with active Crohn's disease?

KQ2: What is the comparative effectiveness of therapies alone or in combination used to maintain remission in adults and children with inactive Crohn's disease?

KQ3: What is the comparative safety of therapies alone or in combination used in adults and children with Crohn's disease in terms of minimizing short- and long-term adverse effects?

KQ4: What is the comparative effectiveness of agents used to prevent post-operative recurrence in Crohn's disease as pertains to patient-reported outcomes?

Figure 3 Analytic framework for assessing the comparative effectiveness and safety of pharmacologic therapies for Crohn's disease

KQ = Key Question

Note: KQ1: comparative effectiveness in inducing remission; KQ2: comparative effectiveness in maintaining remission; KQ3: comparative safety; KQ4: comparative effectiveness of treatments for post-surgical patient-reported outcomes

^*^ For KQ4, the only examined endpoint is patient-reported outcomes.

Figure 3 is our analytic framework, presenting the Key Questions in terms of the PICOTS as presented above. An adult or child with active Crohn's Disease is treated with aminosalicylates, corticosteroids, immunomodulators, and/or biologics. Treatment can induce remission, which can be measured as Crohn's Disease Activity Index (CDAI), patient-reported outcomes, mucosal healing, surgery avoidance, reduction of hospitalizations, corticosteroid reduction, fistula response and growth in children (KQ1). Treatments can also be used to maintain remission, which is measured by the same set of outcomes (KQ2). Treatment may also be associated with adverse events, such as mortality, lymphoma and other cancers, infections, infusion- and injection-site reactions, bone fractures and other adverse events (KQ3). Those patients who have had at least one intestinal resection will be considered as a sub-population of interest and their patient-reported outcomes will be measured (KQ4).

For each KQ, we aimed to evaluate specific outcomes as listed in Table 3. Table 4 lists the disease activity indexes and disease-specific quality of life instruments the studies commonly used.

Table 3 List of outcomes considered for each Key Question on the comparative effectiveness and safety of medications for treatment of Crohn's disease

Key Question | Outcomes
KQ1 | - Disease activity measures (remission, CDAI, PCDAI, HBI, or other disease activity measurements); - Mucosal healing (presence of ulcers, CDEIS); - Hospitalizations; - Surgeries; - Reduction of steroids; - Fistula response (complete or partial fistula closure or other measure of perianal disease); - Patient-reported outcomes (health-related quality of life, IBDQ, days of work or school missed)
KQ2 | - Disease activity measures (relapse, CDAI, PCDAI, HBI, or other disease activity measurements); - Mucosal healing (presence of ulcers, CDEIS); - Hospitalizations; - Surgeries; - Reduction of steroids; - Fistula response (fistula recurrence or other measure of perianal disease); - Patient-reported outcomes (health-related quality of life, IBDQ, days of work or school missed)
KQ3 | - Mortality; - Lymphomas; - Cervical cancer; - Other cancers; - Tuberculosis; - Serious infections; - Other infections; - Infusion- and injection-site reactions; - Bone fractures; - Height and weight (for pediatric studies only)
KQ4 | - Patient-reported outcomes (health-related quality of life, IBDQ, days of work or school missed)

CDAI = Crohn's Disease Activity Index; CDEIS = Crohn's Disease Endoscopic Index of Severity; HBI = Harvey-Bradshaw Index; IBDQ = Inflammatory Bowel Disease Questionnaire; KQ = Key Question; PCDAI = Pediatric Crohn's Disease Activity Index

Note: KQ1: comparative effectiveness in inducing remission; KQ2: comparative effectiveness in maintaining remission; KQ3: comparative safety; KQ4: comparative effectiveness of treatments for post-surgical patient-reported outcomes

Table 4 List of disease activity indexes and disease-specific quality of life instruments

Measure or Instrument | Range of Total Scores | Higher Scores Indicate
Crohn's Disease Activity Index | 0 to 600 | More severe disease activity
Pediatric Crohn's Disease Activity Index | 0 to 100 | More severe disease activity
Harvey-Bradshaw Index | 0 to 19 | More severe disease activity
Crohn's Disease Endoscopic Index of Severity | 0 to 44 | More severe disease activity
Inflammatory Bowel Disease Questionnaire | 32 to 224 | Better quality of life