# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Yngve Falck-Ytter, M.D., AGAF
  Case Western Reserve University
  Case and VA Medical Center
  Cleveland, OH
- Stephen B. Hanauer, M.D.
  University of Chicago Medical Center
  Chicago, IL
- Lisa Herrinton, Ph.D.
  Kaiser Permanente
  Oakland, CA
- Sunanda Kane, M.D.
  Mayo Clinic
  Rochester, MN
- James Lewis, M.D., M.S.C.E.
  Perelman School of Medicine at the University of Pennsylvania
  Philadelphia, PA