# Acknowledgments

The Evidence-based Practice Center thanks Todd Noletto and Elisabeth Haberl for their assistance with reviewing articles and Eric Vohr for copy editing. We would also like to thank the Key Informants, Technical Expert Panel, Peer Reviewers, and Task Order Officer, as well as our Associate Editor, Kathleen N. Lohr, Ph.D., of RTI International.