# Discussion

## Key Findings and Clinical Implications

The purpose of this review was to compare the effectiveness and safety of biologics, immunomodulators, corticosteroids, and aminosalicylates in the treatment of Crohn's disease.

This section provides a summary of the findings, compares the findings with related systematic reviews, lists limitations of the data and the approach, and suggests future directions.

### Summary of Key Findings for Adults

#### Key Question 1 Induction of Remission Measured in Terms of Disease Activity

Of the 78 comparisons with evidence, four resulted in high strength of evidence and 20 resulted in moderate strength of evidence (see Table 6). Consistency of effect was based on a medication comparison having the same direction of effect for both disease activity (across evaluable time points) and for at least one other outcome.

Infliximab was found to have the greatest consistency across the outcomes of disease activity, mucosal healing, fistula healing, and IBDQ when compared with placebo (based on two trials). It was also the only comparison that included a high SOE for a given outcome (fistula healing).

Other consistent comparisons that included at least one outcome with a moderate SOE included: infliximab was favored over azathioprine for disease activity and mucosal healing (based on one trial), the combination of infliximab and azathioprine was favored over azathioprine alone for disease activity and mucosal healing (based on two trials), and the combination of infliximab and azathioprine was favored over infliximab alone for disease activity, mucosal healing (based on one trial). In all three of these comparisons, IBDQ was not different between treatment arms.

Several placebo-controlled trials were also found to be consistent across outcomes. However, all the individual outcomes were rated as low SOE. The following interventions were favored over placebo: prednisone/6-methylprednisolone for disease activity and fistula healing (based on two trials), sulfasalazine for disease activity and fistula healing (based on two trials), and thiopurine for disease activity and fistula healing (based on one trial). Thiopurines and placebo did not differ in corticosteroid reduction and IBDQ.

For head-to-head trails, the following comparisons were consistent across outcomes with all individual outcomes rated as low SOE: combination of infliximab and methotrexate favored over infliximab alone for disease activity, steroid reduction, and IBDQ (based on one trial), and corticosteroids favored over thiopurines for disease activity and fistula healing (based on one trial).

#### Key Question 2 Maintenance of Remission Measured in Terms of Disease Activity

Of the 55 comparisons with evidence, none resulted in high strength of evidence and 11 resulted in moderate strength of evidence (see Table 21). Consistency of effect was based on a medication comparison having the same direction of effect for both disease activity (across evaluable time points) and for at least one other outcome.

Infliximab was found to have the greatest consistency across outcomes when compared with placebo for disease activity, mucosal healing, hospitalization, surgery, corticosteroid reduction, fistula healing, and IBDQ (based on three trials). Adalimumab was also favored over placebo for the outcomes of disease activity, hospitalization, surgery, and corticosteroid reduction (based on two trials); however, adalimumab was not favored over placebo for IBDQ.

Other consistent comparisons with at least one outcome rated as moderate SOE included: natalizumab favored over placebo for disease activity, steroid reduction, and IBDQ (based on one trial), azathioprine over budesonide for disease activity and mucosal healing (based on one trial), and budesonide over aminosalicylates for disease activity and IBDQ (based on one trial). Thiopurines were consistently favored over placebo for disease activity and corticosteroid reduction (based on four trials); however, all the outcomes were rated as low SOE.

#### Key Question 3 Safety

The SOE for nearly every comparison was graded as insufficient or low for safety-related outcomes. Frequently, comparisons graded with low SOE did not favor either medication compared. We graded comparisons as high SOE for only two safety comparisons, both from a single RCT, and both for an outcome of infusion and injection-site reactions. One comparison favored oral azathioprine with placebo infusion over intravenous infliximab, and another favored placebo over intravenous azathioprine.

#### Key Question 4 Patient-Reported Outcomes After Intestinal Resection

We included one RCT that measured a patient-reported outcome (Inflammatory Bowel Disease Questionnaire [IBDQ]) after intestinal resection and no difference was found between azathioprine and mesalamine. Although the data were limited, patient-reported outcomes after intestinal resection had not been addressed in a previous systematic review.19

### Summary of Key Findings for Pediatrics

Ten studies were identified that reported on pediatric outcomes. The SOE was graded as low or insufficient to support any medication to induce or maintain remission in pediatric Crohn's disease for KQ1 and KQ2. No pediatric study reported on a serious adverse event such as mortality, progressive multifocal leukoencephalopathy, lymphoma, or other cancers. No pediatric study reported on a patient-reported outcome.

## Applicability of Remission Results for Adults

### Populations

- The majority of trials enrolled only Caucasians. African Americans, Hispanics, and Asians were not well represented.
- The median age at enrollment in most trials ranged between 25 and 40 years of age. Older persons were not well represented.
- Mean duration of disease, with the exception of a few trials,45,48 was often greater than 10 years. Understanding the effectiveness of medications on the natural history of disease, such as the proposed benefits of top-down compared with step-up therapy, requires trials with recently diagnosed patients.

### Intervention

- The doses and delivery methods of medications used sometimes differed across trials.

### Comparisons

- There were very few direct comparisons of medications.

### Outcomes

- Improvement in CDAI score is non-specific for Crohn's disease. CDAI score also varies with irritable bowel-type symptoms.203 This may explain why many of the studies had high placebo rates of response and remission.
- Few trials reported on outcomes other than the CDAI. Some outcomes such as mucosal healing and fistula response were frequently analyzed as subgroup analyses and not as primary endpoints.

### Timing

- There were very few trials that evaluated endpoints beyond 1 year. For a lifelong disease, the amount of time represented by these trials is very short.

### Setting

- Most trials took place in North America and Europe. Thus, results may not necessarily be transferred to other locales.

### Other—Conflict of Interest

- In KQ1, of the 36 trials (82 percent) trials that reported on conflicts of interest, 86 percent received pharmaceutical support with 56 percent having pharmaceutical company employed co-authors. For the 25 trials (69 percent) reporting on conflicts of interest for KQ2, the figures were 80 percent and 44 percent, respectively.

## Applicability of Safety Results for Adults

The non-RCTs that reported safety outcomes of interest did not have as many eligibility criteria as the RCTs. Very few non-RCTs had disease activity or disease location exclusions. Because observational studies made fewer restrictions on the patient populations, they likely apply to Crohn's disease patients of all disease severities. Despite the differences in eligibility criteria, the RCTs and observational studies did not have meaningful differences in safety signals. The studies that included all IBD patients had similar safety findings as studies that included only Crohn's disease patients or those studies that reported results for both Crohn's disease and IBD patients.

## Pediatric Applicability

The applicability of these studies was limited because of the small number of studies, with few participants per study. Also, very few medications were compared. The longest RCT had only 18 months of followup and the longest prospective study had less than 4 years of followup.

## Comparison With Existing Guidelines and Systematic Reviews

Several clinical guidelines have been developed based on comprehensive literature searches combined with expert opinion8,204-206 and numerous systematic reviews comparing treatments for Crohn's disease have been performed.11,17,207-216 Although the findings of our systematic review are consistent with most of the published guidelines and reviews, we note a few differences in the methodology, strength of evidence and the findings. Our methodologic approach:

- Searched publication databases without year of publication restrictions
- Considered a clinically meaningful threshold to identify differences in treatments outcomes rather than relying on statistical significance
- Abstracted information at multiple clinically relevant time points instead of focusing on the last time point reported
- Included multiple outcomes associated with treatment aimed at achieving remission, instead of using the Crohn's Disease Activity Index to measure response or remission and some safety events with occasional use of endoscopic healing and other outcomes
- Specifically included mortality, progressive multifocal leukoencephalopathy, hepatosplenic-T-cell lymphoma, other lymphomas and cancers, and serious infections and infusion reactions, whereas many reviews consider more generic categories as reported in trials such as overall adverse events, serious adverse events, and infections
- Required that all studies have a comparison group, allowed head-to-head trials, and allowed observational studies for safety outcomes
- Did not include antibiotics and enteral nutrition as comparators of interest
- Did not consider disease location in assessments in contrast with the clinical guidelines which often recommend different initial treatments depending on the location and extent of disease
- Reviewed and graded the strength of evidence separately for safety and efficacy compared with considering the balance between safety and efficacy in a single grade of the SOE.

The strength of evidence was generally graded the same or lower in our review compared with others. This difference might be due to the fact that the other studies pooled all comparisons regardless of study or statistical heterogeneity, whereas we only pooled studies when we felt studies were comparable and statistical heterogeneity was low, frequently leading to inconsistent and imprecise evidence.

The major difference in findings between this review and others pertains to infliximab. Other reviews found that all TNF-alpha inhibitors are efficacious at inducing and maintaining remission. We also would come to this conclusion if we based results on the meta-analysis of TNF-alpha inhibitors that we performed at week 2 after induction. However, when we consider the clinically meaningful threshold for a difference in treatment effects and examine the consistency of efficacy across the different outcomes of interest, infliximab is the only TNF-alpha inhibitor that is consistently favored over placebo at multiple time points and for multiple outcomes.

## Limitations

Our review has a number of limitations, most of which are related to the limitations of the available data. The major limitations in the data were:

- Lack of head-to-head studies
- Study heterogeneity limited meta-analyses
- Inability to isolate patients with moderate-to-severe Crohn's disease from those with mild disease
- Potential measurement error as a result of abstracting data from figures
- Limited reporting of results for the subgroup populations of interest
- Short trial durations
- Difficulty interpreting studies that compared the same drug delivered at different time points (i.e., on-demand versus maintenance therapy for biologics).

The major limitations in our review methods were:

- No standard existed to select a threshold of 10 percent to define a clinically meaningful difference between comparison groups
- Trouble separating induction from maintenance studies (i.e., some studies that met criteria for induction had endpoints of 26 weeks or longer).

### Limitations in the Data

#### Lack of Head-to-Head Studies

There was a paucity of head-to-head studies, particularly for maintenance trials. Practitioners deciding between two maintenance therapies in patients with Crohn's disease need to be aware that little evidence exists to make evidence-based treatment decisions. On initiation of this project, we knew that there were few head-to-head trials in the literature. However, we felt that it was important to systematically document the literature in order to better understand the gaps. Additionally, we had intended to perform a network meta-analysis in order to indirectly compare drug classes that have not been compared in the literature to help address the evidence gap resulting from direct comparisons of treatments. However, study heterogeneity and sparse data (few studies addressed each comparison of interest) prevented a network meta-analysis.

#### Study Heterogeneity Limited Meta-Analyses

One common source of heterogeneity was the variation in study designs, especially for the maintenance trials. For example, the studies of maintenance therapy varied in how they identified a patient's eligibility for randomization to the study arms. Some of the maintenance trials had a run-in period where all patients received the active study medication followed by randomization of patients with a response to the study drug. Other maintenance trials enrolled patients that had a response to the study medication of interest in a previous remission trial or who had long-term inactive disease based on clinic visits.

An additional source of heterogeneity was related to the baseline characteristics of the enrolled patients, particularly with use of previous and concurrent medication to treat Crohn's disease. For example, many TNF-alpha inhibitor studies included both TNF-alpha inhibitor exposed and naïve patients. Additionally, maintenance studies varied with regard to the use of corticosteroids and other medications at randomization and throughout the trial.

Another source of heterogeneity was the use of varied definitions of remission. Among the studies, there were different disease activity scales and different disease activity scale thresholds for remission. For example, some studies required a change in corticosteroid dose and a change in disease activity to define remission whereas other studies considered remission a change in disease activity regardless of a decrease in corticosteroid dose.

We also found heterogeneity in study duration, especially for the safety outcomes where results ranged from trial reports at 2 weeks to observational studies of over 5 years. Finally, we found it difficult to compare studies published prior to the 2000s and after as the study designs and reporting of the design details differed substantially. We often rated the newer studies as having lower risk of bias.

#### Inability To Isolate Patients With Moderate-to-Severe Crohn's Disease

Our original intention was to look at patients with moderate-to-severe Crohn's disease. However, we found that most induction of remission trials included patients with any active disease, including those with mild disease. Identifying patients with moderate-to-severe disease was even more of a challenge with maintenance of remission trials, where most studies randomized patients while in remission, so it was impossible to ascertain the original disease severity.

#### Potential for Measurement Error for Time Points Other Than the Primary Outcome of Interest

Because we included clinically meaningful time points of interest that may not have corresponded to the primary outcome of interest, we frequently abstracted data for these time points from figures. The article figures did not consistently display time points of assessment as reported in the study design and rarely included measures of variation for each time point. The lack of information on the variation of an outcome was especially pronounced for reporting of the IBDQ scores, and prevented us from performing statistical analyses of the difference in IBDQ scores between treatment groups.

#### Subgroup Analyses Were Limited

Most of the subgroup population analyses were limited by poor reporting of statistical interaction terms. This becomes particularly important as many studies allowed patients to use Crohn's medications at randomization and throughout the study as long as the medication dose remained stable.

#### Short Trial Durations

The maintenance of remission evidence was limited to 2 years (104 weeks), a very brief period of time for a chronic condition. For many comparisons, especially the newer trials of biologics, the maximum trial duration was 1 year. For instance, the azathioprine and 6-methylprednisolone were found to consistently outperform placebo at 1 and 2 years with azathioprine also reducing the need for corticosteroids at 6 months (the last reported time point available). However, the evidence for the other efficacious agents, natalizumab and infliximab, is limited to 1 year. The limited duration of trials for a relapsing and remitting chronic condition limits the information that health care providers can share with their patients regarding the efficacy of medications to treat Crohn's disease.

#### Inclusion of Studies That Evaluated the Same Drug at Different Points in Time

Per our methods, we excluded studies that compared different doses of the same medication unless a comparison to an additional medication was made. However, we came across TNF-alpha inhibitor maintenance trials87,95,217 that were intended to compare episodic (on-demand) treatment with regularly scheduled treatment to mimic clinical practice. Additionally, the one study that directly addressed step-up versus top-down therapy examined different time points for introducing immune-based therapies such as thiopurines and infliximab.48 As a result, patients in both study arms may have received both classes of medications. Although these studies presented challenges in interpretation compared with more traditional trial designs, they were included because they are very applicable to clinical practice.

#### Other Limitations of the Data

Other limitations included: (a) most trials were sponsored by the manufacturer of the medications, which has been associated with the reporting of results that are more favorable than studies not supported by industry;218 (b) our analyses indicated the presence of publication bias as measured by Begg's and Egger's tests, especially for corticosteroids and aminosalicylates.

### Limitations in Our Review Method

#### No Standard Existed To Define a Clinically Meaningful Difference Between Comparison Groups

When we assessed the efficacy and safety of the medications, we sought to consider whether differences were clinically meaningful, instead of focusing on statistical significance. In the absence of a standard for a clinically meaningful absolute difference in remission rate for Crohn's disease, we chose a relatively low absolute difference of 10 percent as the threshold for identifying a clinically meaningful difference in the induction and maintenance of remission outcomes. An example of this difference is that if 50 percent of placebo participants were in remission, 60 percent or more active medication participants had to be in remission to label the effect clinically meaningful. Although individual studies may have been designed to have only enough statistical power to detect larger differences in remission rates, we believed it was important to keep in mind that patients with the debilitating symptoms of Crohn's disease might want to know whether a treatment could provide a modest 10 percent absolute increase in their chance at remission. If we had used a higher threshold for identifying a clinically meaningful difference in remission rates, fewer differences would have been considered clinically meaningful in this report.

Because many of the adverse events are very rare, we did not assign a threshold for a clinically meaningful difference for safety. We relied on a statistically significant difference instead, which resulted in only two comparisons graded as high SOE, both with a greater than 10 percent absolute difference between the treatment groups for the outcome of infusion- and injection-site reactions.

#### Trouble Separating Induction From Maintenance Studies

Our inclusion criteria arbitrarily defined eligibility for induction if patients had active disease at randomization and eligibility for maintenance if participants had inactive disease at randomization. However, we acknowledge that time points for induction trials after 12-16 weeks are more consistent with maintenance studies. The alternative was to present the later time points of the induction trials with the maintenance trials, although we thought this would lead to unnecessary repetition of study and population characteristics.

#### Other Limitations

Other limitations included:

- We excluded 223 non-English articles.
- We only included information from peer-reviewed journals (excluding information reported in abstract-only form which has been documented to differ from the subsequent peer-reviewed article).219,220
- We did not examine certain classes of medications including antibiotics or probiotics. We also did not examine other therapies such as enteral or parenteral feeding, as we felt this was out of the scope of this systematic review.

## Future Research Needs

We found many gaps in the literature on medical therapy for Crohn's disease. Most studies evaluated white adults under 50 years of age who often had been diagnosed at least 10 years prior to the start of the study. Further attention needs to be given to non-white populations, pediatric patients, older adults (over 50 years of age), newly diagnosed patients or those who have been on few medications for Crohn's disease, and patients with severe Crohn's disease (including those with complications including abscess and fistula formation).

With regard to intervention and study design, we found few head-to-head trials involving TNF-alpha inhibitor agents and natalizumab. We also need further studies to evaluate the introduction of immunosuppressive therapy early in the disease course (top-down approach) versus more traditional step-up medication strategies as many physicians are beginning to use top-down treatment in the absence of strong evidence to support this treatment paradigm.

Researchers need to design safety studies so they have sufficient power to detect clinically meaningful differences between medications. Randomized trials should also be adequately powered to compare specific, important safety events if they intend to report on safety outcomes. Keeping in mind the practical limitations of acquiring investigator-initiated funding, more trials that are independent of industry input in the design, analysis, interpretation, and design to publish, but with industry sponsorship, combined with investigators who are not paid consultants of industry could help minimize conflicts of interest.

In terms of outcomes, more studies need to evaluate outcomes beyond disease activity, including mucosal healing, rates of hospitalization and surgery, fistula healing, and patient-reported outcomes (including post-surgical studies). Given that Crohn's disease may last many decades, we should extend outcomes for RCTs on maintenance therapy beyond 2 years. Observational studies for safety should be sufficiently long to observe safety outcomes, such as cancer, that may not manifest themselves for many years.

## Conclusions

Infliximab was the only medication that was found to be consistently effective compared with placebo across a number of outcomes for both induction and maintenance of remission. For most medication comparisons, data was lacking on outcomes other than disease activity indices. In children, the evidence was insufficient to permit assessment of the consistency of medication efficacy across outcomes. The quality of the safety evidence was poor due to poor reporting of the methods in trials and poor confounding control in observational studies. No strong or previously unidentified signals of harm were identified. Comparing Crohn's disease medications directly using pragmatic clinical trials will help to understand the effectiveness of medications in clinical practice using outcomes other than the Crohn's Disease Activity Index.