# Subgroup Analysis Tables

(reference list located in full report)

Table 1 Comparative effectiveness of pharmacologic therapies to induce remission in sub-populations of patients with Crohn's disease

Table 2 Comparative effectiveness of pharmacologic therapies to induce remission in sub-populations of patients with Crohn's disease