# Summary of Studies Comparing the Safety of Pharmacologic Therapies Among Patients With Inflammatory Bowel Disease

(reference list located in full report)

## Mortality

### Infliximab Versus No Infliximab

One retrospective study of inflammatory bowel disease patients (80 percent Crohn's disease) compared 743 users of infliximab followed a median of 5 years to 666 never users of a biologic followed a median of 12 years.153 Safety was assessed using chart review and physician and patient contact. Two percent mortality was observed in both groups and an OR was provided (OR, 0.8; 95% CI, 0.3 to 1.8), although concomitant medications, disease severity, or other demographic or disease characteristics may not have been accounted for in the analysis. One of these deaths was from progressive multifocal leukoencephalopathy (PML), which is described in further detail in the PML section of the main report.33 167 This study153 may have underestimated the relative risk of cancer and death among patients treated with infliximab because of a flaw known as immortal time bias resulting from differential exclusion of followup time in the study groups.238

### Combination of Infliximab and Immunomodulators Versus Infliximab

Two single center studies of 221 patients (92 percent173 and 81 percent129 Crohn's disease) reported mortality in inflammatory bowel disease patients for the combination of infliximab and thiopurines versus infliximab.129 173 Concomitant medications were reported at the time of the first infliximab infusion. No deaths were reported in either study.

### Combination of Infliximab and Corticosteroids Versus Infliximab

The same center reported no deaths among 42 users of infliximab and corticosteroids users or among 58 users of infliximab without corticosteroids.173

### Thiopurines Versus No Thiopurines

A prospective study included 19,846 inflammatory bowel disease patients (60 percent Crohn's disease) seen by 817 adult and pediatric gastroenterologists in France.130 One percent mortality was observed in thiopurine users and never users followed for up to three years (Peto OR, 1.2; 95% CI, 0.9 to 1.6). The study also reported mortality among those receiving a thiopurine at study entry (46 deaths, <1 percent), discontinuing a thiopurine prior to study entry (45 deaths, 2 percent), or never receiving thiopurines (95 deaths, <1 percent). The study reported a p-value less than 0.0006 for a difference in the comparison between these three groups.

### Corticosteroids Versus No Corticosteroids

One retrospective cohort of 554 inflammatory bowel disease patients evaluated mortality in users and non-users of corticosteroids or corticotrophin using a chart review of patients seen at the study center between 1946 and 1965.^142^ Suicide was recorded in four of 430 corticosteroid users compared with zero of 124 non-users.

## Lymphoma

### Infliximab Versus Never User of Biologics

One retrospective study including 1,409 inflammatory bowel disease patients aimed to evaluate the long term safety of infliximab at their center.153 The study compared 743 infliximab users followed for 5 years with 666 never users of a biologic followed for 12 years. Two lymphoma cases were reported among infliximab users and three lymphoma cases in never users of biologics corresponding to less than 1 percent lymphoma in each group.153 The corresponding Peto OR was 0.6 (95% CI, 0.1 to 3.5).153 This study153 may have underestimated the relative risk of cancer and death among patients treated with infliximab because of a flaw known as immortal time bias resulting from differential exclusion of followup time in the study groups.238

### Combination of Infliximab and Immunomodulators Versus Infliximab

One retrospective study of 100 inflammatory bowel disease patients reported no cases of lymphoma over 26 months median followup.173

### Combination of Infliximab and Corticosteroids Versus Infliximab

One retrospective study of 100 inflammatory bowel disease patients reported no cases of lymphoma over 26 months median followup.173

### Immunomodulators Versus No Immunomodulators

Four observational studies including 37,943 inflammatory bowel disease patients compared immunomodulators with no immunomodulators and reported on lymphoma.130 133 231 232 One prospective study aimed to assess the risk of lymphoproliferative disorders in inflammatory bowel disease patients with thiopurine use over 3 years of followup.130 Sixty percent of the 11,759 patients had Crohn's disease. One non-Hodgkin's lymphoma and 22 non-Hodgkin's lymphoproliferative disorder cases were reported. The study reported an adjusted HR of 5.3 (95% CI, 2.2 to 12.6) for incident lymphoproliferative disorder between thiopurine users and thiopurine non-users.

One case-control study133 and one retrospective study232 including 17,675 patients reported the association between azathioprine and lymphoma. The case-control study compared azathioprine users versus non-users.133 Fifteen of 15,471 inflammatory bowel disease cases had codes indicating lymphoma. The age and smoking adjusted OR comparing azathioprine users with non-users was 3.2 (95% CI, 1.0 to 10.2). For each tertile increase in azathioprine exposure, the odds of lymphoma increased by 37 percent (age and smoking adjusted OR, 1.4; 95% CI, 0.8 to 2.4). This database may include cases that have been reported in other studies included in this review.136 239 A retrospective study reported three cases of lymphoma among 626 (< 1 percent) patients with azathioprine use recorded in their charts compared with five lymphoma cases among 1,578 inflammatory bowel disease patients with no history of azathioprine use.232 Thirty-nine percent of patients had Crohn's disease. One Crohn's disease patient who had not been treated with azathioprine had lymphoma.

A retrospective study of inflammatory bowel disease patients (34 percent Crohn's disease) reported four non-Hodgkin's lymphoma cases among 238 patients with a record of azathioprine, methotrexate, or cyclosporine in their medical records compared with zero cases among 544 patients with no reported history of azathioprine, methotrexate or cyclosporine.231 One of the lymphoma cases had Crohn's disease.

### Corticosteroids Versus No Corticosteroids

The retrospective study including 15,164 inflammatory bowel disease patients that could include overlapping lymphoma patients as another study also reported lymphoma by corticosteroid use.136 Less than 1 percent of the corticosteroid and no corticosteroid groups had lymphoma. The corresponding Peto OR is 1.0 (95% CI, 0.3 to 3.1).

### Mesalamine Versus No Mesalamine

The same study reported lymphoma by mesalamine use in inflammatory bowel disease patients.136 The Peto OR for mesalamine versus no mesalamine is 1.0 (95% CI, 0.3 to 2.6).

## Cervical Cancer

### Infliximab Versus No Infliximab

Two retrospective studies including 1,205 female inflammatory bowel disease patients reported cervical cancer by infliximab use.141 152 A retrospective study within a case-control study of women with inflammatory bowel disease who had received at least one Papanicolaou (Pap) test reported that none of the 10 cervical cancer cases (defined as cervical intraepithelial neoplasia grade III or greater) used infliximab within three years of their cancer compared with 11 of 1,155 (1 percent) inflammatory bowel disease women who had normal Pap tests.152 Another retrospective study within a case-control study included 40 inflammatory bowel disease patients with at least one normal Pap test prior to inflammatory bowel disease diagnosis and two Pap tests after inflammatory bowel disease diagnosis. No case of cervical cancer was observed.141 None of the seven women with a record of infliximab use in their charts and none of the 33 women with no recorded infliximab use was diagnosed with cervical cancer.141

### TNF-Alpha Inhibitor Versus No TNF-Alpha Inhibitor

One retrospective study within a case-control study including 362 patients compared infliximab or adalimumab use with no use with risk of cervical dysplasia as recorded in pathology records.144 The study included women diagnosed with inflammatory bowel disease prior to age 60 who had no history of abnormal cervical smears prior to inflammatory bowel disease diagnosis and at least one cervical smear after inflammatory bowel disease diagnosis. One cervical adenocarcinoma was reported among the 362 women with inflammatory bowel disease. None of 33 women with adalimumab or infliximab use were diagnosed with cervical cancer compared with one of 329 (<1 percent) women with no record of use.144

### Immunomodulators Versus No Immunomodulators

Four retrospective studies including 1,942 patients reported cervical cancer by immunomodulators use.141 144 152 231 One study reported immunomodulators use within 3 years among three of 10 (30 percent) cervical cancer cases compared with 123 of 1,155 (11 percent) non-cases (age, ethnicity, and smoking adjusted OR, 3.5; 95% CI, 0.8 to 14.5).152 Other medications were not accounted for in the analyses. Another study reported that cervical cancer was diagnosed in 0 of 107 women with a record of thiopurine use for at least three months compared with one of 233 women with no thiopurine use or less than three months of thiopurine use.144 This study also reported no cervical cancer cases among 13 users of methotrexate for at least three months compared with the same single cervical cancer case among the 349 (<1 percent) women with no use or less than three months of methotrexate use.144 A study reported that none of the 22 women with a record of thiopurine use in their charts and none of the 18 women with no recorded thiopurine use was diagnosed with cervical cancer.141 Methotrexate use was not recorded in any of the 40 charts.

One study did not aim to study cervical cancer but specifically reported that cervical cancer was not an observed cancer among those reported. The retrospective study of inflammatory bowel disease patients reported no cervical cancer cases among 238 patients with a record of azathioprine, methotrexate, or cyclosporine in their medical records as well as no cervical cancer cases among 544 with no reported history of azathioprine, methotrexate, or cyclosporine. Of the included patients, 375 were women.231

### Corticosteroids Versus No Corticosteroids

Two retrospective studies including 1,205 patients reported cervical cancer by corticosteroid use.141 152 One study reported corticosteroid use within 3 years among seven of 10 (70 percent) cervical cancer cases compared with 508 of 1,155 (44 percent) non-cases (age, ethnicity, and smoking adjusted OR, 2.8; 95% CI, 0.7 to 11.0).152 One invasive cervical cancer was reported. The invasive cervical cancer case had ulcerative colitis. Another study reported that none of the 12 women with a record of greater than 15 mg of prednisone use in their charts and none of the 28 women having less than 15 mg prednisone use was diagnosed with cervical cancer.141

### Aminosalicylates Versus No Aminosalicylates

A study reported aminosalicylate use within 3 years among 8 of 10 (80 percent) cervical cancer cases compared with 769 of 1,155 (67 percent) non-cases (age, ethnicity, and smoking adjusted OR, 1.7; 95% CI, 0.3 to 8.0).152

## Colorectal Cancer

### Immunomodulators Versus No Immunomodulators

A pooled registry study of 1,149 inflammatory bowel disease patients reported colorectal neoplasia in two patients receiving thiopurines without aminosalicylates compared to 14 cases among patients who had never received thiopurines nor aminosalicylates (adjusted HR 0.1; 95% CI 0.0 – 0.8).234

### Combination of Immunomodulators With Aminosalicylates Versus Never User of These Medications

A pooled registry study of 1,149 inflammatory bowel disease patients reported colorectal neoplasia in one patient who received thiopurines with aminosalicylates (0.3 cases per 1,000 person-years compared to 14 cases among patients who had never received thiopurines nor aminosalicylates (2.9 cases per 1,000 person-years).234

### Aminosalicylates Versus No Aminosalicylates

Two retrospective studies including 10,552 inflammatory bowel disease patients compared aminsalicylate use to never use with risk of colorectal cancer.234 235 Neither study found a statistically significance association with colorectal cancer risk. The effect estimates suggested modest effects of aminosalicylates in opposite directions. The Dutch pooled registry study reported that aminosalicylates were associated with a decreased risk of cancer (adjusted HR 0.6; 95% CI 0.2 – 1.4)234 compared to a slightly elevated effect in the Canadian study (adjusted HR 1.2; 95% CI 0.8 – 1.7).235 The inconsistent effects may be partly explained by the adjustments in the analyses. Both studies adjusted for demographics, but the Dutch study also adjusted for disease location, dysplasia hx, surgery hx, folic acid use, calcium use, other medication use and type of inflammatory bowel disease.234

## Other Cancers

### Infliximab Versus No Infliximab

One retrospective study of 1,409 inflammatory bowel disease patients (80 percent Crohn's disease) compared infliximab with never user of a biologic and reported on cancer risk.153 Three percent of the infliximab group (21 cancers among 743 patients contributing 3,775 person-years) and 5 percent of the never users of biologics (30 of 666 patients contributing 6,704 person-years) had cancer. The study reported an adjusted OR of 1.0 (95% CI, 0.6 to 1.7). An unadjusted rate ratio corresponding to the events and person-time provided was 3.6 (95% CI, 1.9 to 6.4). This study153 may have underestimated the relative risk of cancer and death among patients treated with infliximab because of a flaw known as immortal time bias resulting from differential exclusion of followup time in the study groups.238

### Combination of Infliximab and Immunomodulators Versus Infliximab

Two single center studies of 221 patients (92 percent173 and 81 percent129 Crohn's disease) reported on cancer in inflammatory bowel disease patients for the combination of infliximab and thiopurines versus infliximab.129 173 Concomitant medications were reported at the time of the first infliximab infusion. No cancers were reported in either study.

### Combination of Infliximab and Corticosteroids Versus Infliximab

The same retrospective study of 100 inflammatory bowel disease patients reported no cancers during the 26-month median study period comparing 42 patients taking infliximab and a corticosteroid with 58 patients taking infliximab without a corticosteroid.173

### Other Combinations With Infliximab

One retrospective study of 147 inflammatory bowel disease patients met the inclusion criteria but the cancer cases' concomitant medications may be misclassified as described above.227 Nine cancers were reported. The cancers occurred in seven of 93 patients taking infliximab and an immunomodulator (with or without corticosteroids) and two of 54 (4 percent) patients taking infliximab without an immunomodulator. When examining concomitant corticosteroids (with or without immunomodulators), the cancers occurred in four of 102 (4 percent) patients taking infliximab and a corticosteroid compared with five of 45 (11 percent) patients taking infliximab without a corticosteroid.

### Immunomodulators Versus No Immunomodulators

Four observational studies including 37,943 inflammatory bowel disease patients compared immunomodulators with no immunomodulators and reported on cancer risk.130 133 231 232 A prospective study of 19,486 patients followed a median of 35 months reported cancers in 2 percent of current or previous thiopurine users and 1 percent of never users of thiopurine.130 The study reported P < 0.0006 for a difference in the comparison between these three groups. The corresponding Peto OR comparing ever with never users was 1.4 (95% CI, 1.1 to 1.8).

A retrospective study (39 percent Crohn's disease) with 13.7 mean years of followup reported cancers in 5 percent of the 626 azathioprine patients and 4 percent of the 1,578 no azathioprine group. The corresponding Peto OR was 1.1 (95% CI, 0.7 to 1.7).232 Another retrospective study with 8 years median followup reported 14 (6 percent) cancers in 238 ever users of thiopurines, methotrexate, or cyclosporine and 16 (3 percent) cancers in 544 who had not used these medications according to chart review. The corresponding Peto OR was 2.1 (95% CI, 0.9 to 4.6).231

A case-control study comparing inflammatory bowel disease cancer cases with inflammatory bowel disease patients without cancer reported that 11 percent of cancer patients had been prescribed azathioprine compared with 13 percent of controls.133 After excluding 43 non-melanoma skin cancers (azathioprine versus no azathioprine OR, 1.0), there were 392 incident cases of cancer among 15,471 inflammatory bowel disease patients with at least one year of relevant data between 1987 and 2001. After adjusting for age and smoking, the OR was 1.1 (95% CI, 0.8 to 1.5). Although the number of Crohn's disease patients and their azathioprine use was not reported, the azathioprine versus no azathioprine OR in Crohn's disease was reported as 1.1 (95% CI, 0.7 to 1.8), although it is unclear if this relationship was adjusted.

## Infections

### Infliximab Versus No Infliximab

A retrospective study of 1,409 inflammatory bowel disease patients (80 percent Crohn's disease) reported serious infections that required hospitalization, prolonged hospitalization, led to significant disability, or were life-threatening or fatal.153 Serious infections within 12 weeks of the last infliximab infusion were reported in 48 (6 percent) of 743 infliximab users (5 years of followup) compared with 62 (9 percent) of 666 never users of a biologic (12 years of followup). The corresponding Peto OR was 0.7 (95% CI, 0.5 to 1.0).

### Combination of Infliximab With Immunomodulators Versus Infliximab

The retrospective study of 1,409 inflammatory bowel disease patients (80 percent Crohn's disease) reported that non-serious infections were not affected by methotrexate or thiopurine use, although the magnitude of the association was not reported.153 No infections requiring hospitalization were observed in a hospital-based registry of 121 patients (81 percent Crohn's disease).129

### Combination of Infliximab With Corticosteroids Versus Infliximab

The retrospective study of 1,409 inflammatory bowel disease patients (80 percent Crohn's disease) reported non-serious infections were more likely to occur during periods when corticosteroids were used (OR 2.7, 95% CI 1.2 to 6.1).153

### Other Combinations With Infliximab

Two retrospective studies including 247 inflammatory bowel disease patients met the inclusion criteria but the concomitant medications of the patients with infections may be misclassified as described in the mortality section.173 227 One retrospective study of 100 inflammatory bowel disease patients (92 Crohn's disease) reported infections in four of 82 patients receiving infliximab and a thiopurine compared with no infections in 18 patients receiving infliximab without a thiopurine.173 Examining the combination of infliximab and corticosteroids in these same 100 patients, infections occurred in zero of 42 patients on infliximab and corticosteroids and four of 58 patients on infliximab without a corticosteroid. The observed infections were varicella-zoster, pneumonia, E. coli, and sepsis. The study also reported that no opportunistic infections were observed. Another retrospective study of 147 patients (138 Crohn's disease) followed a median of 9 years reported serious infection requiring hospitalization in 19 percent of 93 patients taking infliximab and an immunomodulator and 33 percent of 54 patients taking infliximab without an immunomodulator.227 In the same 147 patients, serious infections were reported in 18 percent of 102 patients taking infliximab and corticosteroids and 40 percent of 45 patients taking infliximab without corticosteroids. Among these 36 patients, there were 57 unique hospitalizations with infection as the main reason for the hospitalization.227

### Immunomodulators Versus No Immunomodulators

Two studies including 302 inflammatory bowel disease patients compared immunomodulators with no immunomodulators and reported on infections.155 176 A prospective study reported specific benign infections (benign upper respiratory infections and human papillomavirus and herpes simplex virus cutaneous infections) among 230 inflammatory bowel disease patients (162 Crohn's disease) with well-controlled disease.155 Azathioprine use was assessed by chart review over an average of one year of followup. Active ascertainment of infections was performed by physical exams at each visit, with use of standardized forms for benign infections. Inflammatory bowel disease patients with and without use of azathioprine averaged two upper respiratory tract infections per year. Azathioprine users were more likely to have a flare-up of human papillomavirus or herpes simplex virus than patients not on azathioprine (1 flare per year among azathioprine users versus 0.2 flares per year among non-users).

One retrospective study including 72 patients (23 Crohn's disease) tested for cytomegalovirus infections in intestinal biopsies taken from inpatients with active inflammatory bowel disease.176 They reported that 17 percent (2 out of 12) of patients with azathioprine use had cytomegalovirus infection compared with 12 percent (7 out of 60) of patients without azathioprine use.176 Two of the eight cytomegalovirus infection positive patients had Crohn's disease.

### Immunomodulators Versus Corticosteroids

One study including 10,141 inflammatory bowel disease patients compared immunomodulators with corticosteroids and reported on infections.230 Because the study reported rate ratios comparing corticosteroids with immunomodulators, the comparisons reported here also compared corticosteroids with immunomodulators. The number of serious infections requiring hospitalization (as identified by ICD-9-CM codes) was 32 in corticosteroid users (4,066 person-years) compared with 27 in immunomodulator users (3,964 person-years). They adjusted for age, gender, inflammatory bowel disease type, year of diagnosis, mean comorbidity index, number of doctor visits, and number of medications, and reported a serious infection rate ratio of 1.1 (95% CI, 0.6 to 1.9) comparing corticosteroids (with or without infliximab) with immunomodulators. The rate ratio comparing corticosteroids only with immunomodulators only for serious infections was 1.2 (95% CI, 0.7 to 2.1). Clostridium difficile (C. difficile) was a non-serious infection of interest. The number of C. difficile infections was 57 in corticosteroid users (4,063 patient-years) compared with 14 in immunomodulator users (3,972 patient-years). The adjusted rate ratio comparing corticosteroids (with or without infliximab) with immunomodulators was 3.4 (95% CI, 1.9 to 6.1). The adjusted rate ratio comparing corticosteroids alone with immunomodulators alone was 2.7 (95% CI, 1.5 to 4.6).

A retrospective study of 27 users of thiopurines with or without corticosteroids (41 percent Crohn's disease) reported that almost 20 percent of both groups had infections including two cases of shingles and one case each of EBV viremia, PCP pneumonia, and viral meningitis.157

### Combination of Azathioprine and Aminosalicylates Versus Azathioprine

One retrospective study including 199 inflammatory bowel disease patients (122 Crohn's disease) reported that 2 percent (2 out of 104) of inflammatory bowel disease patients who filled prescriptions for both azathioprine and aminosalicylates at the hospital pharmacy had an infection reported in their charts compared with 2 percent (2 out of 95) of patients who filled prescriptions for azathioprine alone.156 The severity and type of infection were not defined.

### Corticosteroids Versus No Corticosteroids

One retrospective cohort including 554 inflammatory bowel disease patients reported infections in corticosteroid or corticotrophin users and non-users according to a chart review of patients seen at the hospital clinic between 1946 and 1965.^142^ Infections of unspecified severity or type were recorded in 17 of 124 (14 percent) corticosteroid or corticotrophin non-users compared with 95 of 430 (22 percent) corticosteroid or corticotrophin users. The corresponding Peto OR was 1.7 (95% CI, 1.0 to 2.8).

## Infusion and Injection-Site Reactions

### Combination of Infliximab and Immunomodulators Versus Infliximab

Five observational studies including 1,189 inflammatory bowel disease patients compared a combination of infliximab and immunomodulators with infliximab alone and reported infusion reactions.173 181 225 228 A retrospective study of 144 inflammatory bowel disease patients (139 Crohn's disease) who received 30 minutes to 1 hour of infusion instead of the standard 2 hours did not report the number of patients who experienced infusion reaction but did report an OR of 1.4 comparing a combination of infliximab and immunomodulators (thiopurines or methotrexate) with infliximab without immunomodulators (95% CI, 0.3 to 7.7) after adjustment for unspecified factors.181 The unadjusted OR comparing a combination of infliximab and thiopurines with infliximab was 1.1 (95% CI, 0.3 to 3.7).

Another retrospective study of 1 hour compared to 2 hour infusions reported 3 percent of patients who received immunosuppressants had an infusion reaction compared to 9 percent of patients who received infliximab alone.184

A retrospective study that followed inflammatory bowel disease patients for 8 months to 17 years reported a p-value only comparing a combination of infliximab and immunomodulators with infliximab. Patients who received the combination of infliximab and immunomodulators were less likely to have any adverse event within 24 hours of infusion than patients receiving infliximab without immunomodulators (univariate P = 0.002).228

A retrospective study of 651 inflammatory bowel disease patients reported 63 infusion reactions in 2,079 (3 percent) infliximab and immunomodulator infusions and 83 infusion reactions in 1,272 (7 percent) infliximab without immunomodulator infusions (during or within 2 hours after infusion).225 A retrospective study of 100 inflammatory bowel disease patients (92 with Crohn's disease) reported infusion reactions in two of 82 patients using infliximab and a thiopurine compared with zero of 18 patients using infliximab without a thiopurine.173 Both patients who experienced an infusion reaction had Crohn's disease.

### Combination of Infliximab and Thiopurines Versus Combination of Infliximab and Methotrexate

The retrospective study of 144 inflammatory bowel disease patients receiving 30 minute to 1-hour infusions instead of 2-hour infusions reported an unadjusted OR for infusion reaction comparing a combination of infliximab and methotrexate or prednisolone with a combination of infliximab and thiopurines of 1.2 (95% CI, 0.5 to 3.0).181

### Combination of Infliximab and Corticosteroids Versus Infliximab

Three retrospective studies including 989 inflammatory bowel disease patients compared infusion reactions in patients who received a combination of infliximab and corticosteroids versus infliximab without corticosteroids.173 225 A study of 100 inflammatory bowel disease patients (92 Crohn's disease) reported two Crohn's disease patients experiencing an infusion reaction in 58 patients receiving infliximab and corticosteroids versus zero in 42 patients receiving infliximab without corticosteroids.173 A retrospective study of 651 inflammatory bowel disease patients reported 33 infusion reactions in 611 infusions of infliximab with corticosteroids compared with 113 infusion reactions in 2,750 infusions of infliximab without corticosteroids.225 A retrospective study of 1 hour compared to 2 hour infusions reported 6 percent of patients who received corticosteroid premedication had an infusion reaction compared to 4 percent of patients who received infliximab alone.184

## Bone Fractures

### Corticosteroids Versus No Corticosteroids

One retrospective cohort (n = 554) evaluated bone fractures in inflammatory bowel disease patients using a corticosteroid or corticotrophin compared with non-users according to a chart review of patients seen at the hospital clinic between 1946 and 1965.^142^ A pathologic fracture was recorded in zero of 124 corticosteroid non-users compared with six of 430 corticosteroid users (1 percent).