# Additional Meta-Analyses

Figure 1 Pooled relative risk of remission^*^ * In all trials, remission was defined as a Crohn's Disease Activity Index less than 150. Boxes indicate individual trial point estimates. The box size denotes the weight of the trial, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95% confidence intervals for each trial. The diamond at the bottom of the graph indicates the 95% confidence interval for the random-effects pooled estimate. at week 2 comparing a TNF-alpha inhibitor with placebo by trials that allowed and did not allow prior TNF-alpha inhibitor use

ADA = adalimumab; CI = confidence interval; CP = certolizumab pegol; IFX = infliximab; RR = relative risk; TNF = tumor necrosis factor-alpha inhibitor

Test for heterogeneity: Q = 2.22 with 2 degrees of freedom (p = 0.33); Q = 3.54 with 3 degrees of freedom (p = 0.32); Q = 7.41 with 6 degrees of freedom (p = 0.29)

I-squared statistic = 10%; 15%; 19%

Figure1 is a forest plot type diagram depicting the pooled relative risk, with 95% confidence interval, of inducing remission at week 2 comparing a TNF-alpha inhibitor with placebo by trials that allowed and did not allow prior TNF-alpha inhibitor use. Seven trials are included, three which did not allow prior TNF-alpha inhibitor use are Hanauer 2006 with adalimumab, Sandborn 2011 with certolizumab pegol, Targan 1997 with infliximab, and four trials which allowed prior TNF-alpha inhibitor use are Sandborn 2007 with adalimumab, Schreiber 2005 with certolizumab pegol, Sandborn 2007 with certolizumab pegol, and Winter 2004 with certolizumab pegol. The information presented in the plot shows the relative risk with 95% confidence interval, number of people with events of remission with the TNF-alpha inhibitor, total number on a TNF-alpha inhibitor presented in the study, then number of events on placebo and total number on placebo in the study. The pooled relative risk for trials that did not allow prior TNF-alpha inhibitor use is 1.54, with a 95% confidence interval of 1.06 to 2.23. The pooled relative risk for trials that allowed prior TNF-alpha inhibitor use is 2.10, with a 95% confidence interval of 1.45 to 3.02. The overall pooled relative risk is 1.83, with a 95% confidence interval of 1.39 to 2.40. We did not find any substantial heterogeneity.