# Evidence Tables

(reference list located in full report)

Evidence Table 1 Number of studies and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for induction of remission (KQ1)

Evidence Table 2 Study design characteristics of randomized controlled trials reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in terms of inducing remission (KQ1)

Evidence Table 3 Population characteristics of randomized controlled trials reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in terms of inducing remission (KQ1)

Evidence Table 4 Effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in terms of inducing remission (KQ1)

Evidence Table 5 Quality of randomized controlled trials reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in terms of inducing remission (KQ1)

Evidence Table 6 Number of studies and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for maintenance of remission (KQ2)

Evidence Table 7 Study design characteristics of randomized controlled trials reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in terms of maintaining remission (KQ2)

Evidence Table 8 Population characteristics of randomized controlled trials reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in terms of maintaining remission (KQ2)

Evidence Table 9 Effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in terms of maintaining remission (KQ2)

Evidence Table 10 Study quality of randomized controlled trials reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in terms of maintaining remission (KQ2)

Evidence Table 11 Number of studies and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for safety (KQ3)

Evidence Table 12 Study design characteristics of randomized controlled trials and observational studies reporting on the safety of pharmacologic therapies for the management of moderate to severe Crohn's disease (KQ3)

Evidence Table 13 Population characteristics of randomized controlled trials and observational studies reporting on the safety of pharmacologic therapies for the management of moderate to severe Crohn's disease (KQ3)

Evidence Table 14 Safety of pharmacologic therapies for the management of Crohn's disease (KQ3)

Evidence Table 15 Quality of randomized controlled trials reporting on the safety of pharmacologic therapies for the management of moderate to severe Crohn's disease (KQ3)

Evidence Table 16 Quality of observational studies reporting on the safety of pharmacologic therapies for the management of moderate to severe Crohn's disease (KQ3)

Evidence Table 17 Study design characteristics of randomized controlled trials and observational studies reporting on the effectiveness of pharmacologic therapies to prevent post-operative recurrence in Crohn's disease in terms of patient-reported outcomes (KQ4)

Evidence Table 18 Population characteristics of randomized controlled trials and observational studies reporting on the effectiveness of pharmacologic therapies to prevent post-operative recurrence in Crohn's disease in terms of patient-reported outcomes (KQ4)

Evidence Table 19 Effectiveness of pharmacologic therapies to prevent post-operative recurrence in Crohn's disease in terms of patient-reported outcomes (KQ4)

Evidence Table 20 Quality of randomized controlled trials reporting on the effectiveness of pharmacologic therapies to prevent post-operative recurrence in Crohn's disease in terms of patient-reported outcomes (KQ4)

Evidence Table 21 Number of studies and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for the comparative effectiveness and safety of therapies among pediatrics

Evidence Table 22 Study design characteristics of randomized controlled trials and observational studies reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in children

Evidence Table 23 Population characteristics of randomized controlled trials and observational studies reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in children

Evidence Table 24 Outcomes from randomized controlled trials and observational studies reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in children

Evidence Table 25 Quality of randomized controlled trials reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in children

Evidence Table 26 Quality of observational studies reporting on the effectiveness of pharmacologic therapies for the management of moderate to severe Crohn's disease in children