# Excluded Articles

Aberra FN, Lewis JD, Hass D, Rombeau JL, Osborne B, Lichtenstein GR. Corticosteroids and immunomodulators: postoperative infectious complication risk in inflammatory bowel disease patients. Gastroenterology. 2003;125(2):320-7. Does not apply to key questions. [pmid: 12891531].
Aberra FN, Stettler N, Brensinger C, Lichtenstein GR, Lewis JD. Risk for active tuberculosis in inflammatory bowel disease patients. Clin Gastroenterol Hepatol. 2007;5(9):1070-5. Does not report side effects by medication class. [pmid: 17627901].
Abitbol V, Roux C, Chaussade S, Guillemant S, Kolta S, Dougados M, Couturier D, Amor B. Metabolic bone assessment in patients with inflammatory bowel disease. Gastroenterology. 95;108(2):417-22. Does not evaluate a drug of interest. [pmid: 7835582].
Achkar JP, Stevens T, Easley K, Brzezinski A, Seidner D, Lashner B. Indicators of clinical response to treatment with six-mercaptopurine or azathioprine in patients with inflammatory bowel disease. Inflamm Bowel Dis. 2004;10(4):339-45. Does not report side effects by medication class. [pmid: 15475740].
Acosta-Ramirez D, Pagan-Ocasio V, Torres EA, Rodriguez M, Caro O. Profile of the inflammatory bowel disease patient with depressive disorders. P R Health Sci J. 2001;20(3):215-20. Does not report side effects by medication class. [pmid: 11776721].
Actis GC, Rosina F. Outpatient care for inflammatory bowel disease at a primary referral hospital in Turin. Minerva Gastroenterol Dietol. 2010;56(1):27-34. Does not apply to key questions; other observational study without a comparison group. [pmid: 20190722].
Adamiak T, Stephens M, Werlin SL. Angioedema Occurring in Pediatric Patients With Crohn Disease Treated With Adalimumab. J Pediatr Gastroenterol Nutr. 2010. Does not apply to key questions.
Agnholt J, Dahlerup JF, Buntzen S, Tottrup A, Nielsen SL, Lundorf E. Response, relapse and mucosal immune regulation after infliximab treatment in fistulating Crohn's disease. Aliment Pharmacol Ther. 2003;17(5):703-10. Does not evaluate a drug of interestOther observational study without a comparison group. [pmid: 12641520].
Agrawal A, Durrani S, Leiper K, Ellis A, Morris AI, Rhodes JM. Effect of systemic corticosteroid therapy on risk for intra-abdominal or pelvic abscess in non-operated Crohn's disease. Clin Gastroenterol Hepatol. 2005;3(12):1215-20. Does not evaluate a drug of interest. [pmid: 16361047].
Ainsworth MA, Bendtzen K, Brynskov J. Tumor necrosis factor-alpha binding capacity and anti-infliximab antibodies measured by fluid-phase radioimmunoassays as predictors of clinical efficacy of infliximab in Crohn's disease. Am J Gastroenterol. 2008;103(4):944-8. Does not apply to key questions; does not report side effects by medication class. [pmid: 18028512].
Al Rifai A, Prasad N, Shuttleworth E, McBurney H, Pushpakom S, Robinson A, Newman W, Campbell S. Natural history of azathioprine-associated lymphopenia in inflammatory bowel disease patients: a prospective observational study. Eur J Gastroenterol Hepatol. 2011;23(2):153-8. Other observational study without a comparison groupOther reason. [pmid: 21164349].
Alcain G, Andrade RJ, Queipo de Llano MP, Moreno MJ, Garcia-Cortes M, Franquelo E. Acute leukemia after infliximab therapy. Am J Gastroenterol. 2003;98(11):2577. Case report or case series. [pmid: 14638375].
Allez M, Lemann M, Bonnet J, Cattan P, Jian R, Modigliani R. Long term outcome of patients with active Crohn's disease exhibiting extensive and deep ulcerations at colonoscopy. Am J Gastroenterol. 2002;97(4):947-53. Does not apply to key questions; does not report side effects by medication class. [pmid: 12003431].
Allez M, Vermeire S, Mozziconacci N, Michetti P, Laharie D, Louis E, Bigard MA, Hebuterne X, Treton X, Kohn A, Marteau P, Cortot A, Nichita C, van Assche G, Rutgeerts P, Lemann M, Colombel JF. The efficacy and safety of a third anti-TNF monoclonal antibody in Crohn's disease after failure of two other anti-TNF antibodies. Aliment Pharmacol Ther. 2010;31(1):92-101. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 19709098].
Allsop JR, Lee EC. Factors which influenced postoperative complications in patients with ulcerative colitis or Crohn's disease of the colon on corticosteroids. Gut. 78;19(8):729-34. Does not apply to key questions; other observational study without a comparison group. [pmid: 680605].
Ally MR, Veerappan GR, Koff JM. Treatment of recurrent Crohn's uveitis with infliximab. Am J Gastroenterol. 2008;103(8):2150-1. Case report or case series. [pmid: 18796120].
Almer SH, Hjortswang H, Hindorf U. 6-Thioguanine therapy in Crohn's disease--observational data in Swedish patients. Dig Liver Dis. 2009;41(3):194-200. Does not report side effects by medication class. [pmid: 18799369].
Alvarez Beltran M, Infante Pina D, Tormo Carnice R, Segarra Canton O, Redecillas Ferreiro S. Optimising azathioprine treatment: determination of thiopurine methyltransferase activity and thiopurine metabolites. An Pediatr (Barc). 2009;70(2):126-31. Not written in English. [pmid: 19217567].
Alzafiri R, Holcroft CA, Malolepszy P, Cohen A, Szilagyi A. Infliximab therapy for moderately severe Crohn's disease and ulcerative colitis: A retrospective comparison over 6 years. Clin. Exp. Gastroenterol. 2011;4(1):9-17. Does not evaluate a drug of interest. [pmid: 21694867].
Alzahrani M. Crohn's colitis in infancy. Ann. Saudi Med. 2003;23(3-4):198-200. Case report or case series. [pmid: 16985320].
Amiot A, Gornet JM, Baudry C, Munoz-Bongrand N, Auger M, Simon M, Allez M, Cattan P, Sarfati E, Lemann M. Crohn's disease recurrence after total proctocolectomy with definitive ileostomy. Dig Liver Dis. 2011. Does not evaluate a drug of interest.
Ananthakrishnan AN, McGinley EL, Binion DG. Inflammatory bowel disease in the elderly is associated with worse outcomes: a national study of hospitalizations. Inflamm Bowel Dis. 2009;15(2):182-9. Does not evaluate a drug of interest. [pmid: 18668678].
Andersson P, Olaison G, Bodemar G, Nystrom PO, Sjodahl R. Surgery for Crohn colitis over a twenty-eight-year period: fewer stomas and the replacement of total colectomy by segmental resection. Scand J Gastroenterol. 2002;37(1):68-73. Does not apply to key questions; does not report side effects by medication class. [pmid: 11843039].
Andoh A, Tsujikawa T, Ban H, Hashimoto T, Bamba S, Ogawa A, Sasaki M, Saito Y, Fujiyama Y. Monitoring 6-thioguanine nucleotide concentrations in Japanese patients with inflammatory bowel disease. J Gastroenterol Hepatol. 2008;23(9):1373-7. Does not apply to key questions; other observational study without a comparison group. [pmid: 18662197].
Andus T, Gross V, Caesar I, Schulz HJ, Lochs H, Strohm WD, Gierend M, Weber A, Ewe K, Scholmerich J. Replacement of conventional glucocorticoids by oral pH-modified release budesonide in active and inactive Crohn's disease: results of an open, prospective, multicenter trial. Dig Dis Sci. 2003;48(2):373-8. Does not evaluate a drug of interest; pther observational study without a comparison group. [pmid: 12643618].
Annunziata ML, Bossa F, Bozzi R, Caprioli F, Cassinotti A, Costantino G, Fiorino G, Onali S, Principi M, Renna S, Tambasco R. The Italian clinical experience with adalimumab in Crohn's disease: Eleven clinical cases. Dig. Liver Dis. Suppl. 2010;4(1):1-3. Other observational study without a comparison group.
Ansari A, Arenas M, Greenfield SM, Morris D, Lindsay J, Gilshenan K, Smith M, Lewis C, Marinaki A, Duley J, Sanderson J. Prospective evaluation of the pharmacogenetics of azathioprine in the treatment of inflammatory bowel disease. Aliment Pharmacol Ther. 2008;28(8):973-83. Does not report side effects by medication class. [pmid: 18616518].
Ansari A, Elliott T, Fong F, Arenas-Hernandez M, Rottenberg G, Portmann B, Lucas S, Marinaki A, Sanderson J. Further experience with the use of 6-thioguanine in patients with Crohn's disease. Inflamm Bowel Dis. 2008;14(10):1399-405. Does not evaluate a drug of interest. [pmid: 18521912].
Ansari A, Patel N, Sanderson J, O'Donohue J, Duley JA, Florin TH. Low-dose azathioprine or mercaptopurine in combination with allopurinol can bypass many adverse drug reactions in patients with inflammatory bowel disease. Aliment Pharmacol Ther. 2010;31(6):640-7. Other observational study without a comparison group. [pmid: 20015102].
Anthonisen P, Barany F, Folkenborg O, Holtz A, Jarnum S, Kristensen M, Riis P, Walan A, Worning H. The clinical effect of salazosulphapyridine (Salazopyrin r) in Crohn's disease. A controlled double-blind study. Scand J Gastroenterol. 74;9(6):549-54. Other observational study without a comparison group. [pmid: 4153646].
Antonija B, Babic Z, Marija G, Matek P. The role of sulfasalazine in the treatment of patients with inflammatory bowel disease with spondyloarthropathies. Croat. J. Gastroenterol. Hepatol. 96;5(2-3):31-34. Does not evaluate a drug of interest; does not report side effects by medication class.
Arden NK, Cooper C. Osteoporosis in patients with inflammatory bowel disease. Gut. 2002;50(1):9-10. No original data; does not report side effects by medication class. [pmid: 11772958].
Ardizzone S, Colombo E, Maconi G, Bollani S, Manzionna G, Petrone MC, Bianchi Porro G. Infliximab in treatment of Crohn's disease: the Milan experience. Dig Liver Dis. 2002;34(6):411-8. Other observational study without a comparison group. [pmid: 12132788].
Ardizzone S, Maconi G, Colombo E, Manzionna G, Bollani S, Bianchi Porro G. Perianal fistulae following infliximab treatment: clinical and endosonographic outcome. Inflamm Bowel Dis. 2004;10(2):91-6. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 15168807].
Ardizzone S, Maconi G, Sampietro GM, Russo A, Radice E, Colombo E, Imbesi V, Molteni M, Danelli PG, Taschieri AM, Bianchi Porro G. Azathioprine and mesalamine for prevention of relapse after conservative surgery for Crohn's disease. Gastroenterology. 2004;127(3):730-40. Does not apply to key questions. [pmid: 15362028].
Arnott ID, McDonald D, Williams A, Ghosh S. Clinical use of Infliximab in Crohn's disease: the Edinburgh experience. Aliment Pharmacol Ther. 2001;15(10):1639-46. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11564005].
Arnott ID, McNeill G, Satsangi J. An analysis of factors influencing short-term and sustained response to infliximab treatment for Crohn's disease. Aliment Pharmacol Ther. 2003;17(12):1451-7. Does not apply to key questionsOther observational study without a comparison group. [pmid: 12823146].
Arslan S, Kav T, Besisik F, Kaymakoglu S, Pinarbasi B, Tozun N, Hamzaoglu HO, Duman D, Ulker A, Parlak E, Palabiyikoglu M, Dokmeci A. Clinical outcome of Crohn's disease treated with infliximab. Hepatogastroenterology. 2003;50(52):952-6. Other observational study without a comparison group. [pmid: 12845957].
Asakura H, Yao T, Matsui T, Koganei K, Fukushima T, Takazoe M, Hobara R, Nakano H, Okamura S, Matsueda K, Kashida H, Makiyama K, Hiwatashi N, Kashiwagi K, Hibi T. Efficacy of treatment with chimeric monoclonal antibody (Infliximab) to tumor necrosis factor-alpha for Crohn's disease in Japan: evaluation by rapid turnover proteins, and radiologic and endoscopic findings. J Gastroenterol Hepatol. 2001;16(7):763-9. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 11446884].
Askling J, Brandt L, Lapidus A, Karlen P, Bjorkholm M, Lofberg R, et al. Risk of haematopoietic cancer in patients with inflammatory bowel disease. Gut. 2005;54(5):617-22. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 15831904].
Asteria CR, Ficari F, Bagnoli S, Milla M, Tonelli F. Treatment of perianal fistulas in Crohn's disease by local injection of antibody to TNF-alpha accounts for a favourable clinical response in selected cases: a pilot study. Scand J Gastroenterol. 2006;41(9):1064-72. Other observational study without a comparison group. [pmid: 16938720].
Atienza Amores MR, Martin-Garrido I, Garcia-Contreras R, Varela Aguilar JM. Alopecia as adverse reaction of mesalazine. Rev Clin Esp. 2009;209(3):153-4. Case report or case seriesNot written in English. [pmid: 19445856].
Avila Alvarez A, Solar Boga A, Garcia-Alonso L. Anti-TNF agents for the treatment of Crohn's disease. Agentes anti-TNF en el tratamiento de la enfermedad de Crohn. Acta Pediatr. Esp. 2010;68(1):19-24. Not written in English.
Azad Khan AK, Piris J, Truelove SC. An experiment to determine the active therapeutic moiety of sulphasalazine. Lancet. 77;2(8044):892-5. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; does not apply to key questions. [pmid: 72239].
Baars JE, Vogelaar L, Wolfhagen FH, Biermann K, Kuipers EJ, et al. A short course of corticosteroids prior to surveillance colonoscopy to decrease mucosal inflammation in inflammatory bowel disease patients: results from a randomized controlled trial. J Crohns Colitis. 2010;4(6):661-8. Does not apply to key questions. [pmid: 21122577].
Baert FJ, D'Haens GR, Peeters M, Hiele MI, Schaible TF, Shealy D, et al. Tumor necrosis factor alpha antibody (infliximab) therapy profoundly down-regulates the inflammation in Crohn's ileocolitis. Gastroenterology. 99;116(1):22-8. Does not apply to key questions. [pmid: 9869598].
Baert F, Moortgat L, Van Assche G, Caenepeel P, Vergauwe P, De Vos M, et al. Mucosal healing predicts sustained clinical remission in patients with early-stage Crohn's disease. Gastroenterology. 2010;138(2):463-8. quiz e10-1. Does not apply to key questions; other reason. [pmid: 19818785].
Baldassano RN. Infliximab in pediatric Crohn's disease patients. Gastroenterol. Hepatol. 2006;2(7):467. No original data.
Baldassano R, Braegger CP, Escher JC, DeWoody K, Hendricks DF, Keenan GF, et al. Infliximab (REMICADE) therapy in the treatment of pediatric Crohn's disease. Am J Gastroenterol. 2003;98(4):833-8. Other observational study without a comparison group. [pmid: 12738464].
Ban H, Andoh A, Tanaka A, Tsujikawa T, Sasaki M, Saito Y, et al. Analysis of thiopurine S-methyltransferase genotypes in Japanese patients with inflammatory bowel disease. Intern Med. 2008;47(19):1645-8. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18827410].
Banovic I, Gilibert D, Cosnes J. Perception of improved state of health and subjective quality of life in Crohn's disease patients treated with Infliximab. J. Crohn's Colitis. 2009;3(1):25-31. Does not apply to key questions; other observational study without a comparison group. [pmid: 21172244].
Barabino A, Torrente F, Ventura A, Cucchiara S, Castro M, Barbera C. Azathioprine in paediatric inflammatory bowel disease: an Italian multicentre survey. Aliment Pharmacol Ther. 2002;16(6):1125-30. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 12030954].
Baron TH, Truss CD, Elson CO. Low-dose oral methotrexate in refractory inflammatory bowel disease. Dig Dis Sci. 93;38(10):1851-6. Other observational study without a comparison group. [pmid: 8404406].
Baryshnikov EN, Lazebnik LB, Parfenov AI. Adalimumab therapy in Crohn's disdease. Eksp Klin Gastroenterol. 2009;(5):92-8. Not written in English. [pmid: 20205331].
Bastida Paz G, Nos Mateu P, Aguas Peris M, Beltran Niclos B, Rodriguez Soler M, Ponce Garcia J. Optimization of immunomodulatory treatment with azathioprine or 6-mercaptopurine in inflammatory bowel disease. Gastroenterol Hepatol. 2007;30(9):511-6. Not written in English. [pmid: 17980127].
Bastida G, Munoz F. Systemic corticosteroids in inflammatory bowel disease: are they really effective. What is their real toxicity?. Gastroenterol Hepatol. Suppl 3. 2008;31:3-9. Not written in English. [pmid: 19087857].
Bastida G, Nos P, Aguas M, Beltran B, Iborra M, et al. The effects of thiopurine therapy on health-related quality of life in Inflammatory Bowel Disease patients. BMC Gastroenterol. 2010;10:26. Does not report side effects by medication class. [pmid: 20196836].
Bastida G, Nos P, Aguas M, Beltran B, Rubin A, et al. Incidence, risk factors and clinical course of thiopurine-induced liver injury in patients with inflammatory bowel disease. Aliment Pharmacol Ther. 2005;22(9):775-82. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 16225485].
Bauditz J, Lochs H, Schreiber S. Chimeric monoclonal antibody cA2 to tumor necrosis factor alpha for Crohn's disease. N Engl J Med. 98;338(5):334. No original data. [pmid: 9446035].
Baumgart DC, Grittner U, Steingraber A, Azzaro M, Philipp S. Frequency, phenotype, outcome, and therapeutic impact of skin reactions following initiation of adalimumab therapy: Experience from a consecutive cohort of inflammatory bowel disease patients. Inflamm Bowel Dis. 2011. Other observational study without a comparison group; does not report side effects by medication class.
Beattie RM, Walker-Smith JA. Use of enteric coated prednisolone in Crohn's disease. Arch Dis Child. 94;71(3):282. Case report or case series. [pmid: 7979514].
Belaiche J, Desager JP, Horsmans Y, Louis E. Therapeutic drug monitoring of azathioprine and 6-mercaptopurine metabolites in Crohn disease. Scand J Gastroenterol. 2001;36(1):71-6. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11218242].
Bell SJ, Halligan S, Windsor AC, Williams AB, Wiesel P, Kamm MA. Response of fistulating Crohn's disease to infliximab treatment assessed by magnetic resonance imaging. Aliment Pharmacol Ther. 2003;17(3):387-93. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 12562451].
Bellizzi A, Anzivino E, Ferrari F, Di Nardo G, Colosimo MT, Fioriti D, et al. Polyomavirus JC reactivation and noncoding control region sequence analysis in pediatric Crohn's disease patients treated with infliximab. J Neurovirol. 2011. Does not evaluate a drug of interest; does not apply to key questions.
Benavente L, Moris G. Neurologic disorders associated with inflammatory bowel disease. Eur. J. Neurol. 2011;18(1):138-143. Does not apply to key questions. [pmid: 20500801].
Bendano T, Frisancho O. Clinical and evolutive profile of Crohn's disease in Hospital Rebagliati (Lima-Peru). Perfil Clinico y Evolutivo de la Enfermedad de Crohn en el Hospital Rebagliati (Lima-Peru). Rev Gastroenterol Peru. 2010;30(1):17-24. Not written in English. [pmid: 20445720].
Berger JR, Houff SA. Neurological infections: the year of PML and influenza. Lancet Neurol. 2010;9(1):14-17. No original data. [pmid: 20083028].
Bermejo F, Lopez San Roman A, Algaba A, van Domselaar M, Carneros JA, Rivero M, Piqueras B, et al. Efficacy of premedication with intravenous corticosteroids and antihistaminics in preventing infusion reactions to infliximab. Gastroenterol Hepatol. 2008;31(10):629-32. Not written in English. [pmid: 19174078].
Bermejo F, Lopez-Sanroman A, Algaba A, Van-Domselaar M, Gisbert JP, Garcia-Garzon S, et al. Mercaptopurine rescue after azathioprine-induced liver injury in inflammatory bowel disease. Aliment Pharmacol Ther. 2010;31(1):120-4. Other observational study without a comparison group. [pmid: 19709096].
Bermejo F, Lopez-Sanroman A, Taxonera C, Gisbert JP, Perez-Calle JL, Vera I, et al. Acute pancreatitis in inflammatory bowel disease, with special reference to azathioprine-induced pancreatitis. Aliment Pharmacol Ther. 2008;28(5):623-8. Does not report side effects by medication class. [pmid: 18513380].
Bernklev T, Jahnsen J, Schulz T, Sauar J, Lygren I, Henriksen M, et al. Course of disease, drug treatment and health-related quality of life in patients with inflammatory bowel disease 5 years after initial diagnosis. Eur J Gastroenterol Hepatol. 2005;17(10):1037-45. Does not apply to key questions; does not report side effects by medication class. [pmid: 16148548].
Bernstein CN, Artinian L, Anton PA, Shanahan F. Low-dose 6-mercaptopurine in inflammatory bowel disease is associated with minimal hematologic toxicity. Dig Dis Sci. 94;39(8):1638-41. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 8050312].
Bernstein CN, Blanchard JF, Kliewer E, Wajda A. Cancer risk in patients with inflammatory bowel disease: a population-based study. Cancer. 2001;91(4):854-62. Does not report side effects by medication class. [pmid: 11241255].
Bernstein CN, Seeger LL, Sayre JW, Anton PA, Artinian L, Shanahan F. Decreased bone density in inflammatory bowel disease is related to corticosteroid use and not disease diagnosis. J Bone Miner Res. 95;10(2):250-6. Other reason. [pmid: 7754804].
Besnard M, Jaby O, Mougenot JF, Ferkdadji L, Debrun A, Faure C, et al. Postoperative outcome of Crohn's disease in 30 children. Gut. 98;43(5):634-8. Does not apply to key questions. [pmid: 9824343].
Biancone L, Cretella M, Tosti C, Palmieri G, Petruzziello C, Geremia A, et al. Local injection of infliximab in the postoperative recurrence of Crohn's disease. Gastrointest Endosc. 2006;63(3):486-92. Other observational study without a comparison group. [pmid: 16500402].
Biancone L, Pavia M, Del Vecchio Blanco G, D'Inca R, Castiglione F, De Nigris F, et al. Hepatitis B and C virus infection in Crohn's disease. Inflamm Bowel Dis. 2001;7(4):287-94. Does not apply to key questions; does not report side effects by medication class. [pmid: 11720317].
Binion DG. Biologic Therapies for Crohn's Disease: Update from the 2009 ACG Meeting. Gastroenterol Hepatol (N Y). 2010;6(1 Suppl 1):4-16. No original data. [pmid: 20567545].
Birnie GG, McLeod TI, Watkinson G. Incidence of sulphasalazine-induced male infertility. Gut. 81;22(6):452-5. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 6114898].
Bischoff A. Drug therapy of Crohn's disease: slowly increase or start aggressively right away?. MMW Fortschr Med. 2010;152(1-2):20. No original data; not written in English.
Blomqvist P, Feltelius N, Lofberg R, Ekbom A. A 10-year survey of inflammatory bowel diseases-drug therapy, costs and adverse reactions. Aliment Pharmacol Ther. 2001;15(4):475-81. Does not report side effects by medication class. [pmid: 11284775].
Blumenstein I, Herrmann E, Filmann N, Zosel C, Tacke W, Bock H, et al. Female patients suffering from inflammatory bowel diseases are treated less frequently with immunosuppressive medication and have a higher disease activity A subgroup analysis of a large multi-centre, prospective, internet-based study. J Crohns Colitis. 2011;5(3):203-210. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 21575882].
Bokemeyer B. Infiximab in an outpatient gastroenterological practice: Tolerance, prognostic parameters and cost-effectiveness. Infliximab in der gastroenterologischen fachpraxis: Vertraglichkeit, prognoseparameter und kosteneffektivitat. Verdauungskrankheiten. 2002;20(3):107-113. Not written in English.
Bonaz B, Boitard J, Marteau P, Lemann M, Coffin B, Flourie B, et al. Tioguanine in patients with Crohn's disease intolerant or resistant to azathioprine/mercaptopurine. Aliment Pharmacol Ther. 2003;18(4):401-8. Does not evaluate a drug of interest. [pmid: 12940925].
Bondesen S, Rasmussen SN, Rask-Madsen J, Nielsen OH, Lauritsen K, Binder VF, et al. 5-Aminosalicylic acid in the treatment of inflammatory bowel disease. Acta Med Scand. 87;221(3):227-42. No original data. [pmid: 3296672].
Bonnet N, Guis S, Koeppel MC, Roudier J, Grimaud JC, Jean-Pastor MJ, et al. Cutaneous events during anti-TNF alpha therapy: A prospective observational study of 41 cases. Evenements cutaneomuqueux au cours des traitements par anti-TNF alpha : etude observationnelle prospective de 41 cas. Ann. Dermatol. Venereol. 2010;137(1):12-20. Not written in English. [pmid: 20110063].
Boot AM, Bouquet J, Krenning EP, de Muinck Keizer-Schrama SM. Bone mineral density and nutritional status in children with chronic inflammatory bowel disease. Gut. 98;42(2):188-94. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 9536942].
Bordeianou L, Stein SL, Ho VP, Dursun A, Sands BE, Korzenik JR, Hodin RA. Immediate versus tailored prophylaxis to prevent symptomatic recurrences after surgery for ileocecal Crohn's disease?. Surgery (USA). 2011;149(1):72-78. Does not report side effects by medication class.
Borrelli O, Bascietto C, Viola F, Bueno de Mesquita M, Barbato M, Mancini V, Bosco S, Cucchiara S. Infliximab heals intestinal inflammatory lesions and restores growth in children with Crohn's disease. Dig Liver Dis. 2004;36(5):342-7. Does not report side effects by medication class. [pmid: 15191204].
Borrelli O, Cordischi L, Cirulli M, Paganelli M, Labalestra V, Uccini S, Russo PM, Cucchiara S. Polymeric diet alone versus corticosteroids in the treatment of active pediatric Crohn's disease: a randomized controlled open-label trial. Clin Gastroenterol Hepatol. 2006;4(6):744-53. Does not evaluate a drug of interest. [pmid: 16682258].
Boruchowicz A, Gallon P, Foissey D, Gower P, Gamblin C, Cuingnet P, Maunoury V, Cortot A, Colombel Frederic JF. Acute pancreatitis associated with corticosteroids in Crohn's disease. Pancreatite aigue associee a un traitement corticoide au cours de la maladie de Crohn. Gastroenterol. Clin. Biol. 2003;27(5):560-561. Not written in English. [pmid: 12843925].
Bossa F, Biscaglia G, Merla A, Terracciano F. Long-term remission with adalimumab in steroid-dependent Crohn's disease patients with multiple drug intolerances. Dig. Liver Dis. Suppl. 2010;4(1):7-9. Case report or case series.
Bossi A, Giuliani GE, Del Poggio P, Fenili D, Ragaini S. Uncoated versus coated 5-aminosalicylic acid in Crohn's disease. Lancet. 89;1(8632):276. Case report or case series. [pmid: 2563434].
Bouguen G, Trouilloud I, Siproudhis L, Oussalah A, Bigard MA, Bretagne JF, Peyrin-Biroulet L. Long-term outcome of non-fistulizing (ulcers, stricture) perianal Crohn's disease in patients treated with infliximab. Aliment Pharmacol Ther. 2009;30(7):749-56. Does not report side effects by medication class. [pmid: 19583709].
Bouhnik Y, Lemann M, Mary JY, Scemama G, Tai R, Matuchansky C, Modigliani R, Rambaud JC. Long-term follow-up of patients with Crohn's disease treated with azathioprine or 6-mercaptopurine. Lancet. 96;347(8996):215-9. Does not evaluate a drug of interest. [pmid: 8551879].
Boyle B, Mackner L, Ross C, Moses J, Kumar S, Crandall W. A single-center experience with methotrexate after thiopurine therapy in pediatric Crohn disease. J Pediatr Gastroenterol Nutr. 2010;51(6):714-7. Does not report side effects by medication class. [pmid: 20706154].
Bresci G, Parisi G, Bertoni M, Masolino P, Scatena F, Capria A. Does the initial location of Crohn's disease have an influence on the time-to-relapse in patients under maintenance treatment with oral mesalamine?. J Clin Gastroenterol. 2000;31(2):147-51. Does not apply to key questions. [pmid: 10993432].
Bresci G, Petrucci A, Banti S. 5-aminosalicylic acid in the prevention of relapses of Crohn's disease in remission: a long-term study. Int J Clin Pharmacol Res. 91;11(4):200-2. Does not report side effects by medication class. [pmid: 1813439].
Breynaert C, Ferrante M, Fidder H, Van Steen K, Noman M, Ballet V, et al. Tolerability of shortened infliximab infusion times in patients with inflammatory bowel diseases: a single-center cohort study. Am J Gastroenterol. 2011;106(4):778-85. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 21407184].
Briggs RC Jr. Five year follow-up study of sixty cases of inflammatory diseases treated with alternate day corticosteroid therapy. Ariz Med. 72;29(2):120-8. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; does not evaluate a drug of interest. [pmid: 5060616].
Brignola C, De Simone G, Belloli C, Iannone P, Belluzzi A, Gionchetti P, et al. Steroid treatment in active Crohn's disease: a comparison between two regimens of different duration. Aliment Pharmacol Ther. 94;8(4):465-8. Does not evaluate a drug of interest. [pmid: 7986973].
Brignola C, De Simone G, Iannone P, Belloli C, Evangelisti A, Campieri M, et al. Influence of steroid treatment's duration in patients with active Crohn's disease. Agents Actions. 92;(Spec No):C90-2. Does not evaluate a drug of interest.
Brooke BN, Cave DR, King DW. Place of azathioprine for Crohn's disease. Lancet. 76;1(7968):1041-2. Does not report side effects by medication class. [pmid: 57449].
Brooke BN, Javett SL, Davison OW. Further experience with azathioprine for Crohn's disease. Lancet. 70;2(7682):1050-3. Case report or case series; other observational study without a comparison group. [pmid: 4098349].
Brown CH, Achkar E. Azathioprine therapy for inflammatory bowel disease. A preliminary report. Am J Gastroenterol. 70;54(4):363-77. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 5478849].
Brown SL, Greene MH, Gershon SK, Edwards ET, Braun MM. Tumor necrosis factor antagonist therapy and lymphoma development: twenty-six cases reported to the Food and Drug Administration. Arthritis Rheum. 2002;46(12):3151-8. Case report or case series. [pmid: 12483718].
Brunasso AM, Laimer M, Massone C. Paradoxical reactions to targeted biological treatments: A way to treat and trigger?. Acta Derm Venereol. 2010;90(2):183-5. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; case report or case series. [pmid: 20169304].
Bujanover Y, Weiss B. Anti-tumor necrosis factor therapy for pediatric inflammatory bowel diseases. Isr Med Assoc J. 2008;10(8-9):634-9. No original data. [pmid: 18847168].
Buller HA. Objectives and outcomes in the conventional treatment of pediatric Crohn's disease. J Pediatr Gastroenterol Nutr. Suppl 1. 2001;33:S11-8. No original data. [pmid: 11685970].
Burakoff R, Barish CF, Riff D, Pruitt R, Chey WY, Farraye FA, et al. A phase 1/2A trial of STA 5326, an oral interleukin-12/23 inhibitor, in patients with active moderate to severe Crohn's disease. Inflamm Bowel Dis. 2006;12(7):558-65. Does not evaluate a drug of interest. [pmid: 16804392].
Burger DC, Florin TH. Peripheral neuropathy with infliximab therapy in inflammatory bowel disease. Inflamm Bowel Dis. 2009;15(12):1772. Case report or case series. [pmid: 19170193].
Burmester GR, Mease P, Dijkmans BA, Gordon K, Lovell D, Panaccione R, et al. Adalimumab safety and mortality rates from global clinical trials of six immune-mediated inflammatory diseases. Ann Rheum Dis. 2009;68(12):1863-9. No original data; other observational study without a comparison group. [pmid: 19147611].
Busam J, Berghaus D, Garbe WE. Oral high dose mesalazine treatment in Crohn's disease and ulcerative colitis. Verdauungskrankheiten. 96;14(2):60-67. Not written in English.
Cadahia V, Garcia-Carbonero A, Vivas S, Fuentes D, Nino P, Rebollo P, et al. Infliximab improves quality of life in the short-term in patients with fistulizing Crohn's disease in clinical practice. Rev Esp Enferm Dig. 2004;96(6):369-74. 374. 8. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 15230666].
Caesar I, Gross V, Roth M, Andus T, Schmidt C, Raedsch R, et al. Treatment of active and postactive ileal and colonic Crohn's disease with oral pH-modified-release budesonide. German Budesonide Study Group. Hepatogastroenterology. 97;44(14):445-51. Does not evaluate a drug of interestOther observational study without a comparison group. [pmid: 9164517].
Caesar I, Gross V, Roth M, Andus T, Schmidt C, Raedsch R, et al. Treatment of active Crohn's ileocolitis with oral pH-modified budesonide. Germany Budesonide Study Group. Z Gastroenterol. 95;33(5):247-50. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 7610691].
Cagnard B, Tosoni-Verlingue D, Tribut O, Moizard C, Bridoux-Henno L, Delaperriere N, et al. Advantages of different dosages of active metabolites in the follow-up of azathioprine treatment for Crohn disease. Arch Pediatr. Suppl 1. 2006;13:S67-8. Not written in English. [pmid: 17370399].
Campbell S, Ghosh S. Is neutropenia required for effective maintenance of remission during azathioprine therapy in inflammatory bowel disease?. Eur J Gastroenterol Hepatol. 2001;13(9):1073-6. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11564958].
Campieri M, Lanfranchi GA, Brignola C, Bazzochi G, Gionchetti P, Minguzzi MR, et al. 5-aminosalicylic acid for the treatment of inflammatory bowel diseases. Gastroenterology. 85;89(3):701-3. No original data. [pmid: 4018510].
Cao Q, Zhu Q, Shang Y, Gao M, Si J. Thiopurine methyltransferase gene polymorphisms in Chinese patients with inflammatory bowel disease. Digestion. 2009;79(1):58-63. Does not report side effects by medication class. [pmid: 19252404].
Caprilli R, Andreoli A, Capurso L, Corrao G, D'Albasio G, Gioieni A, et al. Oral mesalazine (5-aminosalicylic acid; Asacol) for the prevention of post-operative recurrence of Crohn's disease. Gruppo Italiano per lo Studio del Colon e del Retto (GISC). Aliment Pharmacol Ther. 94;8(1):35-43. Does not apply to key questions; other reason. [pmid: 8186345].
Caprilli R, Andreoli A, Capurso L, Corrao G, D'Albasio G, Gioieni A, et al. Oral mesalazine (5-aminosalicylic acid; Asacol) for the prevention of post-operative recurrence of Crohn's disease. ALIMENT. PHARMACOL. THER. 94;8(1):35-43. Other reason. [pmid: 8186345].
Carbone J, Gonzalez-Lara V, Sarmiento E, Chean C, Perez JL, Marin I, et al. Humoral and cellular monitoring to predict the development of infection in Crohn's disease patients beginning treatment with infliximab. Ann N Y Acad Sci. 2007;1107:346-55. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 17804562].
Card T, West J, Hubbard R, Logan RF. Hip fractures in patients with inflammatory bowel disease and their relationship to corticosteroid use: a population based cohort study. Gut. 2004;53(2):251-5. Other reason. [pmid: 14724159].
Carter MJ, Lobo AJ. Lack of effect of intravenous azathioprine on time to respond for steroid treated Crohn's disease. Gut. 2001;48(3):295-6. No original data. [pmid: 11171815].
Casellas F, Rodrigo L, Nino P, Pantiga C, Riestra S, Malagelada JR. Sustained improvement of health-related quality of life in Crohn's disease patients treated with infliximab and azathioprine for 4 years. Inflamm Bowel Dis. 2007;13(11):1395-400. Other observational study without a comparison group. [pmid: 17567874].
Casellas F, Vallano A, Malagelada JR. Leukopenia and thrombocytopenia as adverse effects of treatment with 5-aminosalicylic suppositories. J Clin Gastroenterol. 96;22(2):160-1. Case report or case series. [pmid: 8742664].
Cassinotti A, Fichera M, Ardizzone S, Porro GB. Is mucosal healing a predictor of decreased risk of Crohn's disease relapse after withdrawal of 1-year, successful adalimumab?. Dig. Liver Dis. Suppl. 2010;4(1):18-21. Case report or case series.
Castro M, Rossi L, Papadatou B, Bracci F, Knafelz D, Ambrosini MI, et al. Long-term treatment with autologous red blood cells loaded with dexamethasone 21-phosphate in pediatric patients affected by steroid-dependent Crohn disease. J Pediatr Gastroenterol Nutr. 2007;44(4):423-6. Does not evaluate a drug of interest. [pmid: 17414137].
Cattan P, Bonhomme N, Panis Y, Lemann M, Coffin B, Bouhnik Y, et al. Fate of the rectum in patients undergoing total colectomy for Crohn's disease. Br J Surg. 2002;89(4):454-9. Does not apply to key questions; does not report side effects by medication class. [pmid: 11952587].
Cattan S, Lemann M, Thuillier F, Bengoufa D, Rabian C, Ngo Y, et al. 6-mercaptopurine levels and study of blood lymphocyte subsets during azathioprine treatment of Crohn's disease. Gastroenterol Clin Biol. 98;22(2):160-7. Not written in English. [pmid: 9762190].
Caviglia R, Ribolsi M, Rizzi M, Emerenziani S, Annunziata ML, Cicala M. Maintenance of remission with infliximab in inflammatory bowel disease: efficacy and safety long-term follow-up. World J Gastroenterol. 2007;13(39):5238-44. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 17876895].
Cezard JP, Munck A, Mouterde O, Morali A, Lenaerts C, Lachaux A, et al. Prevention of recurrence by mesalamine (PENTASA) in pediatric Crohn's disease. A multicentric double blind trial. Journal of Pediatric Gastroenterology and Nutrition. 2003;36(4):542. Abstract only.
Cezard JP, Nouaili N, Talbotec C, Hugot JP, Gobert JG, Schmitz J, et al. A prospective study of the efficacy and tolerance of a chimeric antibody to tumor necrosis factors (remicade) in severe pediatric crohn disease. J Pediatr Gastroenterol Nutr. 2003;36(5):632-6. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 12717087].
Chalupna P, Lukas M, Kumsta M, Sebesta I. Effect of the activity of thiopurine methyltransfrase on the results of long-term immunosuppressive therapy with azathioprin (6-mercaptopurine) in patients with inflammatory bowel diseases. Ceska Slov. Gastroenterol. Hepatol. 2002;56(6):208-213. Not written in English.
Chande N, Abdelgadir I, Gregor J. The Safety and Tolerability of Methotrexate for Treating Patients With Crohn's Disease. J Clin Gastroenterol. 2011. Other observational study without a comparison group; does not report side effects by medication class.
Chaparro M, Panes J, Garcia V, Manosa M, Esteve M, Merino O, et al. Long-term durability of infliximab treatment in Crohn's disease and efficacy of dose “escalation” in patients losing response. J Clin Gastroenterol. 2011;45(2):113-8. Does not apply to key questions; does not report side effects by medication class. [pmid: 21242747].
Chapman P. Sulphasalazine and inflammatory bowel disease. N Z Med J. 87;100(822):257. No original data. [pmid: 2901061].
Chaudhary R, Ghosh S. Prediction of response to infliximab in Crohn's disease. Dig. Liver Dis. 2005;37(8):559-563. No original data. [pmid: 15893967].
Chebli JM, Gaburri PD, De Souza AF, Pinto AL, Chebli LA, Felga GE, et al. Long-term results with azathioprine therapy in patients with corticosteroid-dependent Crohn's disease: open-label prospective study. J Gastroenterol Hepatol. 2007;22(2):268-74. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17295882].
Chehade M, Benkov K. A multicenter trial of 6-mercaptopurine and prednisone in children with newly diagnosed Crohn disease. J Pediatr Gastroenterol Nutr. 2001;32(2):120-1. No original data; other reason. [pmid: 11321377].
Cheikh I, Ben Ammar A, Essid M, Azzouz M, Ettahri N, Krichene M, et al. Treatment and outcomes of Crohn's disease. Results of a multicentric and retrospectif Tunisian's study. Traitement et evolution de la maladie de crohn initialement non compliquee. Resultats d'une etude retrospective et multicentrique tunisienne. Tunis. Med. 2002;80(4):193-198. Not written in English. [pmid: 12416354].
Chen M, Xia B, Chen B, Guo Q, Li J, Ye M, Hu Z. N-acetyltransferase 2 slow acetylator genotype associated with adverse effects of sulphasalazine in the treatment of inflammatory bowel disease. Can J Gastroenterol. 2007;21(3):155-8. Does not apply to key questions; other reason. [pmid: 17377643].
Chevrel B. Acute and maintenance therapy of intestinal inflammatory disease with pentasa. LE PENTASA. TRAITEMENT D'ATTAQUE ET D'ENTRETIEN DES MALADIES INFLAMMATOIRES INTESTINALES. MED. CHIR. DIG. 89;18(7):431-436. Not written in English.
Chevrel B. Treatment of mild to moderate Crohn's disease by budesonide. Traitement des formes legeres a moderees de la maladie de Crohn par le budesonide. Med. Chir. Dig. 99;28(7-8):265-269. Not written in English.
Chong RY, Hanauer SB, Cohen RD. Efficacy of parenteral methotrexate in refractory Crohn's disease. Aliment Pharmacol Ther. 2001;15(1):35-44. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11136276].
Chopra A, Pardi DS, Loftus EV Jr, Tremaine WJ, Egan LJ, Faubion WA, et al. Budesonide in the treatment of inflammatory bowel disease: the first year of experience in clinical practice. Inflamm Bowel Dis. 2006;12(1):29-32. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 16374255].
Chouliaras G, Panayiotou J, Dimakou C, Pachoula J, Orfanou I, Chrousos GP, et al. Biological agents in paediatric inflammatory bowel disease: a clinical observation study from Greece. Acta Gastroenterol Belg. 2010;73(3):342-8. Does not report side effects by medication class. [pmid: 21086936].
Christodoulou D, Katsanos K, Baltayannis G, Tzabouras N, Tsianos EV. A report on efficacy and safety of azathioprine in a group of inflammatory bowel disease patients in northwest Greece. Hepatogastroenterology. 2003;50(52):1021-4. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 12845970].
Cino M, Greenberg GR. Bone mineral density in Crohn's disease: a longitudinal study of budesonide, prednisone, and nonsteroid therapy. Am J Gastroenterol. 2002;97(4):915-21. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 12003427].
Cocco AE, Pavlides GP. Fever due to azathioprine in the treatment of patients with an inflammatory bowel disease. Md State Med J. 77;26(6):61-2. Case report or case series. [pmid: 875479].
Cohen AD, Dreiher J, Birkenfeld S. Psoriasis associated with ulcerative colitis and Crohn's disease. J Eur Acad Dermatol Venereol. 2009;23(5):561-5. Does not apply to key questions. [pmid: 19207663].
Cohen RD. Efficacy and safety of repeated infliximab infusions for Crohn's disease: 1-year clinical experience. Inflamm Bowel Dis. Suppl 1. 2001;7:S17-22. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11380038].
Cohen RD, Lewis JR, Turner H, Harrell LE, Hanauer SB, Rubin DT. Predictors of adalimumab dose escalation in patients with crohn's disease at a tertiary referral center. Inflamm Bowel Dis. 2011. Does not apply to key questions; case report or case series.
Cohen RD, Tsang JF, Hanauer SB. Infliximab in Crohn's disease: first anniversary clinical experience. Am J Gastroenterol. 2000;95(12):3469-77. Other observational study without a comparison group. [pmid: 11151879].
Colbert C, Chavarria A, Berkelhammer C. Fulminant hepatic failure in chronic hepatitis B on withdrawal of corticosteroids, azathioprine and infliximab for Crohn's disease. Inflamm Bowel Dis. 2007;13(11):1453-4. Case report or case series. [pmid: 17600380].
Colli MV, Amaro TA, Pinto AL, Gaburri PD, Chebli JM. Azathioprine toxicity in Crohn's disease: incidence, approach and course. Rev Assoc Med Bras. 2008;54(5):415-21. Not written in English. [pmid: 18989561].
Colombel JF, Lomann M, Cassagnou M, Bouhnik Y, Duclos B, Dupas JL, et al. Ciprofloxacin Vs Mesalazine in the Treatment of Active Crohn's Disease [abstract]. Gut. Suppl 3. 96;39:A188. Abstract only.
Colombel JF, Loftus EV Jr, Tremaine WJ, Pemberton JH, Wolff BG, Young-Fadok T, et al. Early postoperative complications are not increased in patients with Crohn's disease treated perioperatively with infliximab or immunosuppressive therapy. Am J Gastroenterol. 2004;99(5):878-83. Does not apply to key questions. [pmid: 15128354].
Colombel JF, Ricart E, Loftus EV Jr, Tremaine WJ, Young-Fadok T, Dozois EJ, et al. Management of Crohn's disease of the ileoanal pouch with infliximab. Am J Gastroenterol. 2003;98(10):2239-44. Other observational study without a comparison group. [pmid: 14572574].
Colombel JF, Sandborn WJ, Panaccione R, Robinson AM, Lau W, Li J, Cardoso AT. Adalimumab safety in global clinical trials of patients with Crohn's disease. Inflamm Bowel Dis. 2009;15(9):1308-19. No original data. [pmid: 19434735].
Colonna T, Korelitz BI. The role of leukopenia in the 6-mercaptopurine-induced remission of refractory Crohn's disease. Am J Gastroenterol. 94;89(3):362-6. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 8122645].
Condino AA, Fidanza S, Hoffenberg EJ. A home infliximab infusion program. J Pediatr Gastroenterol Nutr. 2005;40(1):67-9. Does not report side effects by medication class. [pmid: 15625429].
Connell WR, Kamm MA, Dickson M, Balkwill AM, Ritchie JK, Lennard-Jones JE. Long-term neoplasia risk after azathioprine treatment in inflammatory bowel disease. Lancet. 94;343(8908):1249-52. Does not evaluate a drug of interest. [pmid: 7910274].
Connell WR, Kamm MA, Ritchie JK, Lennard-Jones JE. Bone marrow toxicity caused by azathioprine in inflammatory bowel disease: 27 years of experience. Gut. 93;34(8):1081-5. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 8174958].
Cortot A, Colombel JF, Rutgeerts P, Lauritsen K, Malchow H, Haming J, et al. Safety of switching systemic steroids to budesonide controlled ileal release capsules in steroid-dependent patients with inactive crohns disease [abstract]. GUT. 2000;47(Suppl III A243):939. Abstract only.
Cortot A, Colombel JF, Rutgeerts P, Lauritsen K, Malchow H, Hamling J, et al. Switch from systemic steroids to budesonide controlled ileal release (CIR) capsules in steroid-dependent patients with Crohn's disease (CD)[abstract]. GUT. 99;45(Suppl V):A22. Abstract only.
Cosnes J, Nion-Larmurier I, Beaugerie L, Afchain P, Tiret E, Gendre JP. Impact of the increasing use of immunosuppressants in Crohn's disease on the need for intestinal surgery. Gut. 2005;54(2):237-41. Does not apply to key questions. [pmid: 15647188].
Costantino G, Navarra G, Familiari L, Fries W. Prevention of post-surgical recurrence with adalimumab in a patient with complicated Crohn's disease. Dig. Liver Dis. Suppl. 2010;4(1):22-24. Case report or case series.
Cottone M, Mocciaro F, Scimeca D. Adalimumab induction for Crohn's disease. Gastroenterology. 2006;130(6):1929. No original data. [pmid: 16697762].
Cottone M, Renna S. IBD: incidence of HSV and HPV with azathioprine. Nat Rev Gastroenterol Hepatol. 2009;6(8):444-5. No original data. [pmid: 19654597].
Cottone M, Orlando A, Mocciaro F. Improving patients' QoL: how the success of treatment can improve workability. Dig. Liver Dis. Suppl. 2008;2(1):17-18. No original data.
Crandall WV, Mackner LM. Infusion reactions to infliximab in children and adolescents: frequency, outcome and a predictive model. Aliment Pharmacol Ther. 2003;17(1):75-84. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 12492735].
Crandall W, Hyams J, Kugathasan S, Griffiths A, Zrubek J, et al. Infliximab therapy in children with concurrent perianal Crohn disease: observations from REACH. J Pediatr Gastroenterol Nutr. 2009;49(2):183-90. Does not evaluate a drug of interest. [pmid: 19561542].
Cravo M, Guerreiro CS, Dos Santos PM, Brito M, Ferreira P, Fidalgo C, et al. Risk factors for metabolic bone disease in Crohn's disease patients. Inflammatory Bowel Dis. 2010;16(12):2117-2124. Does not apply to key questions.
Cross RK, Lapshin O, Finkelstein J. Patient subjective assessment of drug side effects in inflammatory bowel disease. J. Clin. Gastroenterol. 2008;42(3):244-251. Does not apply to key questions; does not report side effects by medication class. [pmid: 18223502].
Cuffari C, Dassopoulos T, Turnbough L, Thompson RE, Bayless TM. Thiopurine methyltransferase activity influences clinical response to azathioprine in inflammatory bowel disease. Clin Gastroenterol Hepatol. 2004;2(5):410-7. Does not report side effects by medication class. [pmid: 15118980].
Cummings JR, Keshav S, Travis SP. Medical management of Crohn's disease. BMJ. 2008;336(7652):1062-6. No original data. [pmid: 18467414].
Curtis JR, Kramer JM, Martin C, Saag KG, Patkar N, Shatin D, et al. Heart failure among younger rheumatoid arthritis and Crohn's patients exposed to TNF-alpha antagonists. Rheumatology (Oxford). 2007;46(11):1688-93. Does not report side effects by medication class. [pmid: 17938138].
Curtis JR, Martin C, Saag KG, Patkar NM, Kramer J, Shatin D, et al. Confirmation of administrative claims-identified opportunistic infections and other serious potential adverse events associated with tumor necrosis factor alpha antagonists and disease-modifying antirheumatic drugs. Arthritis Rheum. 2007;57(2):343-6. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 17330283].
Cury DB, Moss AC. Ocular manifestations in a community-based cohort of patients with inflammatory bowel disease. Inflamm Bowel Dis. 2009. Does not report side effects by medication class.
Cury DB, Moss AC, Elias G, Nakao A. Adalimumab for cutaneous metastatic Crohn's disease. Inflamm Bowel Dis. 2010;16(5):723-4. Case report or case series. [pmid: 19728388].
Czaja-Bulsa G, Gebala A, Korlatowicz-Bilar A. The impact of infliximab treatment on mucosal healing and clinical remission in pediatric patients with severe crohn's disease in the own observation. Pediatr. Wspolczesna. 2010;12(2):104-107. Not written in English.
Dacute Haens GR, Van deventer SJH, Van Hogezand R, Chalmers DM, Braakman TAJ, Bijl H, Rutgeerts PJ. Endoscopic Healing with cA2 Anti-TNF Antibodies in Crohn's Disease: A European Multicenter Trial.(abstrac). Endoscopy. 96;28:S31. Abstract only.
Danese S, Mocciaro F, Guidi L, Scribano ML, Comberlato M, Annese V, et al. Successful induction of clinical response and remission with certolizumab pegol in Crohn's disease patients refractory or intolerant to infliximab: a real-life multicenter experience of compassionate use. Inflamm Bowel Dis. 2008;14(8):1168-70. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18357580].
Daperno M, Sostegni R, Canaparo R, Serpe L, Lavagna A, Crocella L, et al. Prospective study of the effects of concomitant medications on thiopurine metabolism in inflammatory bowel disease. Aliment Pharmacol Ther. 2009;30(8):843-53. Does not report side effects by medication class. [pmid: 19650826].
Dayharsh GA, Loftus EV Jr, Sandborn WJ, Tremaine WJ, Zinsmeister AR, Witzig TE, et al. Epstein-Barr virus-positive lymphoma in patients with inflammatory bowel disease treated with azathioprine or 6-mercaptopurine. Gastroenterology. 2002;122(1):72-7. Case report or case series; other observational study without a comparison group. [pmid: 11781282].
De Bie CI, Hummel TZ, Kindermann A, Kokke FT, Damen GM, Kneepkens CM, et al. The duration of effect of infliximab maintenance treatment in paediatric Crohn's disease is limited. Aliment Pharmacol Ther. 2011;33(2):243-50. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 21083595].
de Boer NK, Zondervan PE, Gilissen LP, den Hartog G, Westerveld BD, Derijks LJ, et al. Absence of nodular regenerative hyperplasia after low-dose 6-thioguanine maintenance therapy in inflammatory bowel disease patients. Dig Liver Dis. 2008;40(2):108-13. Does not evaluate a drug of interestDoes not apply to key questions. [pmid: 18083079].
De Iudicibus S, Stocco G, Martelossi S, Drigo I, Norbedo S, Lionetti P, et al. Association of BclI polymorphism of the glucocorticoid receptor gene locus with response to glucocorticoids in inflammatory bowel disease. Gut. 2007;56(9):1319-20. Does not evaluate a drug of interest. [pmid: 17698869].
de Jong DJ, Bac DJ, Tan G, de Boer SY, Grabowsky IL, Jansen JB, et al. Maintenance treatment with budesonide 6 mg versus 9 mg once daily in patients with Crohn's disease in remission. Neth J Med. 2007;65(9):339-45. Does not report side effects by medication class; other reason. [pmid: 17954953].
de Jong DJ, Goullet M, Naber TH. Side effects of azathioprine in patients with Crohn's disease. Eur J Gastroenterol Hepatol. 2004;16(2):207-12. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 15075996].
de Jong DJ, Mannaerts L, van Rossum LG, Corstens FH, Naber AH. Longitudinal study of bone mineral density in patients with Crohn's disease. Dig Dis Sci. 2003;48(7):1355-9. Does not apply to key questions; other observational study without a comparison group. [pmid: 12870795].
de Jong DJ, Tielen J, Habraken CM, Wetzels JF, Naber AH. 5-Aminosalicylates and effects on renal function in patients with Crohn's disease. Inflamm Bowel Dis. 2005;11(11):972-6. Does not report side effects by medication class. [pmid: 16239842].
De La Morena EJ, Abreu L, Garcia P, Pineda JR, Leal JC, Blasco M, et al. Treatment with 6-mercaptopurine in Crohn's disease. GASTROENTEROL. HEPATOL. 94;17(7):361-366. Not written in English.
de Ridder L, Escher JC, Taminiau JA. Infliximab therapy in children and adolescents with refractory Crohn's disease in the Netherlands; experience with 23 patients. Ned Tijdschr Geneeskd. 2002;146(40):1879-83. Not written in English. [pmid: 12395595].
de Ridder L, Escher JC, Bouquet J, Schweizer JJ, Rings EH, Tolboom JJ, et al. Infliximab therapy in 30 patients with refractory pediatric crohn disease with and without fistulas in The Netherlands. J Pediatr Gastroenterol Nutr. 2004;39(1):46-52. Does not evaluate a drug of interest. [pmid: 15187780].
de Ridder L, Rings EH, Damen GM, Kneepkens CM, Schweizer JJ, Kokke FT, et al. Infliximab dependency in pediatric Crohn's disease: long-term follow-up of an unselected cohort. Inflamm Bowel Dis. 2008;14(3):353-8. Does not report side effects by medication class. [pmid: 18069674].
de Saussure P, Lavergne-Slove A, Mazeron MC, Alain S, Matuchansky C, Bouhnik Y. A prospective assessment of cytomegalovirus infection in active inflammatory bowel disease. Aliment Pharmacol Ther. 2004;20(11-12):1323-7. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; does not report side effects by medication class. [pmid: 15606394].
Dejaco C, Mittermaier C, Reinisch W, Gasche C, Waldhoer T, Strohmer H, et al. Azathioprine treatment and male fertility in inflammatory bowel disease. Gastroenterology. 2001;121(5):1048-53. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11677195].
Del Corso L, Moruzzo D, Romanelli AM, Norpoth M, Pentimone F, Bresci G. 5-Aminosalicylic acid in the prevention of recurrences of Crohn's disease. Dtsch Med Wochenschr. 95;120(50):1723-7. Not written in English. [pmid: 8542807].
Demetriou AA. Comparison of enteral nutrition and drug treatment in active Crohn's disease: results of the European Cooperative Crohn's Disease Study IV. J Parenter Enteral Nutr. 92;16(1):84-5. Does not evaluate a drug of interest.
Denson LA, Kim MO, Bezold R, Carey R, Osuntokun B, Nylund C, et al. A Randomized Controlled Trial of Growth Hormone in Active Pediatric Crohn Disease. J Pediatr Gastroenterol Nutr. 2010. Does not evaluate a drug of interest.
Derijks LJ, Gilissen LP, Engels LG, Bos LP, Bus PJ, Lohman JJ, et al. Pharmacokinetics of 6-mercaptopurine in patients with inflammatory bowel disease: implications for therapy. Ther Drug Monit. 2004;26(3):311-8. Other observational study without a comparison group. [pmid: 15167634].
Derkx B, Taminiau J, Radema S, Stronkhorst A, Wortel C, Tytgat G, et al. Tumour-necrosis-factor antibody treatment in Crohn's disease. Lancet. 93;342(8864):173-4. Case report or case series. [pmid: 8101267].
Desmond AN, O'Regan K, Curran C, McWilliams S, Fitzgerald T, Maher MM, et al. Crohn's disease: factors associated with exposure to high levels of diagnostic radiation. Gut. 2008;57(11):1524-9. Does not apply to key questions; does not report side effects by medication class. [pmid: 18443021].
Deter HC, Keller W, von Wietersheim J, Jantschek G, Duchmann R, Zeitz M. Psychological treatment may reduce the need for healthcare in patients with Crohn's disease. Inflamm Bowel Dis. 2007;13(6):745-52. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 17230495].
Dew MJ, Evans BK, Rhodes J. 5-Aminosalicylic acid for the treatment of inflammatory bowel disease. Gastroenterology. 84;87(2):480-1. No original data. [pmid: 6735091].
D'Haens G, Rutgeerts P, Braakman T. Anti-tumor necrosis factor-alpha (cA2) induces remission and endoscopic healing in active Crohn's disease: A double-blind, placebo-controlled study. (ABSTRACT). Acta Gastroenterologica Belgica. 97;60(1). Abstract only.
D'Haens G, Verstraete A, Bouillon R, Rutgeerts P. Suppression of bone formation by short-term methylprednisolone but not by budesonide cir treatment in active ileocolonic Crohn's disease. (ABSTRACT). Acta Gastroenterologica Belgica. 97;60(1):C 34. Abstract only.
D'Haens G, Rutgeerts P. Immunosuppression-associated lymphoma in IBD. Lancet. 2009;374(9701):1572-1573. No original data. [pmid: 19837454].
D'Haens G, Geboes K, Rutgeerts P. Endoscopic and histologic healing of Crohn's (ileo-) colitis with azathioprine. Gastrointest Endosc. 99;50(5):667-71. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 10536324].
D'Haens G, Geboes K, Ponette E, Penninckx F, Rutgeerts P. Healing of severe recurrent ileitis with azathioprine therapy in patients with Crohn's disease. Gastroenterology. 97;112(5):1475-81. Does not apply to key questions; does not report side effects by medication class. [pmid: 9136824].
D'Haens G, Verstraete A, Cheyns K, Aerden I, Bouillon R, Rutgeerts P. Bone turnover during short-term therapy with methylprednisolone or budesonide in Crohn's disease. Aliment Pharmacol Ther. 98;12(5):419-24. Does not apply to key questions. [pmid: 9663720].
Dhawan SS, Finks AL, Wang BW. Mycobacterial coxitis masked by concomitant staphylococcal infection after infliximab for Crohn's disease. Joint Bone Spine. 2009;76(1):107-8. Case report or case series. [pmid: 18674947].
Dideberg V, Theatre E, Farnir F, Vermeire S, Rutgeerts P, De Vos M, et al. The TNF/ADAM 17 system: implication of an ADAM 17 haplotype in the clinical response to infliximab in Crohn's disease. Pharmacogenet Genomics. 2006;16(10):727-34. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 17001292].
Din S, Cochrane CJ, Noble CL, Satsangi J, Arnott ID. Combination therapy of infliximab and azathioprine reduces disease progression in Crohn's disease. Inflamm Bowel Dis. 2008;14(1):143-5. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17932978].
Din S, Dahele A, Fennel J, Aitken S, Shand AG, Arnott ID, et al. Use of methotrexate in refractory Crohn's disease: the Edinburgh experience. Inflamm Bowel Dis. 2008;14(6):756-62. Does not report side effects by medication class. [pmid: 18275071].
Dinca M, Fries W, Luisetto G, Peccolo F, Bottega F, Leone L, et al. Evolution of osteopenia in inflammatory bowel disease. Am J Gastroenterol. 99;94(5):1292-7. Does not report side effects by medication class. [pmid: 10235209].
Domenech E, Lopez San, Roman A, Garcia-Planella E. How long should combined therapy with biological and immunomodulatory agents be maintained in inflammatory bowel disease?. Gastroenterol Hepatol. 2010. No original data; not written in English.
Domenech E, Manosa M, Navarro M, Masnou H, Garcia-Planella E, Zabana Y, et al. Long-term methotrexate for Crohn's disease: safety and efficacy in clinical practice. J Clin Gastroenterol. 2008;42(4):395-9. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18277899].
Domenech E, Nos P, Papo M, Lopez-San Roman A, Garcia-Planella E, Gassull MA. 6-mercaptopurine in patients with inflammatory bowel disease and previous digestive intolerance of azathioprine. Scand J Gastroenterol. 2005;40(1):52-5. Does not evaluate a drug of interest; case report or case series. [pmid: 15841714].
Domenech E, Scala L, Bernal I, Garcia-Planella E, Casalots A, Pinol M, et al. Azathioprine and mesalazine in the prevention of postsurgical recurrence of Crohn's disease: a retrospective study. Gastroenterol Hepatol. 2004;27(10):563-7. Not written in English. [pmid: 15574279].
Donald IP, Wilkinson SP. The value of 5-aminosalicylic acid in inflammatory bowel disease for patients intolerant or allergic to sulphasalazine. Postgrad Med J. 85;61(722):1047-8. Other reason. [pmid: 2869480].
D'Ovidio V, Aratari A, Viscido A, Pimpo MT, Caprilli R, Torchio P. Infliximab and quality of life in steroid-dependent Crohn's disease. Dig Liver Dis. 2004;36(8):557-8. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 15334780].
D'Ovidio V, Vernia P, Gentile G, Capobianchi A, Marcheggiano A, Viscido A, et al. Cytomegalovirus infection in inflammatory bowel disease patients undergoing anti-TNFalpha therapy. J Clin Virol. 2008;43(2):180-3. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 18614396].
Dreyling KW, Hoppe U, Peskar BA, Schaarschmidt K, Peskar BM. Leukotrienes in Crohn's disease: effect of sulfasalazine and 5-aminosalicylic acid. Adv Prostaglandin Thromboxane Leukot Res. 87;17A:339-43. Does not apply to key questions; does not report side effects by medication class. [pmid: 2889333].
Drucker WR, Jeejeebhoy KN. Azathioprine: an adjunct to surgical therapy of granulomatous enteritis. Ann Surg. 70;172(4):618-26. Other observational study without a comparison group. [pmid: 5458618].
Dubinsky MC. Monitoring of AZA/6-MP treatment in children with IBD is necessary. Inflamm Bowel Dis. 2003;9(6):386-8. discussion 392-3. No original data. [pmid: 14671488].
Dubinsky MC, Feldman EJ, Abreu MT, Targan SR, Vasiliauskas EA. Thioguanine: a potential alternate thiopurine for IBD patients allergic to 6-mercaptopurine or azathioprine. Am J Gastroenterol. 2003;98(5):1058-63. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 12809828].
Dubinsky MC, Vasiliauskas EA, Singh H, Abreu MT, Papadakis KA, et al. 6-thioguanine can cause serious liver injury in inflammatory bowel disease patients. Gastroenterology. 2003;125(2):298-303. No original data; case report or case series. [pmid: 12891528].
Dubinsky MC, Yang H, Hassard PV, Seidman EG, Kam LY, Abreu MT, et al. 6-MP metabolite profiles provide a biochemical explanation for 6-MP resistance in patients with inflammatory bowel disease. Gastroenterology. 2002;122(4):904-15. Other observational study without a comparison group. [pmid: 11910342].
Ducharme J, Pelletier C, Zacharias R. The safety of infliximab infusions in the community setting. Can J Gastroenterol. 2010;24(5):307-11. No original data; other observational study without a comparison group. [pmid: 20485705].
Dudley-Brown S, Nag A, Cullinan C, Ayers M, Hass S, Panjabi S. Health-related quality-of-life evaluation of crohn disease patients after receiving natalizumab therapy. Gastroenterol Nurs. 2009;32(5):327-39. No original data. [pmid: 19820441].
Duricova D, Pedersen N, Elkjaer M, Jensen JK, Munkholm P. 5-aminosalicylic acid dependency in Crohn's disease: a Danish Crohn Colitis Database study. J Crohns Colitis. 2010;4(5):575-81. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 21122562].
Duricova D, Pedersen N, Lenicek M, Hradsky O, Bronsky J, Adamcova M, et al. Infliximab dependency in children with Crohn's disease. Aliment Pharmacol Ther. 2009;29(7):792-9. Does not report side effects by medication class. [pmid: 19183163].
East JE, Brooker JC, Rutter MD, Saunders BP. A pilot study of intrastricture steroid versus placebo injection after balloon dilatation of Crohn's strictures. Clin Gastroenterol Hepatol. 2007;5(9):1065-9. Does not apply to key questions. [pmid: 17627903].
Echarri A, Castro J, Barreiro M, Carpio D, Pereira S, Lorenzo A. Evaluation of adalimumab therapy in multidisciplinary strategy for perianal Crohn's disease patients with infliximab failure. J Crohns Colitis. 2010;4(6):654-60. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 21122576].
Egan LJ, Sandborn WJ, Tremaine WJ, Leighton JA, Mays DC, Pike MG, et al. A randomized dose-response and pharmacokinetic study of methotrexate for refractory inflammatory Crohn's disease and ulcerative colitis. Aliment Pharmacol Ther. 99;13(12):1597-604. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 10594394].
Eland IA, De Gooyer DJ, Stokkers P, Westerveld BD, Wilson JHP, Stricker BHC. Acute pancreatitis attributed to use of mesalazine. Tijdschr. Geneeskd. 98;54(6):417-420. Not written in English.
El-Nachef N, Terdiman J, Mahadevan U. Anti-tumor necrosis factor therapy for inflammatory bowel disease in the setting of immunosuppression for solid organ transplantation. Am J Gastroenterol. 2010;105(5):1210-1. Case report or case series. [pmid: 20445523].
Elseviers MM, D'Haens G, Lerebours E, Plane C, Stolear JC, Riegler G, et al. Renal impairment in patients with inflammatory bowel disease: association with aminosalicylate therapy?. Clin Nephrol. 2004;61(2):83-9. Does not report side effects by medication class. [pmid: 14989626].
Escher JC, van den Brink G, Kate FT, te Velde A, van Deventer S. Mucosal healing and down-regulation of inflammation with anti-tumor necrosis factor a (INFLIXIMAB) in children with refractory Crohn's disease. Journal of Pediatric Gastroenterology &amp; Nutrition. 2000;31(Suppl 2):S19. Abstract only.
Eshuis EJ, Bemelman WA, van Bodegraven AA, Sprangers MA, Bossuyt PM, van Milligen de Wit AW, et al. Laparoscopic ileocolic resection versus infliximab treatment of distal ileitis in Crohn's disease: a randomized multicenter trial (LIR!C-trial). BMC Surg. 2008;8:15. Other reason. [pmid: 18721465].
Eshuis EJ, Polle SW, Slors JF, Hommes DW, Sprangers MA, Gouma DJ, et al. Long-term surgical recurrence, morbidity, quality of life, and body image of laparoscopic-assisted vs. open ileocolic resection for Crohn's disease: a comparative study. Dis Colon Rectum. 2008;51(6):858-67. Does not evaluate a drug of interest. [pmid: 18266036].
Ezzat Y, Hamdy K. The frequency of low bone mineral density and its associated risk factors in patients with inflammatory bowel diseases. Int. J. Rheum. Dis. 2010;13(3):259-265. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 20704624].
Faber SM, Korelitz BI. Experience with Eudragit-S-coated mesalamine (Asacol) in inflammatory bowel disease. An open study. J Clin Gastroenterol. 93;17(3):213-8. Other observational study without a comparison group. [pmid: 8228082].
Fahrlaender H, Shalev E. Regional enteritis (Crohn's disease). A follow up and comparative study of 182 patients. Dtsch. Med. Wochenschr. 74;99(44):2207-2214. Not written in English. [pmid: 4154191].
Fanning SB, Chapman G, Yau Y, Leong RW. Education and imaging. Gastrointestinal: Improvement of granuloma annulare with anti-tumour necrosis factor alpha therapy for Crohn's disease. J Gastroenterol Hepatol. 2010;25(1):215. Does not apply to key questions; case report or case series. [pmid: 20136975].
Farrell RJ, Shah SA, Lodhavia PJ, Alsahli M, Falchuk KR, Michetti P, et al. Clinical experience with infliximab therapy in 100 patients with Crohn's disease. Am J Gastroenterol. 2000;95(12):3490-7. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11151882].
Faubion WA Jr, Loftus EV Jr, Harmsen WS, Zinsmeister AR, Sandborn WJ. The natural history of corticosteroid therapy for inflammatory bowel disease: a population-based study. Gastroenterology. 2001;121(2):255-60. Other observational study without a comparison group. [pmid: 11487534].
Fausa O, Gjone E. Azathioprine (Imurel) therapy in Crohn's disease. Acta Med Scand. 71;190(3):211-2. Case report or case series; other observational study without a comparison group. [pmid: 5120971].
Feagan B, Greenberg GR, Lofberg R, Ferguson A, Persson T. Budesonide controlled ileal release prolonged remission in Crohn's disease: A pooled analysis [abstract]. Gut. Suppl 3. 97;41:A1. Abstract only.
Feagan BG, Sandborn WJ, Baker JP, Cominellis F, Sutherland LR, Elson CO, et al. A randomized, double-blind, placebo-controlled trial of CDP571, a humanized monoclonal antibody to tumour necrosis factor-a, in patients with corticosteroid-dependent Crohn's disease. Alimentary Pharmacology & Therapeutics. 2005;21(4):373-84. Does not evaluate a drug of interest. [pmid: 15709987].
Feagan BG. Aminosalicylates for active disease and in the maintenance of remission in Crohn's disease. Eur J Surg. 98;164(12):903-9. No original data. [pmid: 10029385].
Feagan BG. Methotrexate treatment for Crohn's disease. Inflamm Bowel Dis. 98;4(2):120-1. No original data. [pmid: 9687221].
Feagan B. Infliximab in the treatment of Crohn's disease. Can J Gastroenterol. Suppl C. 2000;14:6C. No original data.
Feagins LA, Spechler SJ. Biologic agent use varies inversely with age at diagnosis in Crohn's disease. Dig Dis Sci. 2010;55(11):3164-70. Does not apply to key questions. [pmid: 20844954].
Fefferman DS, Lodhavia PJ, Alsahli M, Falchuk KR, Peppercorn MA, Shah SA, et al. Smoking and immunomodulators do not influence the response or duration of response to infliximab in Chrohn's disease. Inflammatory Bowel Dis. 2004;10(4):346-351. Does not apply to key questions; does not report side effects by medication class.
Felder JB, Adler DJ, Korelitz BI. The safety of corticosteroid therapy in Crohn's disease with an abdominal mass. Am J Gastroenterol. 91;86(10):1450-5. Case report or case series. [pmid: 1656728].
Felekis T, Katsanos K, Kitsanou M, Trakos N, Theopistos V, Christodoulou D, et al. Spectrum and frequency of ophthalmologic manifestations in patients with inflammatory bowel disease: a prospective single-center study. Inflamm Bowel Dis. 2009;15(1):29-34. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 18626979].
Ferlitsch A, Teml A, Reinisch W, Ulbrich G, Wrba F, Homoncik M, et al. 6-Thioguanine associated nodular regenerative hyperplasia in patients with inflammatory bowel disease may induce portal hypertension. Am. J. Gastroenterol. 2007;102(11):2495-2503. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 17894846].
Fernando del Rosario J, Orenstein SR, Neigut DA, Giarrusso V, Wolfson N, Kocoshis SA. Retrospective analysis of alternate-day prednisone maintenance therapy for Crohn's disease. Clin Pediatr (Phila). 98;37(7):413-9. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 9675434].
Fieschi C, Allez M, Casanova JL. High risk of infectious disease caused by salmonellae and mycobacteria infections in patients with Crohn disease treated with anti-interleukin-12 antibody. Clin Infect Dis. 2005;40(9):1381. No original data; does not evaluate a drug of interest. [pmid: 15825051].
Fiorino G, Allez M, Malesci A, Danese S. Review article: anti TNF-alpha induced psoriasis in patients with inflammatory bowel disease. Aliment Pharmacol Ther. 2009;29(9):921-7. No original data. [pmid: 19210297].
Fishman M. Methotrexate and maintenance of remission in Crohn's disease. Can J Gastroenterol. 2001;15(7):428. No original data. [pmid: 11493943].
Floren CH, Ahren B, Bengtsson M, Bartosik J, Obrant K. Bone mineral density in patients with Crohn's disease during long-term treatment with azathioprine. J Intern Med. 98;243(2):123-6. Does not apply to key questions. [pmid: 9566640].
Florent C, Cortot A, Quandale P, Sahmound T, Modigliani R, Sarfaty E, et al. Placebo-controlled clinical trial of mesalazine in the prevention of early endoscopic recurrences after resection for Crohn's disease. Groupe d'Etudes Therapeutiques des Affections Inflammatoires Digestives (GETAID). Eur J Gastroenterol Hepatol. 96;8(3):229-33. Does not apply to key questions. [pmid: 8724022].
Fogo AJ, Hunt JB, Clement M. Multiple cutaneous malignancies arising in a patient with Crohn disease treated with concomitant azathioprine and antitumour necrosis factor-alpha. Clin Exp Dermatol. 2010. Case report or case series.
Forbes A. Is there a role for multidrug therapy in active Crohn's disease?. Inflamm Bowel Dis. Suppl 2. 2008;14:S257-8. No original data. [pmid: 18816649].
Fournier MR, Klein J, Minuk GY, Bernstein CN. Changes in Liver Biochemistry During Methotrexate Use for Inflammatory Bowel Disease. Am J Gastroenterol. 2010. Does not apply to key questions; other observational study without a comparison group.
Francella A, Dyan A, Bodian C, Rubin P, Chapman M, Present DH. The safety of 6-mercaptopurine for childbearing patients with inflammatory bowel disease: a retrospective cohort study. Gastroenterology. 2003;124(1):9-17. Does not apply to key questions. [pmid: 12512024].
Franklin JL, Rosenberg HH. Impaired folic acid absorption in inflammatory bowel disease: effects of salicylazosulfapyridine (Azulfidine). Gastroenterology. 73;64(4):517-25. Does not apply to key questions. [pmid: 4144775].
Fraser AG, Morton D, McGovern D, Travis S, Jewell DP. The efficacy of methotrexate for maintaining remission in inflammatory bowel disease. Aliment Pharmacol Ther. 2002;16(4):693-7. Other observational study without a comparison group. [pmid: 11929386].
Fraser JS, Muller AF, Smith DJ, Newman DJ, Lamb EJ. Renal tubular injury is present in acute inflammatory bowel disease prior to the introduction of drug therapy. Aliment Pharmacol Ther. 2001;15(8):1131-7. Other observational study without a comparison group. [pmid: 11472315].
Friedman LS. Male infertility related to 5-ASA enemas. Dig Dis Sci. 89;34(5):803. No original data; does not report side effects by medication class. [pmid: 2565799].
Friesen CA, Calabro C, Christenson K, Carpenter E, Welchert E, Daniel JF, et al. Safety of infliximab treatment in pediatric patients with inflammatory bowel disease. J Pediatr Gastroenterol Nutr. 2004;39(3):265-9. Does not report side effects by medication class. [pmid: 15319627].
Fuentes D, Torrente F, Keady S, Thirrupathy K, Thomson MA, Walker-Smith JA, et al. High-dose azathioprine in children with inflammatory bowel disease. Aliment Pharmacol Ther. 2003;17(7):913-21. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 12656694].
Fuster Sanjurjo L, Salazar Laya B, Rodriguez Penin I, Lopez Sandomingo L, Dominguez Urbistondo G, Iglesias Barreira R. Quality of life in patients with Crohn's disease under treatment with adalimumab. Aten. Farm. 2010;12(6):375-378. Not written in English.
Gabalec L, Bures J, Sedova M, Valenta Z. Quality of life of Crohn's disease patients. Cas Lek Cesk. 2009;148(5):201-5. Not written in English. [pmid: 19642314].
Gaertner WB, Madoff RD, Spencer MP, Mellgren A, Goldberg SM, Lowry AC. Results of combined medical and surgical treatment of rectovaginal fistula in Crohn's disease. Colorectal Dis. 2010. Does not apply to key questions.
Garcia Vidal C, Rodriguez Fernandez S, Martinez Lacasa J, Salavert M, Vidal R, Rodriguez Carballeira M, et al. Paradoxical response to antituberculous therapy in infliximab-treated patients with disseminated tuberculosis. Clin Infect Dis. 2005;40(5):756-9. Case report or case series. [pmid: 15714425].
Garcia-Ferrer L, Estornell J, Palanca V. Myocarditis by mesalazine with cardiac magnetic resonance imaging. Eur Heart J. 2009;30(8):1015. Case report or case series. [pmid: 19168869].
Garcia-Vidal C, Rodriguez-Fernandez S, Teijon S, Esteve M, Rodriguez-Carballeira M, et al. Risk factors for opportunistic infections in infliximab-treated patients: the importance of screening in prevention. Eur J Clin Microbiol Infect Dis. 2009;28(4):331-7. Does not report side effects by medication class. [pmid: 18797940].
Gassull MA, Fernandez-Banares F, Cabre E, Papo M, Giaffer MH, Sanchez-Lombrana JL, et al. Fat composition may be a clue to explain the primary therapeutic effect of enteral nutrition in Crohn's disease: results of a double blind randomised multicentre European trial. Gut. 2002;51(2):164-8. Does not evaluate a drug of interest. [pmid: 12117873].
Gazouli M, Pachoula I, Panayotou I, Mantzaris G, Syriopoulou VP, Goutas N, et al. Thiopurine S-methyltransferase genotype and the use of thiopurines in paediatric inflammatory bowel disease Greek patients. J Clin Pharm Ther. 2010;35(1):93-7. Does not apply to key questions; does not report side effects by medication class. [pmid: 20175817].
Gearry RB, Barclay ML, Burt MJ, Collett JA, Chapman BA. Thiopurine drug adverse effects in a population of New Zealand patients with inflammatory bowel disease. Pharmacoepidemiol Drug Saf. 2004;13(8):563-7. Does not report side effects by medication class. [pmid: 15317038].
Gelb A, Zalusky R. The use of azathiaprine and 6-mercaptopurine (6-MP) as immunosuppressive therapy in inflammatory bowel disease and its role in the etiology of lymphocytic lymphoma. Am J Gastroenterol. 83;78(5):316. No original data; case report or case series. [pmid: 6687782].
Gelbmann CM, Rogler G, Gross V, Gierend M, Bregenzer N, Andus T, et al. Prior bowel resections, perianal disease, and a high initial Crohn's disease activity index are associated with corticosteroid resistance in active Crohn's disease. Am J Gastroenterol. 2002;97(6):1438-45. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 12094862].
Gellona VJ, Zarraonandia AA, Zuniga DA, Palma CR, Contreras PJ, Silva Ch J, et al. Infliximab in the treatment of patients with Crohn's disease. Preliminary report. Infliximab en el tratamiento de la enfermedad de Crohn. Estudio preliminar. Rev. Med. Chile. 2006;134(3):320-325. Not written in English. [pmid: 16676104].
Gellona VJ, Zarraonandia AA, Zuniga DA, Palma CR, Contreras PJ, Silva Ch J, et al. Infliximab in the treatment of patients with Crohn's disease: preliminary report. Rev Med Chil. 2006;134(3):320-5. Not written in English. [pmid: 16676104].
Generini S, Giacomelli R, Fedi R, Fulminis A, Pignone A, Frieri G, et al. Infliximab in spondyloarthropathy associated with Crohn's disease: an open study on the efficacy of inducing and maintaining remission of musculoskeletal and gut manifestations. Ann Rheum Dis. 2004;63(12):1664-9. Other observational study without a comparison group. [pmid: 15297279].
Geyer AS, Anhalt GJ, Nousari HC. Effectiveness of infliximab in the treatment of refractory perineal cutaneous Crohn disease. Arch Dermatol. 2000;136(4):459-60. Case report or case series. [pmid: 10768643].
Gheorghe L, Gheorghe C, Badea M, Vadan R, Parvulescu I, Toader C, et al. Infliximab for Crohn's disease in clinical practice: the experience of a single center in romania. Rom J Gastroenterol. 2003;12(1):7-13. Does not evaluate a drug of interest; other reason. [pmid: 12673373].
Ghosh S. Top down therapy in Crohn's disease. Dig. Liver Dis. Suppl. 2008;2(1):15-16. No original data.
Ghosh S, Goldin E, Gordon FH, Malchow HA, Rask-Madsen J, Rutgeerts P, et al. Natalizumab for active Crohn's disease. N Engl J Med. 2003;348(1):24-32. No original data. [pmid: 12510039].
Giaffer MH, O'Brien CJ, Holdsworth CD. Clinical tolerance to three 5-aminosalicylic acid releasing preparations in patients with inflammatory bowel disease intolerant or allergic to sulphasalazine. Aliment Pharmacol Ther. 92;6(1):51-9. Does not evaluate a drug of interest. [pmid: 1347468].
Gilissen LP, Derijks LJ, Bos LP, Bus PJ, Hooymans PM, Engels LG. Therapeutic drug monitoring in patients with inflammatory bowel disease and established azathioprine therapy. Clin Drug Investig. 2004;24(8):479-86. Does not apply to key questions.
Gilissen LP, Derijks LJ, Driessen A, Bos LP, Hooymans PM, Stockbrugger RW, et al. Toxicity of 6-thioguanine: no hepatotoxicity in a series of IBD patients treated with long-term, low dose 6-thioguanine. Some evidence for dose or metabolite level dependent effects?. Dig Liver Dis. 2007;39(2):156-9. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 17188950].
Gill AM, Otaki AT, Daly JR, Spencer-Peet J. Oral Betamethasone 17-Valerate in Chronic Ulcerative Colitis and Crohn's Disease. Br Med J. 65;2(5452):29-31. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 14305348].
Ginard D, Marino Z. Inflammatory bowel disease: should all patients be premedicated when infliximab is administered to reduce infusion reactions and/or immunogenicity?. Gastroenterol Hepatol. 2008;31(8):542-3. No original dataNot written in English. [pmid: 18928758].
Gionchetti P, Campieri M, Belluzzi A, Boschi S, Brignola C, Miglioli M, et al. Bioavailability of single and multiple doses of a new oral formulation of 5-ASA in patients with inflammatory bowel disease and healthy volunteers. Aliment Pharmacol Ther. 94;8(5):535-40. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 7865646].
Gionchetti P, Tambasco R, Campieri M. How do biological drugs meet treatment goals in anti-TNF naive patients, in patients with anti-TNF failure and in fistulizing patients?. Dig. Liver Dis. Suppl. 2008;2(1):13-14. No original data.
Girodengo L, Barthet M, Desjeux A, Berdah S, Berthezene P, Bellon P, et al. Risk factors for Crohn's disease relapse after treatment of intestinal stenosis. Ann Chir. 2001;126(4):296-301. Not written in English. [pmid: 11413807].
Gisbert JP, Gomollon F, Mate J, Pajares JM. Pharmacological treatment of fistulizing Crohn's disease. Tratamiento farmacologico de las fistulas en la enfermedad de Crohn. Med. Clin. 2001;116(17):664-671. Not written in English.
Gisbert JP, Luna M, Gonzalez-Lama Y, Pousa ID, Velasco M, Moreno-Otero R, et al. Effect of 5-aminosalicylates on renal function in patients with inflammatory bowel disease: 4-year follow-up study. Gastroenterol Hepatol. 2008;31(8):477-84. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18928745].
Gisbert JP, Luna M, Gonzalez-Lama Y, Pousa ID, Velasco M, Moreno-Otero R, et al. Liver injury in inflammatory bowel disease: long-term follow-up study of 786 patients. Inflamm Bowel Dis. 2007;13(9):1106-14. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17455203].
Gisbert JP, Nino P, Cara C, Rodrigo L. Comparative effectiveness of azathioprine in Crohn's disease and ulcerative colitis: prospective, long-term, follow-up study of 394 patients. Aliment Pharmacol Ther. 2008;28(2):228-38. Does not evaluate a drug of interestDoes not report side effects by medication class. [pmid: 18485129].
Glazier KD, Palance AL, Griffel LH, Das KM. The ten-year single-center experience with 6-mercaptopurine in the treatment of inflammatory bowel disease. J Clin Gastroenterol. 2005;39(1):21-6. Does not report side effects by medication class; other reason. [pmid: 15599205].
Gokhale R, Favus MJ, Karrison T, Sutton MM, Rich B, Kirschner BS. Bone mineral density assessment in children with inflammatory bowel disease. Gastroenterology. 98;114(5):902-11. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 9558278].
Goldberg HI, Caruthers SB Jr, Nelson JA, Singleton JW. Radiographic findings of the National Cooperative Crohn's Disease Study. Gastroenterology. 79;77(4 Pt 2):925-37. Other reason. [pmid: 38181].
Goldstein F, Murdock MG. Clinical and radiologic improvement of regional enteritis and enterocolitis after treatment with salicylazosulfapyridine. Am J Dig Dis. 71;16(5):421-31. Case report or case series. [pmid: 4397078].
Goldstein F, Menduke H, Thornton JJ 3rd, Abramson J. Anti-inflammatory drug treatment of Crohn's disease: a prospective evaluation of 100 consecutively treated patients. J Clin Gastroenterol. 80;2(1):77-85. Does not report side effects by medication class. [pmid: 6126497].
Gomollon F, Hinojosa J, Nos P. Budesonide and inflammatory bowel disease. Gastroenterol Hepatol. 99;22(10):525-32. Not written in English. [pmid: 10650668].
Gonzaga JE, Ananthakrishnan AN, Issa M, Beaulieu DB, Skaros S, Zadvornova Y, et al. Durability of infliximab in Crohn's disease: A single-center experience. Inflamm Bowel Dis. 2009;15(12):1837-1843. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19462426].
Gonzalez-Lama Y, Lopez-San Roman A, Marin-Jimenez I, Casis B, Vera I, Bermejo F, et al. Open-label infliximab therapy in Crohn's disease: a long-term multicenter study of efficacy, safety and predictors of response. Gastroenterol Hepatol. 2008;31(7):421-6. Does not report side effects by medication class. [pmid: 18783686].
Goodacre RL, Ali MA, Vanderlinden B, Hamilton JD, Castelli M, Seaton T. Hemolytic anemia in patients receiving sulfasalazine. Digestion. 78;17(6):503-8. Other reason. [pmid: 30666].
Goodhand J, Dawson R, Hefferon M, Tshuma N, Swanson G, Wahed M, et al. Inflammatory bowel disease in young people: the case for transitional clinics. Inflamm Bowel Dis. 2010;16(6):947-52. Does not apply to key questionsDoes not report side effects by medication class. [pmid: 19834978].
Gorard DA, Hunt JB, Payne-James JJ, Palmer KR, Rees RG, Clark ML, et al. Initial response and subsequent course of Crohn's disease treated with elemental diet or prednisolone. Gut. 93;34(9):1198-202. Does not evaluate a drug of interest. [pmid: 8406153].
Grand RJ. Management of severe colitis/ileocolitis. Inflamm Bowel Dis. 98;4(3):225-7. No original data. [pmid: 9741027].
Green CJ, Mee AS. Re-introduction of azathioprine in previously intolerant patients. Eur J Gastroenterol Hepatol. 2006;18(1):17-9. Does not apply to key questionsOther observational study without a comparison group. [pmid: 16357614].
Green JR, Lobo AJ, Giaffer M, Travis S, Watkins HC. Maintenance of Crohn's disease over 12 months: fixed versus flexible dosing regimen using budesonide controlled ileal release capsules. Aliment Pharmacol Ther. 2001;15(9):1331-41. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 11552903].
Greenberger NJ, Miner PB. Is maintenance therapy effective in Crohn's disease?. Lancet. 94;344(8927):900-1. No original data. [pmid: 7934340].
Griffiths AM. Monitoring of azathioprine/6-mercaptopurine treatment in children with IBD is not necessary. Inflamm Bowel Dis. 2003;9(6):389-91. discussion 392-3. No original data. [pmid: 14671489].
Griffiths AM, Nguyen P, Smith C, MacMillan JH, Sherman PM. Growth and clinical course of children with Crohn's disease. Gut. 93;34(7):939-43. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 8344582].
Gross R, Scapa E. Hepatotoxicity of 6-mercaptopurine in Crohn's disease. Am J Gastroenterol. 92;87(12):1885-6. Case report or case series. [pmid: 1449165].
Grossman AB, Noble AJ, Mamula P, Baldassano RN. Increased dosing requirements for 6-mercaptopurine and azathioprine in inflammatory bowel disease patients six years and younger. Inflamm Bowel Dis. 2008;14(6):750-5. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18266236].
Gruenagel HH, Orth E, Beglau E. Crohn's disease: Follow-up, conservative and operative treatment. Review of 55 patients. MED. WELT. 81;32(48):1832-1836. Not written in English. [pmid: 7311795].
Gujral N, Friedenberg F, Friedenberg J, Gabriel G, Kotler M, Levine G. Pleuropericarditis related to the use of mesalamine. Dig Dis Sci. 96;41(3):624-6. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; case report or case series. [pmid: 8617147].
Gunnarsson I, Forslid J, Ringertz B. Mesalazine-induced lupus syndrome. Lupus. 99;8(6):486-8. Case report or case series. [pmid: 10483021].
Guslandi M. Respiratory distress during mesalamine therapy. Dig Dis Sci. 99;44(1):48-9. Case report or case series. [pmid: 9952222].
Haapamaki J, Turunen U, Roine RP, Farkkila MA, Arkkila Pe. Impact of demographic factors, medication and symptoms on disease-specific quality of life in inflammatory bowel disease. Qual Life Res. 2009;18(8):961-9. Does not apply to key questions. [pmid: 19629750].
Haber CJ, Meltzer SJ, Present DH, Korelitz BI. Nature and course of pancreatitis caused by 6-mercaptopurine in the treatment of inflammatory bowel disease. Gastroenterology. 86;91(4):982-6. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 2427386].
Hadigan CBR, Braegger CP, Vasilauskis E, Escher JC, Sinaasappel M, Ferry GD, et al. Pharmacokinetics of infliximab (Anti-TNFx) in children with Crohn's disease: A multicenter trial. Journal of Pediatric Gastroenterology & Nutrition. 99;29(4):525. Abstract only.
Hadziselimovic F. Adalimumab induces and maintains remission in severe, resistant paediatric Crohn disease. J Pediatr Gastroenterol Nutr. 2008;46(2):208-11. Case report or case series. [pmid: 18223382].
Haennig A, Bonnet D, Thebault S, Alric L. Infliximab-induced acute hepatitis during Crohn's disease therapy: Absence of cross-toxicity with adalimumab. Gastroenterol Clin Biol. 2010. Case report or case series.
Hagel S, Bruns T, Kantowski M, Fix P, Seidel T, Stallmach A. Cholestatic hepatitis, acute acalculous cholecystitis, and hemolytic anemia: primary Epstein-Barr virus infection under azathioprine. Inflamm Bowel Dis. 2009;15(11):1613-6. Case report or case series. [pmid: 19137606].
Haines ML, Ajlouni Y, Irving PM, Sparrow MP, Rose R, Gearry RB, et al. Clinical usefulness of therapeutic drug monitoring of thiopurines in patients with inadequately controlled inflammatory bowel disease. Inflammatory Bowel Dis. 2011;17(6):1301-1307. Does not evaluate a drug of interestDoes not report side effects by medication class.
Hanauer Sb. Natural history of corticosteroid therapy for inflammatory bowel disease. Rev. Gastroenterol. Disord. 2002;2(2):93-94. Other observational study without a comparison groupOther reason.
Hanauer SB, Korelitz BI, Rutgeerts P, Peppercorn MA, Thisted RA, Cohen RD, Present DH. Postoperative maintenance of Crohn's disease remission with 6-mercaptopurine, mesalamine, or placebo: a 2-year trial. Gastroenterology. 2004;127(3):723-9. Does not apply to key questions. [pmid: 15362027].
Hanauer SB, Krawitt EL, Robinson M, Rick GG, Safdi MA. Long-term management of Crohn's disease with mesalamine capsules (Pentasa). Pentasa Crohn's Disease Compassionate Use Study Group. Am J Gastroenterol. 93;88(9):1343-51. Other observational study without a comparison group. [pmid: 8362827].
Harries JT, Lloyd JK. Azathioprine in the treatment of Crohn's disease. Acta Paediatr Scand. 71;60(3):376. Does not evaluate a drug of interest; case report or case series. [pmid: 5579888].
Hausmann J, Zabel K, Herrmann E, Schroder O. Methotrexate for maintenance of remission in chronic active Crohn's disease: long-term single-center experience and meta-analysis of observational studies. Inflamm Bowel Dis. 2010;16(7):1195-202. Does not report side effects by medication class. [pmid: 19924799].
Hausmann M, Herfarth H, Scholmerich J, Rogler G. Glucocorticoid receptor isoform expression does not predict steroid treatment response in IBD. Gut. 2007;56(9):1328-9. Does not evaluate a drug of interest. [pmid: 17698877].
Haveran LA, Sehgal R, Poritz LS, McKenna KJ, Stewart DB, Koltun WA. Infliximab and/or azathioprine in the treatment of Crohn's disease-like complications after IPAA. Dis. Colon Rectum. 2011;54(1):15-20. Does not apply to key questions. [pmid: 21160308].
Hawwa AF, Millership JS, Collier PS, Vandenbroeck K, McCarthy A, Dempsey S, et al. Pharmacogenomic studies of the anticancer and immunosuppressive thiopurines mercaptopurine and azathioprine. Br J Clin Pharmacol. 2008;66(4):517-28. Other observational study without a comparison group. [pmid: 18662289].
Heijman JA, Vroegh AN, Van Dullemen HM, Postma MJ, Rutten WJMJ. Costs and effectiveness: Azathioprine for the treatment of inflammatory bowel diseases. Pharm. Weekbl. 2002;137(11):402-405. Not written in English.
Hellers G, Cortot A, Jewell D, Leijonmarck CE, Lofberg R, Malchow H, et al. Oral budesonide for prevention of postsurgical recurrence in Crohn's disease. The IOIBD Budesonide Study Group. Gastroenterology. 99;116(2):294-300. Does not apply to key questions. [pmid: 9922309].
Herfarth H, Gross V, Andus T, Caesar I, Vogelsang H, Adler G, et al. Analysis of the therapeutic efficacy of different doses of budesonide in patients with active Crohn's ileocolitis depending on disease activity and localization. Int J Colorectal Dis. 2004;19(2):147-52. Does not evaluate a drug of interest. [pmid: 13680283].
Herfarth H, Tjaden C, Lukas M, Obermeier F, Dilger K, Muller R, et al. Adverse events in clinical trials with azathioprine and mesalamine for prevention of postoperative recurrence of Crohn's disease. Gut. 2006;55(10):1525-6. No original data. [pmid: 16966711].
Hermann GG. Sulfasalazine: adverse effects. Dig Dis Sci. 84;29(8):781-2. Case report or case series. [pmid: 6146502].
Hermida C, Cantero J, Moreno-Otero R, Mate-Jimenez J. Methotrexate and 6-mercaptopurine in steroid-dependent inflammatory bowel disease patients: A randomized controlled clinical trial.[abstract]. GUT. 99;45(Suppl V):A132. Abstract only.
Herrlinger KR, Deibert P, Schwab M, Kreisel W, Fischer C, Fellermann K, et al. Remission maintenance by tioguanine in chronic active Crohn's disease. Aliment Pharmacol Ther. 2003;17(12):1459-64. Does not evaluate a drug of interest. [pmid: 12823147].
Herrlinger KR, Fellermann K, Fischer C, Kreisel W, Deibert P, Schoelmerich J, et al. Thioguanine-nucleotides do not predict efficacy of tioguanine in Crohn's disease. Aliment Pharmacol Ther. 2004;19(12):1269-76. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 15191508].
Herrlinger KR, Witthoeft T, Raedler A, Bokemeyer B, Krummenerl T, Schulzke JD, et al. Randomized, double blind controlled trial of subcutaneous recombinant human interleukin-11 versus prednisolone in active Crohn's disease. Am J Gastroenterol. 2006;101(4):793-7. Does not evaluate a drug of interest. [pmid: 16635225].
Hibi T, Iwao Y, Yajima T, Inoue N, Ueno Y, Takaishi H, et al. Immunosuppressive agents in the treatment of Crohn's disease and ulcerative colitis. J Gastroenterol. Suppl 8. 95;30:121-3. Does not evaluate a drug of interest; other reason. [pmid: 8563872].
Hindorf U, Johansson M, Eriksson A, Kvifors E, Almer SH. Mercaptopurine treatment should be considered in azathioprine intolerant patients with inflammatory bowel disease. Aliment Pharmacol Ther. 2009;29(6):654-61. Does not report side effects by medication class. [pmid: 19183142].
Hinojosa del Val J, Moles JR, Nos P, Hoyos M, Ramirez JJ, Primo J, et al. Efficacy of 6-mercaptopurine in the treatment of inflammatory bowel disease. Rev. Esp. Enferm. Dig. 95;87(11):775-780. Not written in English. [pmid: 8534531].
Hinojosa J, Gomollon F, Garcia S, Bastida G, Cabriada JL, Saro C, et al. Efficacy and safety of short-term adalimumab treatment in patients with active Crohn's disease who lost response or showed intolerance to infliximab: a prospective, open-label, multicentre trial. Aliment Pharmacol Ther. 2007;25(4):409-18. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17269996].
Ho GT, Mowat A, Potts L, Cahill A, Mowat C, Lees CW, et al. Efficacy and complications of adalimumab treatment for medically-refractory Crohn's disease: analysis of nationwide experience in Scotland (2004-2008). Aliment Pharmacol Ther. 2009;29(5):527-34. Does not report side effects by medication class. [pmid: 19183339].
Ho GT, Smith L, Aitken S, Lee HM, Ting T, Fennell J, et al. The use of adalimumab in the management of refractory Crohn's disease. Aliment Pharmacol Ther. 2008;27(4):308-15. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18081730].
Hoang P, Fontaine P, Dalton HR, Gehenot M, Sibille C, et al. Immunosuppressive therapy in inflammatory bowel disease. Acta Gastroenterol Belg. 94;57(5-6):333-8. No original data. [pmid: 7709704].
Holdsworth CD. Sulphasalazine hepatotoxicity after 15 years' treatment. Br Med J (Clin Res Ed). 83;287(6394):759. No original data.
Holtmann MH, Galle PR, Neurath MF. Treatment of patients with Crohn's disease and concomitant chronic hepatitis C with a chimeric monoclonal antibody to TNF. Am J Gastroenterol. 2003;98(2):504-5. Case report or case series. [pmid: 12591081].
Holtmann MH, Krummenauer F, Claas C, Kremeyer K, Lorenz D, Rainer O, et al. Significant differences between Crohn's disease and ulcerative colitis regarding the impact of body mass index and initial disease activity on responsiveness to azathioprine: results from a European multicenter study in 1,176 patients. Dig Dis Sci. 2010;55(4):1066-78. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19513841].
Holtmann MH, Krummenauer F, Claas C, Kremeyer K, Lorenz D, Rainer O, et al. Long-term effectiveness of azathioprine in IBD beyond 4 years: a European multicenter study in 1176 patients. Dig Dis Sci. 2006;51(9):1516-24. Other observational study without a comparison group. [pmid: 16927148].
Hommel KA, Baldassano RN. Brief Report: Barriers to Treatment Adherence in Pediatric Inflammatory Bowel Disease. J Pediatr Psychol. 2009. Does not apply to key questions.
Hommes DW, Parlevliet W, Sterringa GJ, Hermans M, Bartelsman JFWM, Van Deventer SJH. Infliximab therapy in patients with Crohn's disease; experience with 132 patients. Ned. Tijdschr. Geneeskd. 2002;146(25):1187-1191. Not written in English.
Hommes DW, van de Heisteeg BH, van der Spek M, Bartelsman JF, van Deventer SJ. Infliximab treatment for Crohn's disease: one-year experience in a Dutch academic hospital. Inflamm Bowel Dis. 2002;8(2):81-6. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11854604].
Huang LJ, Zhu Q, Lei M, Cao Q. Current use of immunosuppressive agents in inflammatory bowel disease patients in East China. World J Gastroenterol. 2009;15(24):3055-9. Does not report side effects by medication class. [pmid: 19554661].
Huber W, Herrmann G, Schuster T, Phillip V, Saugel B, Schultheiss C, et al. Life-threatening complications of Crohns disease and ulcerative colitis: A systematic analysis of admissions to an ICU during 18 years. Lebensbedrohliche Komplikationen von Morbus Crohn und Colitis ulcerosa. Dtsch. Med. Wochenschr. 2010;135(14):668-674. Not written in English. [pmid: 20358493].
Hudson E, Dore C, Sowter C, Toovey S, Levi AJ. Sperm size in patients with inflammatory bowel disease on sulfasalazine therapy. Fertil Steril. 82;38(1):77-84. Does not apply to key questions. [pmid: 6124462].
Huerta C, Johansson S, Wallander MA, Garcia Rodriguez LA. Risk factors and short-term mortality of venous thromboembolism diagnosed in the primary care setting in the United Kingdom. Arch Intern Med. 2007;167(9):935-43. Does not evaluate a drug of interest. [pmid: 17502535].
Hyams JS, Markowitz J, Wyllie R. Use of infliximab in the treatment of Crohn's disease in children and adolescents. J Pediatr. 2000;137(2):192-6. Other observational study without a comparison group. [pmid: 10931411].
Hyams JS, Wilson DC, Thomas A, Heuschkel R, Mitton S, Mitchell B, et al. Natalizumab therapy for moderate to severe Crohn disease in adolescents. J Pediatr Gastroenterol Nutr. 2007;44(2):185-91. Other observational study without a comparison group. [pmid: 17255829].
Hyams J, Crandall W, Kugathasan S, Griffiths A, Olson A, Johanns J, et al. Induction and maintenance infliximab therapy for the treatment of moderate-to-severe Crohn's disease in children. Gastroenterology. 2007;132(3):863-73. quiz 1165-6. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17324398].
Hyams J, Walters TD, Crandall W, Kugathasan S, Griffiths A, Blank M, et al. Safety and efficacy of maintenance infliximab therapy for moderate-to-severe Crohn's disease in children: REACH open-label extension. Curr. Med. Res. Opin. 2011;27(3):651-662. Does not evaluate a drug of interestOther observational study without a comparison group. [pmid: 21241207].
Hyder SA, Travis SP, Jewell DP, McC Mortensen NJ, George BD. Fistulating anal Crohn's disease: results of combined surgical and infliximab treatment. Dis Colon Rectum. 2006;49(12):1837-41. Other observational study without a comparison group. [pmid: 17041753].
Iglesias M, Barreiro de Acosta M, Vazquez I, Figueiras A, Nieto L, Lorenzo A, et al. Psychological impact of Crohn's disease on patients in remission: anxiety and depression risks. Rev Esp Enferm Dig. 2009;101(4):249-57. Does not apply to key questions. [pmid: 19492900].
Iofel E, Chawla A, Daum F, Markowitz J. Mesalamine intolerance mimics symptoms of active inflammatory bowel disease. J Pediatr Gastroenterol Nutr. 2002;34(1):73-6. Case report or case series. [pmid: 11753169].
Irving PM. Recent advances in the management of inflammatory bowel disease. Clin Med. 2009;9(6):605-8. No original data. [pmid: 20095311].
Ito H, Furuta S, Sasaki H, Yoshida T, Takano Y, Hibi T. Pharmacokinetics and safety of single and multiple doses of Asacol tablets in Japanese healthy volunteers. Adv Ther. 2009;26(8):749-61. RCT patient population not exclusively Crohn's or observational study not exclusively IBD. [pmid: 19730804].
Izuel-Rami M, Carcelen Andres J, Allende-Bandre MaA, Agustin Ferrandez MaJ, Urbieta Sanz E, et al. Study of the use of infliximab in Crohn' disease. Estudio de utilizacion de infliximab en la enfermedad de Crohn. Aten Farm. 2004;6(5):333-342. Not written in English.
Jacobstein DA, Markowitz JE, Kirschner BS, Ferry G, Cohen SA, Gold BD, et al. Premedication and infusion reactions with infliximab: results from a pediatric inflammatory bowel disease consortium. Inflamm Bowel Dis. 2005;11(5):442-6. Does not report side effects by medication class. [pmid: 15867583].
Jahnsen J, Falch JA, Mowinckel P, Aadland E. Body composition in patients with inflammatory bowel disease: a population-based study. Am J Gastroenterol. 2003;98(7):1556-62. Does not apply to key questions. [pmid: 12873577].
Jakobsen C, Munkholm P, Paerregaard A, Wewer V. Steroid dependency and pediatric inflammatory bowel disease in the era of immunomodulators-A population-based study. Inflamm Bowel Dis. 2010. Other observational study without a comparison group; does not report side effects by medication class.
Jakobsen C, Paerregaard A, Munkholm P, Faerk J, Lange A, Andersen J, et al. Pediatric inflammatory bowel disease: Increasing incidence, decreasing surgery rate, and compromised nutritional status: A prospective population-based cohort study 2007-2009. Inflammatory Bowel Dis. 2011. Case report or case series; does not report side effects by medication class.
Jalocha L, Wojtun S, Gil J, Dyrla P. Efficacy of anti-TNF-(alpha) agents in mucosal healing in Crohn disease. Skutecznosc lekow anty-TNF-(alpha) w gojeniu sluzowkowym u osob z choroba lesniowskiego- Crohna. Prz. Gastroenterol. 2009;4(4):184-187. Not written in English.
Jankovic G. Aminosalicylates in Crohn's disease. Arch. Gastroenterohepatol. 2008;27(1-2):17-22. No original data.
Jantschek G, Zeitz M, Pritsch M, Wirsching M, Klor HU, Studt HH, et al. Effect of psychotherapy on the course of crohn's disease: results of the prospective multicenter psychotherapy treatment study on crohn's disease. Scandinavian Journal of Gastroenterology. 98;33:1289-96. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 9930393].
Jaspers GJ, Verkade HJ, Escher JC, de Ridder L, Taminiau JA, Rings EH. Azathioprine maintains first remission in newly diagnosed pediatric Crohn's disease. Inflamm Bowel Dis. 2006;12(9):831-6. Does not report side effects by medication class. [pmid: 16954801].
Javett SL, Hoffmann VJ. Azathioprine in acute Crohn's disease. S Afr Med J. 72;46(38):1369. Case report or case series. [pmid: 4638224].
Jenss H, Hartmann F, Schulmerich J, Deutsche 5-ASA Studiengruppe. 5-Aminosalicylic acid versus methylprednisolone in the therapy of acute Crohn's disease - Results of a double-blind multicentric clinical study. Klinische Wochenschrift. 90;68(Suppl 19):34. Not written in EnglishAbstract only.
Jharap B, Seinen ML, de Boer NK, van Ginkel JR, Linskens RK, Kneppelhout JC, et al. Thiopurine therapy in inflammatory bowel disease patients: Analyses of two 8-year intercept cohorts. Inflamm Bowel Dis. 2010. Does not report side effects by medication class.
Jick H, Myers MW, Dean AD. The risk of sulfasalazine- and mesalazine-associated blood disorders. Pharmacotherapy. 95;15(2):176-81. Does not report side effects by medication class. [pmid: 7624265].
John A, Dickey K, Fenwick J, Sussman B, Beeken W. Pneumatosis intestinalis in patients with Crohn's disease. Dig Dis Sci. 92;37(6):813-7. Other reason. [pmid: 1587184].
Judit BK, Nagy A, Szabo A, Lorincz M. To grow up with Crohn's disease: (A follow-up of 81 patients until the 18th year of age). Felnoni Crohn-betegseggel: (81 gyermek kovetese 18 eves korig). Orvosi Hetil. 2011;152(14):546-554. Not written in English.
Jung YS, Cheon JH, Park JJ, Moon CM, Kim ES, Lee JH, et al. Correlation of genotypes for thiopurine methyltransferase and inosine triphosphate pyrophosphatase with long-term clinical outcomes in Korean patients with inflammatory bowel diseases during treatment with thiopurine drugs. J Hum Genet. 2010;55(2):121-3. Does not apply to key questions. [pmid: 19960028].
Jurgens M, Mahachie John JM, Cleynen I, Schnitzler F, Fidder H, van Moerkercke W, et al. Levels of C-reactive Protein Are Associated With Response to Infliximab Therapy in Patients With Crohn's Disease. Clin. Gastroenterol. Hepatol. 2011;9(5):421-427.e1. Does not evaluate a drug of interest. [pmid: 21334460].
Kabacam G, Toruner M. What is the importance of anti-TNF agents in the treatment of luminal (inflammatory type) Crohn's disease?. Turk J Gastroenterol. 2010;21(1):107-12. No original data. [pmid: 20552736].
Kader HA, Raynor SC, Young R, Kaufman SS, Vanderhoof J, Ruby EI, et al. Introduction of 6-mercaptopurine in Crohn's disease patients during the perioperative period: a preliminary evaluation of recurrence of disease. J Pediatr Gastroenterol Nutr. 97;25(1):93-7. Does not apply to key questions; does not report side effects by medication class. [pmid: 9226535].
Kader HA, Wenner WJ Jr, Telega GW, Maller ES, Baldassano RN. Normal thiopurine methyltransferase levels do not eliminate 6-mercaptopurine or azathioprine toxicity in children with inflammatory bowel disease. J Clin Gastroenterol. 2000;30(4):409-13. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 10875470].
Kane S, Dixon L. Adherence rates with infliximab therapy in Crohn's disease. Aliment Pharmacol Ther. 2006;24(7):1099-103. Other observational study without a comparison group. [pmid: 16984504].
Kane SV, Chao J, Mulani PM. Adherence to infliximab maintenance therapy and health care utilization and costs by Crohn's disease patients. Adv Ther. 2009;26(10):936-46. Does not apply to key questions; does not report side effects by medication class. [pmid: 19838649].
Kaplan G, Panaccione R. Use of combination therapy in IBD. Inflamm Bowel Dis. Suppl 2. 2008;14:S219-21. No original data. [pmid: 18816768].
Karmiris K, Koutroubakis IE. Role of infliximab in the treatment of fistulizing Crohn's disease. Ann. Gastroenterol. 2005;18(3):297-302. No original data.
Karmiris K, Paintaud G, Noman M, Magdelaine-Beuzelin C, Ferrante M, Degenne D, et al. Influence of trough serum levels and immunogenicity on long-term outcome of adalimumab therapy in Crohn's disease. Gastroenterology. 2009;137(5):1628-40. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 19664627].
Karoui S, Ben Yaghlene L, Fekih M, Boubaker J, Filali A. Corticosteroid dependence and resistance in Crohn's disease: prevalence and predictive factors. Tunis Med. 2003;81(1):15-9. Not written in English. [pmid: 12708187].
Katsanos KH, Stamou P, Tatsioni A, Tsianos VE, Zoumbas S, Kavvadia S, et al. Prevalence of inflammatory bowel disease related dysplasia and cancer in 1500 colonoscopies from a referral center in northwestern Greece. J. Crohn's Colitis. 2011;5(1):19-23. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 21272799].
Katsanos KH, Tsianos VE, Zois CD, Zioga H, Vagias I, Zervou E, et al. Inflammatory bowel disease and hepatitis B and C in Western Balkans: A referral centre study and review of the literature. J Crohn's Colitis. 2010;4(4):450-465. Other reason. [pmid: 21122543].
Katz JA. How long is it advisable to continue maintenance treatment of Crohn's disease?. Inflamm Bowel Dis. Suppl 2. 2008;14:S264-5. No original data. [pmid: 18816686].
Kawanishi H, Rudolph E, Bull FE. Azathioprine-induced acute pancreatitis. N Engl J Med. 73;289(7):357. Case report or case series. [pmid: 4718516].
Kerbleski JF, Gottlieb AB. Dermatological complications and safety of anti-TNF treatments. Gut. 2009;58(8):1033-1039. No original data. [pmid: 19592682].
Kevans D, Keegan D, Mulcahy HE, O'Donoghue DP. Infliximab therapy in Crohn's disease: a pragmatic approach?. Aliment Pharmacol Ther. 2006;24(2):351-9. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 16842462].
Khadgawat R, Makharia GK, Puri K. Evaluation of bone mineral density among patients with inflammatory bowel disease in a tertiary care setting in India. Indian J Gastroenterol. 2008;27(3):103-6. Does not report side effects by medication class. [pmid: 18787279].
Kiefer K, El-Matary W. 6-mercaptopurine as an alternative to azathioprine in azathioprine-induced hepatoxicity. Inflamm Bowel Dis. 2009;15(2):318-9. Case report or case series. [pmid: 18989893].
Kim DU, Kim YH, Kim BJ, Chang DK, Son HJ, Rhee PL, et al. The efficacy of low dose azathioprine/6-mercaptopurine in patients with inflammatory bowel disease. Hepatogastroenterology. 2009;56(94-95):1395-402. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 19950798].
Kim JH, Cheon JH, Kim WH. The frequency and the course of the adverse effects of azathioprine/6-mercaptopurine treatment in patients with inflammatory bowel disease. Korean J Gastroenterol. 2008;51(5):291-7. Not written in English. [pmid: 18516013].
Kim PS, Zlatanic J, Korelitz BI, Gleim GW. Optimum duration of treatment with 6-mercaptopurine for Crohn's disease. Am J Gastroenterol. 99;94(11):3254-7. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 10566725].
Kim SH, Yang S, Kim KJ, Kim EH, Yoon SM, Ye BD, et al. Efficacy of infliximab in the treatment of korean patients with crohns disease. Korean J Gastroenterol. 2009;54(2):108-16. Other observational study without a comparison group; not written in English. [pmid: 19696538].
Kirschner BS. Methotrexate therapy for pediatric patients with inflammatory bowel disease. Inflamm Bowel Dis. 98;4(2):121-3. No original data. [pmid: 9687222].
Kirschner BS. Safety of azathioprine and 6-mercaptopurine in pediatric patients with inflammatory bowel disease. Gastroenterology. 98;115(4):813-21. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 9753482].
Kitano A, Okabe H, Nakagawa M, Watanabe Y, Tabata A, Obayashi M, et al. Medication for and perianal lesions in Crohn's disease: A clinical study of 102 cases. J. JPN. SOC. COLO-PROCTOL. 92;45(8):1079-1083. Not written in English.
Kitis G. Maintenance azathioprine in Crohn's disease. Lancet. 78;2(8103):1306. No original data. [pmid: 82802].
Klein RQ, Spivack J, Choate KA. Psoriatic skin lesions induced by certolizumab pegol. Arch Dermatol. 2010;146(9):1055-6. Case report or case series. [pmid: 20855720].
Klingenstein G, Levy RN, Kornbluth A, Shah AK, Present DH. Inflammatory bowel disease related osteonecrosis: report of a large series with a review of the literature. Aliment Pharmacol Ther. 2005;21(3):243-9. Case report or case series. [pmid: 15691298].
Klotz U. Clinical efficacy of oral 5-aminosalicylic acid in the treatment of inflammatory bowel disease. Am J Gastroenterol. 85;80(8):660. No original data. [pmid: 4025285].
Klotz U, Maier K, Fischer C, Heinkel K. Therapeutic efficacy of sulfasalazine and its metabolites in patients with ulcerative colitis and Crohn's disease. N Engl J Med. 80;303(26):1499-502. Other reason. [pmid: 6107853].
Klugmann T, Bokemeyer B. Long-term-tolerance of 6-thioguanine in outpatients with IBD. Langzeitvertraglichkeit der 6-thioguanin-therapie bei CED-patienten in der gastroenterologischen fachpraxis. Verdauungskrankheiten. 2005;23(4):181-185. Not written in English.
Ko JM, Gottlieb AB, Kerbleski JF. Induction and exacerbation of psoriasis with TNF-blockade therapy: a review and analysis of 127 cases. J Dermatolog Treat. 2009;20(2):100-8. No original data; case report or case series. [pmid: 18923992].
Kochi S, Matsumoto T, Esaki M, Jo Y, Iida M. Prediction of 6-thioguanine nucleotides levels in Japanese patients with inflammatory bowel diseases during long-term thiopurine administration. Scand J Gastroenterol. 2010;45(5):608-14. Does not apply to key questions; does not report side effects by medication class. [pmid: 20163203].
Koelewijn C, Schrijvers A, Oldenburg B. Infliximab use in patients with Crohn's disease: Quality of life, costs and resource use. Neth. J. Med. 2006;64(7):212-218. No original data; does not apply to key questions. [pmid: 16929082].
Kopylov U, Mantzaris GJ, Katsanos KH, Reenaers C, Ellul P, Rahier JF, et al. The efficacy of shortening the dosing interval to once every six weeks in Crohn's patients losing response to maintenance dose of infliximab. Aliment. Pharmacol. Ther. 2011;33(3):349-357. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 21118397].
Korelitz BI, Present DH. Favorable effect of 6-mercaptopurine on fistulae of Crohn's disease. Dig Dis Sci. 85;30(1):58-64. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 2856904].
Korelitz BI. Therapy of inflammatory bowel disease, including use of immunosuppressive agents. Clin Gastroenterol. 80;9(2):331-49. No original data; does not evaluate a drug of interest. [pmid: 6104550].
Korelitz BI, Adler DJ, Mendelsohn RA, Sacknoff AL. Long-term experience with 6-mercaptopurine in the treatment of Crohn's disease. Am J Gastroenterol. 93;88(8):1198-205. Other observational study without a comparison group. [pmid: 8338087].
Korelitz BI, Fuller SR, Warman JI, Goldberg MD. Shingles during the course of treatment with 6-mercaptopurine for inflammatory bowel disease. Am J Gastroenterol. 99;94(2):424-6. Case report or case series; does not report side effects by medication class. [pmid: 10022640].
Korelitz BI, Mirsky FJ, Fleisher MR, Warman JI, Wisch N, Gleim GW. Malignant neoplasms subsequent to treatment of inflammatory bowel disease with 6-mercaptopurine. Am J Gastroenterol. 99;94(11):3248-53. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 10566724].
Korelitz BI, Zlatanic J, Goel F, Fuller S. Allergic reactions to 6-mercaptopurine during treatment of inflammatory bowel disease. J Clin Gastroenterol. 99;28(4):341-4. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 10372932].
Kothe MJC, van Hogezand R, DeWoody K, Braakman T, Schaible T, van Deventer. Controlled study of anti-TNF-alpha treatment for enterocutaneous fistulae complicating Crohn's disease [abstract]. Eur-j-gastroenterol-hepatol. 97;9(Suppl 12):A57. Abstract only.
Kotlyar DS, Blonski W, Diamond RH, Wasik M, Lichtenstein GR. Hepatosplenic T-cell lymphoma in inflammatory bowel disease: a possible thiopurine-induced chromosomal abnormality. Am J Gastroenterol. 2010;105(10):2299-301. No original data. [pmid: 20927075].
Koutroubakis IE, Oustamanolakis P, Malliaraki N, Karmiris K, Chalkiadakis I, Ganotakis E, et al. Effects of tumor necrosis factor alpha inhibition with infliximab on lipid levels and insulin resistance in patients with inflammatory bowel disease. Eur J Gastroenterol Hepatol. 2009;21(3):283-8. Does not report side effects by medication class. [pmid: 19279474].
Koutroubakis IE, Zavos C, Damilakis J, Papadakis GZ, Neratzoulakis J, Karkavitsas N, et al. Low bone mineral density in Greek patients with inflammatory bowel disease: Prevalence and risk factors. Ann. Gastroenterol. 2011;24(1):41-46. Does not apply to key questions; does not report side effects by medication class.
Kozarek RA, Patterson DJ, Gelfand MD, Botoman VA, Ball TJ, Wilske KR. Methotrexate induces clinical and histologic remission in patients with refractory inflammatory bowel disease. Ann Intern Med. 89;110(5):353-6. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 2492786].
Kraemer M, Kirschmeier A, Marth T. Perioperative adjuvant therapy with infliximab in complicated anal Crohn's disease. Int J Colorectal Dis. 2008;23(10):965-9. Other observational study without a comparison group. [pmid: 18553089].
Krupoves A, Mack DR, Seidman EG, Deslandres C, Bucionis V, Amre DK. Immediate and long-term outcomes of corticosteroid therapy in pediatric Crohn's disease patients. Inflammatory Bowel Dis. 2011;17(4):954-962. Other observational study without a comparison group; does not report side effects by medication class.
Kugathasan S. Prolonged duration of response to infliximab in early pediatric Crohn's disease. J Pediatr Gastroenterol Nutr. Suppl 1. 2001;33:S40-3. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11685975].
Kugathasan S, Levy MB, Saeian K, Vasilopoulos S, Kim JP, Prajapati D, et al. Infliximab retreatment in adults and children with Crohn's disease: risk factors for the development of delayed severe systemic reaction. Am J Gastroenterol. 2002;97(6):1408-14. Does not evaluate a drug of interestDoes not report side effects by medication class. [pmid: 12094858].
Kugathasan S, Werlin SL, Martinez A, Rivera MT, Heikenen JB, Binion DG. Prolonged duration of response to infliximab in early but not late pediatric Crohn's disease. Am J Gastroenterol. 2000;95(11):3189-94. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11095340].
Kull E, Beau P. Compared azathioprine efficacy in ulcerative colitis and in Crohn's disease. Gastroenterol Clin Biol. 2002;26(4):367-71. Not written in English. [pmid: 12070412].
Kundhal P, Zachos M, Holmes JL, Griffiths AM. Controlled ileal release budesonide in pediatric Crohn disease: efficacy and effect on growth. J Pediatr Gastroenterol Nutr. 2001;33(1):75-80. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 11479412].
Kunisaki R, Chaki O, Taguchi T, Sugiyama T, Sugita A. Infliximab and the bone in Crohn's disease. Aliment Pharmacol Ther. 2005;21(6):789-90. No original data. [pmid: 15771766].
Kuzela L, Oltman M, Sutka J, Zacharova B, Paulen P, Repakova B, et al. Results of prospective evaluation of mucosal changes in the small bowel by capsule enteroscopy in patients with Crohn's disease treated with infliximab and adalimumab. Ceska. Slov. Gastroenterol Hepatol. 2010;64(2):22-30. Not written in English.
Laasila K, Leirisalo-Repo M. Side effects of sulphasalazine in patients with rheumatic diseases or inflammatory bowel disease. Scand J Rheumatol. 94;23(6):338-40. Does not report side effects by medication class. [pmid: 7801059].
Laharie D, Chanteloup E, Chabrun E, Subtil C, Kowo M, El Hanafi K, et al. The tolerance and efficacy of a postponed retreatment with infliximab in Crohn's disease primary responders. Aliment Pharmacol Ther. 2009;29(12):1240-8. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19416134].
Laharie D, Reffet A, Belleannee G, Chabrun E, Subtil C, Razaire S, et al. Mucosal healing with methotrexate in Crohns disease: A prospective comparative study with azathioprine and infliximab. Aliment. Pharmacol. Ther. 2011;33(6):714-721. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 21235604].
Lamireau T, Cezard JP, Dabadie A, Goulet O, Lachaux A, Turck D, et al. Efficacy and tolerance of infliximab in children and adolescents with Crohn's disease. Inflamm Bowel Dis. 2004;10(6):745-50. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 15626892].
Landi B, Anh TN, Cortot A, Soule JC, Rene E, Gendre JP, et al. Endoscopic monitoring of Crohn's disease treatment: a prospective, randomized clinical trial. The Groupe d'Etudes Therapeutiques des Affections Inflammatoires Digestives. Gastroenterology. 92;102(5):1647-53. Other reason. [pmid: 1568574].
Langer-Gould A, Steinman L. Progressive multifocal leukoencephalopathy and multiple sclerosis: lessons from natalizumab. Curr Neurol Neurosci Rep. 2006;6(3):253-8. No original data. [pmid: 16635435].
Lankarani KB. Mortality associated with infliximab. J Clin Gastroenterol. 2001;33(3):255-6. Case report or case series; other reason. [pmid: 11500623].
Larvol L, Soule JC, Le Tourneau A. Reversible lymphoma in the setting of azathioprine therapy for Crohn's disease. N Engl J Med. 94;331(13):883-4. Case report or case series. [pmid: 8078549].
Laverdant C, Molinie C, Essioux H. Treatment of Crohn's disease by metronidazole or its by-products. Med. Chir. Dig. 82;11(5):315-319. Not written in English. [pmid: 7144278].
Lecomte T, Contou JF, Beaugerie L, Carbonnel F, Cattan S, Gendre JP, et al. Predictive factors of response of perianal Crohn's disease to azathioprine or 6-mercaptopurine. Dis Colon Rectum. 2003;46(11):1469-75. Does not apply to key questions; does not report side effects by medication class. [pmid: 14605564].
Lee JS, Lee JH, Lee JH, Lee HJ, Kim MJ, Lee HJ, et al. Efficacy of early treatment with infliximab in pediatric Crohn's disease. World J Gastroenterol. 2010;16(14):1776-81. Does not report side effects by medication class. [pmid: 20380012].
Lee KM, Kim JS, Shin DH, Cheong JY, Yoo BM, Kim JK, et al. Effect of infliximab in the treatment of refractory inflammatory bowel disease with complication. Korean J Gastroenterol. 2004;44(5):259-66. Not written in English. [pmid: 15564805].
Lee WS. The use of infliximab in South-east Asian children with severe Crohn's disease. Pediatr Int. 2004;46(2):198-201. Case report or case series; other observational study without a comparison group. [pmid: 15056252].
Lees CW, Maan AK, Hansoti B, Satsangi J, Arnott ID. Tolerability and safety of mercaptopurine in azathioprine-intolerant patients with inflammatory bowel disease. Aliment Pharmacol Ther. 2008;27(3):220-7. Does not apply to key questions; does not report side effects by medication class. [pmid: 17988235].
Leite S, Ribeiro JM, Lima SC, Barroso S, Cotter J. Azathioprine in inflammatory bowel disease. Acta Med Port. 2009;22(1):33-40. Not written in English. [pmid: 19341591].
Lemann M, Chamiot-Prieur C, Mesnard B, Halphen M, Messing B, Rambaud JC, et al. Methotrexate for the treatment of refractory Crohn's disease. Aliment Pharmacol Ther. 96;10(3):309-14. Other observational study without a comparison group. [pmid: 8791956].
Lemann M, Zenjari T, Bouhnik Y, Cosnes J, Mesnard B, Rambaud JC, et al. Methotrexate in Crohn's disease: long-term efficacy and toxicity. Am J Gastroenterol. 2000;95(7):1730-4. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 10925976].
Lennard-Jones JE. Azathioprine and 6-mercaptopurine have a role in the treatment of Crohn's disease. Dig Dis Sci. 81;26(4):364-8. No original data. [pmid: 7016483].
Lennard-Jones JE. Azathioprine in the treatment of Crohn's disease. Proc R Soc Med. 72;65(3):291-3. Case report or case series; other observational study without a comparison group. [pmid: 5083325].
Leung Y, Sparrow MP, Schwartz M, Hanauer SB. Long term efficacy and safety of allopurinol and azathioprine or 6-mercaptopurine in patients with inflammatory bowel disease. J. Crohn's Colitis. 2009;3(3):162-167. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 21172265].
Leveque N, Brixi-Benmansour H, Reig T, Renois F, Talmud D, Brodard V, et al. Low frequency of cytomegalovirus infection during exacerbations of inflammatory bowel diseases. J. Med. Virol. 2010;82(10):1694-1700. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 20827767].
Levi Z, Fraser E, Krongrad R, Hazazi R, benjaminov O, meyerovitch J, et al. Factors associated with radiation exposure in patients with inflammatory bowel disease. Aliment Pharmacol Ther. 2009;30(11-12):1128-36. Does not apply to key questions. [pmid: 19899197].
Levine A, Kori M, Dinari G, Broide E, Shaoul R, Yerushalmi B, et al. Comparison of two dosing methods for induction of response and remission with oral budesonide in active pediatric Crohn's disease: a randomized placebo-controlled trial. Inflamm Bowel Dis. 2009;15(7):1055-61. Does not evaluate a drug of interest; other reason. [pmid: 19229988].
Lewis JD, Gelfand JM, Troxel AB, Forde KA, Newcomb C, Kim H, et al. Immunosuppressant medications and mortality in inflammatory bowel disease. Am J Gastroenterol. 2008;103(6):1428-35. quiz 1436. Does not apply to key questions. [pmid: 18494836].
Lewis JD, Schwartz JS, Lichtenstein GR. Azathioprine for maintenance of remission in Crohn's disease: benefits outweigh the risk of lymphoma. Gastroenterology. 2000;118(6):1018-24. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 10833475].
Lichtenstein GR. Use of laboratory testing to guide 6-mercaptopurine/azathioprine therapy. Gastroenterology. 2004;127(5):1558-64. No original data. [pmid: 15521022].
Lichtenstein GR, Bala M, Han C, DeWoody K, Schaible T. Infliximab improves quality of life in patients with Crohn's disease. Inflamm Bowel Dis. 2002;8(4):237-43. Other reason. [pmid: 12131606].
Lichtenstein GR, Olson A, Travers S, Diamond RH, Chen DM, Pritchard ML, et al. Factors associated with the development of intestinal strictures or obstructions in patients with Crohn's disease. Am J Gastroenterol. 2006;101(5):1030-8. No original data. [pmid: 16606351].
Lichtenstein GR, Thomsen OO, Schreiber S, Lawrance IC, Hanauer SB, Bloomfield R, et al. Continuous Therapy With Certolizumab Pegol Maintains Remission of Patients With Crohn's Disease for up to 18 Months. Clin Gastroenterol Hepatol. 2010. Does not evaluate a drug of interest.
Lidar M, Langevitz P, Barzilai O, Ram M, Porat-Katz BS, Bizzaro N, et al. Infectious serologies and autoantibodies in inflammatory bowel disease: insinuations at a true pathogenic role. Ann N Y Acad Sci. 2009;1173:640-8. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 19758210].
Lindor KD, Fleming CR, Ilstrup DM. Preoperative nutritional status and other factors that influence surgical outcome in patients with Crohn's disease. Mayo Clin Proc. 85;60(6):393-6. Other reason. [pmid: 3999809].
Lindor KD, Fleming CR, Burnes JU, Nelson JK, Ilstrup DM. A randomized prospective trial comparing a defined formula diet, corticosteroids, and a defined formula diet plus corticosteroids in active Crohn's disease. Mayo Clin Proc. 92;67(4):328-33. Does not evaluate a drug of interest. [pmid: 1548947].
Lionetti P, Bronzini F, Salvestrini C, Bascietto C, Canani RB, De Angelis GL, et al. Response to infliximab is related to disease duration in paediatric Crohn's disease. Aliment Pharmacol Ther. 2003;18(4):425-31. Other observational study without a comparison group. [pmid: 12940928].
Ljung T, Axelsson LG, Herulf M, Lundberg JO, Hellstrom PM. Early changes in rectal nitric oxide and mucosal inflammatory mediators in Crohn's colitis in response to infliximab treatment. Aliment Pharmacol Ther. 2007;25(8):925-32. Does not apply to key questions; other reason. [pmid: 17402996].
Ljung T, Karlen P, Schmidt D, Hellstrom PM, Lapidus A, Janczewska I, et al. Infliximab in inflammatory bowel disease: clinical outcome in a population based cohort from Stockholm County. Gut. 2004;53(6):849-53. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 15138212].
Ljung T, Lundberg S, Varsanyi M, Johansson C, Schmidt PT, Herulf M, et al. Rectal nitric oxide as biomarker in the treatment of inflammatory bowel disease: responders versus nonresponders. World J Gastroenterol. 2006;12(21):3386-92. Does not apply to key questions. [pmid: 16733856].
Lloyd-Still JD. Azathioprine and the treatment of chronic inflammatory bowel disease. The Journal of pediatrics. 90;117(5):732-5. No original data. [pmid: 2231203].
Lofberg R, Danielsson O, Floron CH, Noble I, Brown R, Ericsson K, et al. Cost effectiveness of oral budesonide (Entocort capsules) maintenace therapy versus no maintenance therapy for Crohn's disease in Sweden [abstract]. Gut. Suppl 3. 97;41:A223. Abstract only.
Lofberg R. Treatment of fistulas in Crohn's disease with infliximab. Gut. 99;45(5):642-3. No original data. [pmid: 10517896].
Lofberg R, Danielsson A, Salde L. Oral budesonide in active Crohn's disease. Aliment Pharmacol Ther. 93;7(6):611-6. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 8161666].
Loftus EV Jr, Johnson SJ, Wang ST, Wu E, Mulani PM, Chao J. Risk-benefit analysis of adalimumab versus traditional non-biologic therapies for patients with Crohn's disease. Inflamm Bowel Dis. 2011;17(1):127-40. No original data. [pmid: 20848523].
Loftus EV. New Data on the Use of Biologic Agents for Crohn. Gastroenterol Hepatol (N Y). 2010;6(2 Suppl 3):4-16. No original data. [pmid: 20567559].
Lonnkvist MH, Befrits R, Lundberg JO, Lundahl J, Fagerberg UL, Hjortswang H, et al. Infliximab in clinical routine: experience with Crohn's disease and biomarkers of inflammation over 5 years. Eur J Gastroenterol Hepatol. 2009;21(10):1168-76. Does not report side effects by medication class. [pmid: 19757522].
Lopez Palacios N, Mendoza JL, Taxonera C, Lana R, Fuentes Ferrer M, Diaz-Rubio M. Adalimumab induction and maintenance therapy for Crohn's disease. An open-label study. Rev Esp Enferm Dig. 2008;100(11):676-81. Not written in English. [pmid: 19159170].
Lopez-Martin C, Chaparro M, Espinosa L, Bejerano A, Mate J, Gisbert JP. Adverse events of thiopurine immunomodulators in patients with inflammatory bowel disease. Gastroenterol Hepatol. 2011. Does not evaluate a drug of interest.
Loras C, Saro C, Gonzalez-Huix F, Minguez M, Merino O, Gisbert JP, et al. Prevalence and factors related to hepatitis B and C in inflammatory bowel disease patients in Spain: a nationwide, multicenter study. Am J Gastroenterol. 2009;104(1):57-63. Does not report side effects by medication class. [pmid: 19098850].
Lou GC, Yang JM, Huang W, Zhang J, Zhou B. Esophageal Crohn's disease. Endoscopy. Suppl 2. 2009;41:E257. Case report or case series. [pmid: 19787580].
Louis EJ, Watier HE, Schreiber S, Hampe J, Taillard F, Olson A, et al. Polymorphism in IgG Fc receptor gene FCGR3A and response to infliximab in Crohn's disease: a subanalysis of the ACCENT I study. Pharmacogenet Genomics. 2006;16(12):911-4. Does not apply to key questions. [pmid: 17108815].
Louis E, Boverie J, Dewit O, Baert F, De Vos M, D'Haens G. Treatment of small bowel subocclusive Crohn's disease with infliximab: an open pilot study. Acta Gastroenterol Belg. 2007;70(1):15-9. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17619533].
Louis E, Vermeire S, Rutgeerts P, De Vos M, Van Gossum A, Pescatore P, et al. A positive response to infliximab in Crohn disease: association with a higher systemic inflammation before treatment but not with -308 TNF gene polymorphism. Scand J Gastroenterol. 2002;37(7):818-24. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 12190096].
Lowry PW, Sandborn WJ. A comparison of budesonide and mesalamine for active Crohn's disease. Gastroenterology. 99;116(5):1263. No original data. [pmid: 10220523].
Lowry PW, Weaver AL, Tremaine WJ, Sandborn WJ. Combination therapy with oral tacrolimus (FK506) and azathioprine or 6-mercaptopurine for treatment-refractory Crohn's disease perianal fistulae. Inflamm Bowel Dis. 99;5(4):239-45. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 10579116].
Ludwig D, Stange EF. Efficacy of azathioprine in the treatment of chronic active Crohn's disease: prospective one-year follow-up study. German Imurek Study Group. Z Gastroenterol. 99;37(11):1085-91. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 10604222].
Lukas M, Bortlik M, Novotny A, Pospisilova B, Fialova J, Vavrova J. Nephrotoxicity of mesalazine in long-term treatment of ulcerative colitis and Crohn's disease. Gastroenterol. 99;53(5):135-139. Not written in English.
Luna-Chadid M, Perez Calle JL, Mendoza JL, Vera MI, Bermejo AF, Sanchez F, et al. Predictors of response to infliximab in patients with fistulizing Crohn's disease. Rev Esp Enferm Dig. 2004;96(6):379-81. 382. 4. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 15230667].
Lust M, Travis S. Is anti-TNF therapy always prohibited in patients with inflammatory bowel disease and previous malignancy?. Pract. Gastroenterol. 2009;33(8):25-30. No original data.
Lyckegaard E, Hakansson K, Bengtsson B. Budesonide in Crohn's disease: findings of a compassionate-use program. Hepatogastroenterology. 2007;54(79):2024-7. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18251152].
Mack DR, Young R, Kaufman SS, Ramey L, Vanderhoof JA. Methotrexate in patients with Crohn's disease after 6-mercaptopurine. J Pediatr. 98;132(5):830-5. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 9602195].
MacLean LD. The National Cooperative Crohn's Disease Study. Can J Surg. 80;23(1):7-8. No original data; does not apply to key questions. [pmid: 6102492].
MacLennan C, Lammas DA, Kumararatne DS. Anti-interleukin-12 antibody treatment for Crohn disease: potential risk of invasive disease due to mycobacteria and salmonellae infection. Clin Infect Dis. 2005;40(9):1381-2. No original data; does not evaluate a drug of interest. [pmid: 15825052].
Madonia S, Orlando A, Scimeca D, Olivo M, Rossi F, Cottone M. Occult hepatitis B and infliximab-induced HBV reactivation. Inflamm Bowel Dis. 2007;13(4):508-9. Case report or case series. [pmid: 17206687].
Mahadevan U, Marion JF, Present DH. Fistula response to methotrexate in Crohn's disease: a case series. Aliment Pharmacol Ther. 2003;18(10):1003-8. Case report or case series; other observational study without a comparison group. [pmid: 14616166].
Mahadevan U, Terdiman JP, Aron J, Jacobsohn S, Turek P. Infliximab and semen quality in men with inflammatory bowel disease. Inflamm Bowel Dis. 2005;11(4):395-9. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 15803031].
Mahida YR, Jewell DP. Slow-release 5-amino-salicylic acid (Pentasa) for the treatment of active Crohn's disease. Digestion. 90;45(2):88-92. Other reason. [pmid: 2190851].
Maier K, Fruhmorgen P, Bode JC, et al. Successful management of chronic inflammatory gut disease with oral 5-aminosalicylic acid. DTSCH-MED-WOCHENSCHR. 85;110(10):363-368. Not written in English. [pmid: 2857633].
Maier K, Gaisberg Uv, Frohmorgen S, Sinn I, Bode C, Klotz U. Clinical effectiveness and pharmacokinetics of oral 5-aminosalicylic acod in chronic inflammatory bowel diseases. Klinische Wochenschrift. 85;63(Suppl 4):19. Not written in English.
Maire F. Infliximab, azathioprine, or combination therapy for Crohn's disease. Traitement de la maladie de Crohn: Azathioprine, infliximab ou association des deux?. Hepato-Gastro. 2010;17(4):355-360. Not written in English.
Makhzoum J, Jobin G, Dagenais P, Makhzoum S, Perreault S. Risk for osteoporosis and antiresorptive therapies in patients with Crohn's disease. J. Pharm. Technol. 2006;22(1):9-14. Other reason.
Malik M, Tobin AM, Shanahan F, O'Morain C, Kirby B, Bourke J. Steroid allergy in patients with inflammatory bowel disease. Br J Dermatol. 2007;157(5):967-9. Does not apply to key questions. [pmid: 17854354].
Malireddy K, Larson DW, Sandborn WJ, Loftus EV, Faubion WA, Pardi DS, et al. Recurrence and impact of postoperative prophylaxis in laparoscopically treated primary ileocolic Crohn disease. Arch Surg. 2010;145(1):42-7. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 20083753].
Mamula P, Cohen SA, Ferry GD, Kirschner BS, Winter HS, Innes A, et al. CDP571, a humanized anti-tumor necrosis factor-alpha monoclonal antibody in pediatric Crohn's disease. Inflamm Bowel Dis. 2004;10(6):723-30. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 15626889].
Manosa M, Naves JE, Leal C, Cabre E, Moreno V, Lorenzo-Zuniga V, et al. Does methotrexate induce mucosal healing in Crohn's disease?. Inflamm Bowel Dis. 2010;16(3):377-8. Case report or case series; other observational study without a comparison group. [pmid: 19575354].
Mantzaris GJ, Archavlis E, Amberiadis P, Kourtessas D, Triantafullou G. A Prospective Randomized Trial in Active Crohn's Disease Comparing prednisolone, a Polymeric Diet and a Polymeric Diet Plus Prednisolon [abstract]. Gut. Suppl 3. 96;39:A166. Abstract only.
Marchal L, D'Haens G, Van Assche G, Vermeire S, Noman M, Ferrante M, et al. The risk of post-operative complications associated with infliximab therapy for Crohn's disease: a controlled cohort study. Aliment Pharmacol Ther. 2004;19(7):749-54. Does not apply to key questions; does not report side effects by medication class. [pmid: 15043515].
Margo F, Marques M, Santos CC. Episodic infliximab treatment induces infusion reactions. Inflamm Bowel Dis. 2008;14(11):1608-10. Case report or case series. [pmid: 18398893].
Mariette X, Tubach F, Bagheri H, Bardet M, Berthelot JM, Gaudin P, et al. Lymphoma in patients treated with anti-TNF: Results of the 3-year prospective French RATIO registry. Ann. Rheum. Dis. 2010;69(2):400-408. Other reason. [pmid: 19828563].
Marinaki AM, Ansari A, Duley JA, Arenas M, Sumi S, Lewis CM, et al. Adverse drug reactions to azathioprine therapy are associated with polymorphism in the gene encoding inosine triphosphate pyrophosphatase (ITPase). Pharmacogenetics. 2004;14(3):181-7. Does not evaluate a drug of interest. [pmid: 15167706].
Marion JF. Toxicity of 6-mercaptopurine/azathioprine in patients with inflammatory bowel disease. Inflamm Bowel Dis. 98;4(2):116-7. No original data. [pmid: 9687219].
Markowitz J, Grancher K, Mandel F, Daum F. Immunosuppressive therapy in pediatric inflammatory bowel disease: results of a survey of the North American Society for Pediatric Gastroenterology and Nutrition. Subcommittee on Immunosuppressive Use of the Pediatric IBD Collaborative Research Forum. Am J Gastroenterol. 93;88(1):44-8. Does not apply to key questions; no human data. [pmid: 8420272].
Markowitz J, Hyams J, Mack D, Leleiko N, Evans J, Kugathasan S, et al. Corticosteroid therapy in the age of infliximab: acute and 1-year outcomes in newly diagnosed children with Crohn's disease. Clin Gastroenterol Hepatol. 2006;4(9):1124-9. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 16861053].
Martin-de-Carpi J, Pociello N, Varea V. Long-term efficacy of adalimumab in Paediatric Crohn's disease patients naive to other anti-TNF therapies. J. Crohn's Colitis. 2010;4(5):594-598. Case report or case series. [pmid: 21122566].
Martreau P. A comparison of methotrexate with placebo for the maintenance of remission in Crohn's disease. North American Crohn's Study Group Investigators. Gastroenterol Clin Biol. 2000;24(12):1243-4. Not written in English. [pmid: 11277090].
Matsumoto T, Iida M, Motoya S, Haruma K, Suzuki Y, Kobayashi K, et al. Therapeutic efficacy of infliximab on patients with short duration of Crohn's disease: a Japanese multicenter survey. Dis Colon Rectum. 2008;51(6):916-23. Other observational study without a comparison group. [pmid: 18322754].
Max MH, Wolff M, Broell JR, Gump FE. The effect of long-term steroid therapy on the histopathology of regional enteritis. J Surg Res. 73;14(2):124-32. Does not apply to key questions. [pmid: 4693916].
McCullough JE, Kim CH, Banks PM. Mantle zone lymphoma of the colon simulating diffuse inflammatory bowel disease. Role of immunohistochemistry in establishing the diagnosis. DIG. DIS. SCI. 92;37(6):934-938. RCT patient population not exclusively Crohn's or observational study not exclusively IBD, Case report or case series. [pmid: 1587200].
McDonnell MJ, Dhar A. Azathioprine use in inflammatory bowel disease in South Durham - An insight into clinical practice. J. R. Coll. Phys. Edinburgh. 2009;39(2):100-106. Other observational study without a comparison group.
McNatty D. Crohn's disease - Strategies to improve quality of life. 2008;74(9). 42+44. No original data.
Medkour F, Babai S, Chanteloup E, Buffard V, Delchier JC, Le-Louet H. Development of diffuse psoriasis with alopecia during treatment of Crohn's disease with infliximab. Gastroenterol Clin Biol. 2010;34(2):140-1. Case report or case series. [pmid: 20138448].
Meier C, Thonnessen C, Rothe U, Henker J, Quietzsch J, Prager J, et al. Chronic inflammatory bowel disease in childhood and adolescence. Initial symptoms, diagnosis, treatment - Data recorded in the register of chronic inflammatory bowel disease in children and adolescents in Saxony. Monatsschr. Kinderheilkd. 2006;154(12):1212-1218. Not written in English.
Melendez JD, Larregui Y, Vazquez JM, Carlo VL, Torres EA. Medication profiles of patients in the University of Puerto Rico inflammatory bowel disease registry. Puerto Rico Health Sci. J. 2011;30(1):3-8. Does not evaluate a drug of interest; case report or case series.
Menachem Y, Avidan B, Lavy A, Lang A, Bardan E, Fidder H, et al. Increasing the infliximab dose is beneficial in Crohn's disease patients who responded to a lower dose and relapsed. Digestion. 2005;72(2-3):124-8. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 16172549].
Mendes FD, Levy C, Enders FB, Loftus EV Jr, Angulo P, Lindor KD. Abnormal hepatic biochemistries in patients with inflammatory bowel disease. Am J Gastroenterol. 2007;102(2):344-50. Does not apply to key questions; does not report side effects by medication class. [pmid: 17100965].
Mendoza JL, Garcia-Paredes J, Cruz Santamaria DM, Lana R, Ramirez Fernandez E, Rodriguez Asteaga E, et al. Infliximab treatment and prognostic factors for response in patients with Crohn's disease. Rev Esp Enferm Dig. 2002;94(5):269-79. Not written in English; other reason. [pmid: 12474335].
Mendoza JL, Urcelay E, Lana R, Martin MC, Lopez N, Guijarro LG, et al. MDR1 polymorphisms and response to azathioprine therapy in patients with Crohn's disease. Inflamm Bowel Dis. 2007;13(5):585-90. Does not apply to key questions; other observational study without a comparison group. [pmid: 17262810].
Miheller P, Lakatos PL, Horvath G, Molnar T, Szamosi T, Czegledi Z, et al. Efficacy and safety of infliximab induction therapy in Crohn's Disease in Central Europe--a Hungarian nationwide observational study. BMC Gastroenterol. 2009;9:66. Does not report side effects by medication class. [pmid: 19740450].
Miheller P, Muzes G, Racz K, Blazovits A, Lakatos P, Herszenyi L, Tulassay Z. Changes of OPG and RANKL concentrations in Crohn's disease after infliximab therapy. Inflamm Bowel Dis. 2007;13(11):1379-84. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 17663430].
Minderhoud IM, Samsom M, Oldenburg B. Crohn's disease, fatigue, and infliximab: is there a role for cytokines in the pathogenesis of fatigue?. World J Gastroenterol. 2007;13(14):2089-93. Does not apply to key questions other observational study without a comparison group. [pmid: 17465453].
Molloy JW, Kim E, Mahadevan U. Do Side-by-Side Anastomoses Decrease the Risk of Recurrence in Crohn's Disease?. Gastroenterology. 2010;138(5):2010-2012. No original data; does not apply to key questions. [pmid: 20303965].
Molnar T, Farkas K, Miheller P, Nyari T, Szepes Z, Herszenyi L, et al. Is the efficacy of successful infliximab induction therapy maintained for one year lasting without retreatment in different behavior types of Crohn's disease?. J. Crohn's Colitis. 2008;2(4):322-326. Other observational study without a comparison group. [pmid: 21172231].
Molnar T, Farkas K, Nagy F, Szepes Z, Wittmann T. Lymphomas in two IBD patients treated with anti-TNF-alpha mono or combination therapy: Is hepatosplenic lymphoma really the &quot;old maid&quot;?. Inflamm Bowel Dis. 2011. Case report or case series; other observational study without a comparison group.
Molnar T, Farkas K, Nyari T, Szepes Z, Nagy F, Kiss T, et al. Frequency and predictors of loss of response to biological therapy in Crohn's disease after one-year treatment period. Orv Hetil. 2011;152(24):951-957. Not written in English. [pmid: 21609921].
Molnar T, Farkas K, Szepes Z, Nagy F, Wittmann T. Long-term outcome of infliximab therapy is highly comparable in a Danish and in a Hungarian tertiary center. Scand J Gastroenterol. 2011;46(2):248-9. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; other reason. [pmid: 20923382].
Morales A, Salguti S, Miao CL, Lewis JD. Relationship between 6-mercaptopurine dose and 6-thioguanine nucleotide levels in patients with inflammatory bowel disease. Inflamm Bowel Dis. 2007;13(4):380-5. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 17206711].
Morelli J, Wilson FA. Does administration of infliximab increase susceptibility to listeriosis?. Am J Gastroenterol. 2000;95(3):841-2. Case report or case series. [pmid: 10710107].
Mortimore M, Gibson PR, Selby WS, Radford-Smith GL, Florin THJ, Ooi K, et al. Early Australian experience with infliximab, a chimeric antibody against tumour necrosis factor-(alpha), in the treatment of Crohn's disease: Is its efficacy augmented by steroid-sparing immunosuppressive therapy?. Intern. Med. J. 2001;31(3):146-150. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 11478343].
Motamed F, Famouri F, Najafi M, Moazzami K, Farahmand F, Khodadad A, et al. Response to induction therapy in a pediatric population of inflammatory bowel disease. Z. Gastroenterol. 2010;48(7):748-752. Does not report side effects by medication class. [pmid: 20607631].
Motil KJ, Grand RJ, Davis-Kraft L, Ferlic LL, Smith EO. Growth failure in children with inflammatory bowel disease: a prospective study. Gastroenterology. 93;105(3):681-91. Does not evaluate a drug of interest. [pmid: 8359640].
Moum B. Follow up of the use of biological drugs against inflammatory bowel diseases. Tidsskr Nor Laegeforen. 2007;127(21):2841-2. Not written in English. [pmid: 17987080].
Moum B. When should anti-TNF-alpha treatment in Crohn disease be terminated?. Tidsskr Nor Laegeforen. 2010;130(5):474. Not written in English. [pmid: 20224609].
Mudge TJ. Semen and sulphasalazine. Clin Reprod Fertil. 82;1(2):157-8. No original data. [pmid: 6138142].
Mulder CJ, Rondas AA, Wiltink EH, Tytgat GN. Topical corticosteroids in inflammatory bowel disease. Neth J Med. Suppl 1. 89;35:S27-34. No original data. [pmid: 2702309].
Mulder CJ, Tytgat GN, Dekker W, Terpstra IJ. Pentasa in lieu of sulfasalazine. Ann Intern Med. 88;108(6):911-2. Other observational study without a comparison group. [pmid: 2897181].
Muller AF, Stevens PE, McIntyre AS, Ellison H, Logan RF. Experience of 5-aminosalicylate nephrotoxicity in the United Kingdom. Aliment Pharmacol Ther. 2005;21(10):1217-24. Does not report side effects by medication class. [pmid: 15882242].
Munk EM, Pedersen L, Floyd A, Norgard B, Rasmussen HH, Sorensen HT. Inflammatory bowel diseases, 5-aminosalicylic acid and sulfasalazine treatment and risk of acute pancreatitis: a population-based case-control study. Am J Gastroenterol. 2004;99(5):884-8. Does not report side effects by medication class. [pmid: 15128355].
Munkholm P. Crohn's disease-occurrence, course and prognosis: An epidemiologic cohort-study. DAN. MED. BULL. 97;44(3):287-302. Does not apply to key questions; does not report side effects by medication class. [pmid: 9233548].
Munkholm P, Langholz E, Davidsen M, Binder V. Frequency of glucocorticoid resistance and dependency in Crohn's disease. Gut. 94;35(3):360-2. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 8150347].
Murakami Y, Matsui T, Hirai F, Takatsu N, Takaki Y, Nagahama T, et al. Efficacy of azathioprine in mild or moderate relapse in Crohn's disease: clinical and endoscopic evaluation. Dig Endosc. 2010;22(1):25-32. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 20078661].
Myrelid P, Olaison G, Sjodahl R, Nystrom PO, Almer S, Andersson P. Thiopurine therapy is associated with postoperative intra-abdominal septic complications in abdominal surgery for crohn's disease. Dis. Colon Rectum. 2009;52(8):1387-1394. Does not apply to key questions; does not report side effects by medication class. [pmid: 19617749].
Naganuma M, Hyun SB, Watanabe M. Diagnosis and treatment for small intestinal lesions in patients with Crohn's disease. J. Jpn. Soc. Gastroenterolog. 2010;107(6):845-854. Not written in English.
Nagy F, Molnar T, Szepes Z, Farkas K, Nyari T, Lonovics J. Efficacy of 6-mercaptopurine treatment after azathioprine hypersensitivity in inflammatory bowel disease. World J Gastroenterol. 2008;14(27):4342-6. Other observational study without a comparison group. [pmid: 18666323].
Nagy G, Pronay G, Ujszaszy L. Therapeutical experiments in ulcerative colitis and Crohn's disease. Acta Med Hung. 85;42(3-4):163-74. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 2869469].
Nakshabendi IM, Duncan A, Russell RI. Is Asacol as effective as sulphasalazine in maintaining remission of Crohn's disease and ulcerative colitis?. Postgrad Med J. 92;68(797):189-91. Other observational study without a comparison group. [pmid: 1350343].
Nancey S, Blanvillain E, Parmentier B, Flourie B, Bayet C, Bienvenu J, et al. Infliximab treatment does not induce organ-specific or nonorgan-specific autoantibodies other than antinuclear and anti-double-stranded DNA autoantibodies in Crohn's disease. Inflamm Bowel Dis. 2005;11(11):986-91. Does not report side effects by medication class. [pmid: 16239844].
Nathan DM, Iser JH, Gibson PR. A single center experience of methotrexate in the treatment of Crohn's disease and ulcerative colitis: a case for subcutaneous administration. J Gastroenterol Hepatol. 2008;23(6):954-8. Other observational study without a comparison group. [pmid: 17559377].
Nayar M, Cunliffe W, Cross P, Oppong K. Mesalazine-induced jaundice, eosonophilia, and thrombocytopenia. Inflamm Bowel Dis. 2008;14(9):1320-1. Case report or case series. [pmid: 18452221].
Ng SC, Plamondon S, Gupta A, Burling D, Kamm MA. Prospective assessment of the effect on quality of life of anti-tumour necrosis factor therapy for perineal Crohn's fistulas. Aliment Pharmacol Ther. 2009;30(7):757-66. Does not apply to key questions; does not report side effects by medication class. [pmid: 19575762].
Ng SC, Plamondon S, Gupta A, Burling D, Swatton A, Vaizey CJ, et al. Prospective evaluation of anti-tumor necrosis factor therapy guided by magnetic resonance imaging for Crohn's perineal fistulas. Am J Gastroenterol. 2009;104(12):2973-86. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19755971].
Nguyen GC, Nugent Z, Shaw S, Bernstein CN. Outcomes of Patients With Crohn's Disease Improved From 1988 to 2008 and Were Associated With Increased Specialist Care. Gastroenterology. 201. Does not evaluate a drug of interest; other observational study without a comparison group.
Nguyen KD, Alexis R, Schwarz SM. Oropharyngeal and proximal esophageal involvement during adalimumab treatment of Crohn disease. J Pediatr Gastroenterol Nutr. 2010;50(2):225-6. Case report or case series. [pmid: 19841594].
Nguyen TM, Le Gall C, Lachaux A, Boulieu R. High thiopurine metabolite concentrations associated with lymphopenia in inflammatory bowel disease (IBD) pediatric patients receiving aminosalicylates combined with azathioprine. Int J Clin Pharmacol Ther. 2010;48(4):275-81. Does not apply to key questions; does not report side effects by medication class. [pmid: 20353749].
Nguyen T, Vacek PM, O'Neill P, Colletti RB, Finette BA. Mutagenicity and potential carcinogenicity of thiopurine treatment in patients with inflammatory bowel disease. Cancer Res. 2009;69(17):7004-12. Does not apply to key questions; other observational study without a comparison group. [pmid: 19706768].
Nguyen TMH, Le Gall C, Lachaux A, Boulieu R. High thiopurine metabolite concentrations associated with lymphopenia in inflammatory bowel disease (IBD) pediatric patients receiving aminosalicylates combined with azathioprine. Int J Clin Pharmacol Ther. 2010;48(4):275-281. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; does not apply to key questions. [pmid: 20353749].
Nichita C, Stelle M, Vavricka S, El-Wafa Ali A, Ballabeni P, de Saussure P, et al. Clinical experience with adalimumab in a multicenter Swiss cohort of patients with Crohn's disease. Digestion. 2010;81(2):78-85. Other observational study without a comparison group. [pmid: 20093835].
Nielsen OH. Sulfasalazine intolerance. A retrospective survey of the reasons for discontinuing treatment with sulfasalazine in patients with chronic inflammatory bowel disease. Scand J Gastroenterol. 82;17(3):389-93. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 6127793].
Nightingale SL. From the Food and Drug Administration. JAMA. 98;280(13):1128. No original data. [pmid: 9777799].
Noe JD, Pfefferkorn M. Short-term response to adalimumab in childhood inflammatory bowel disease. Inflamm Bowel Dis. 2008;14(12):1683-7. Does not report side effects by medication class. [pmid: 18618629].
Nogueira JR, Freedman MA. Acute pancreatitis as a complication of Imuran therapy in regional enteritis. Gastroenterology. 72;62(5):1040-1. Case report or case series. [pmid: 5029069].
Norden DK, Lichtenstein GR, Williams WV. Sulfasalazine-induced myopathy. Am J Gastroenterol. 94;89(5):801-2. Case report or case series. [pmid: 7909646].
Norgard B, Czeizel AE, Rockenbauer M, Olsen J, Sorensen HT. Population-based case control study of the safety of sulfasalazine use during pregnancy. Aliment Pharmacol Ther. 2001;15(4):483-6. Does not apply to key questions. [pmid: 11284776].
Norgard B, Pedersen L, Fonager K, Rasmussen SN, Sorensen HT. Azathioprine, mercaptopurine and birth outcome: a population-based cohort study. Aliment Pharmacol Ther. 2003;17(6):827-34. Does not apply to key questions. [pmid: 12641505].
Nos Mateu P. Locally acting corticosteroids in inflammatory bowel disease. Are they effective? Are they really less toxic?. Gastroenterol Hepatol. Suppl 3. 2008;31:16-21. No original data; not written in English. [pmid: 19087859].
Nos P, Bastida G, Beltran B, Aguas M, Ponce J. Crohn's disease in common variable immunodeficiency: treatment with antitumor necrosis factor alpha. Am J Gastroenterol. 2006;101(9):2165-6. Case report or case series. [pmid: 16968516].
Novacek G, Kleinberger M, Vogelsang H, Moser G, Lochs H. Budesonide in glucocorticoid dependent chronic active Crohn's disease; a pilot study. Z Gastroenterol. 95;33(5):251-4. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 7610692].
Nugent FW, Roy MA. Duodenal Crohn's disease: An analysis of 89 cases. AM. J. GASTROENTEROL. 89;84(3):249-254. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 2919581].
Nyman M, Hansson I, Eriksson S. Long-term immunosuppressive treatment in Crohn's disease. Scand J Gastroenterol. 85;20(10):1197-203. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 3912958].
Oakes RA. Asacol in inflammatory bowel disease. N Z Med J. 87;100(824):325. No original data. [pmid: 3451096].
O'Brien JJ, Bayless TM, Bayless JA. Use of azathioprine or 6-mercaptopurine in the treatment of Crohn's disease. Gastroenterology. 91;101(1):39-46. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 2044925].
Ochsenkuhn T, Goke B, Sackmann M. Combining infliximab with 6-mercaptopurine/azathioprine for fistula therapy in Crohn's disease. Am J Gastroenterol. 2002;97(8):2022-5. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 12190171].
O'Donnell S, Murphy S, Anwar MM, O'Sullivan M, Breslin N, O'Connor HJ, et al. Safety of infliximab in 10 years of clinical practice. Eur. J. Gastroenterol. Hepatol. 2011. Case report or case series.
Ooi CY, Bohane TD, Lee D, Naidoo D, Day AS. Thiopurine metabolite monitoring in paediatric inflammatory bowel disease. Aliment Pharmacol Ther. 2007;25(8):941-7. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17402998].
Orlando A, Colombo E, Kohn A, Biancone L, Viscido A, Sostegni R, et al. Infliximab in the treatment of steroid resistant/dependant and fistulating Crohn's disease: An analysis of predictors of response in a italian multicentric open study in 573 patients. Eur. Rev. Med. Pharmacol. Sci. 2004;8(5):230. Abstract only.
Oshima T, Taira S, Nonaka M, Hayama Y, Yagi K, Yukawa I, et al. A study on bone mineral density in patients with Crohn's disease. Hepatogastroenterology. 2008;55(88):2116-20. Does not apply to key questions. [pmid: 19260488].
Oshitani N, Kitano A, Sawa Y, Sano K, Ueda W, Hara J, et al. Outcome of maintenance therapy in Crohn's disease. J. JPN. SOC. COLO-PROCTOL. 96;49(3):253-259. Not written in English.
Oussalah A, Babouri A, Chevaux JB, Stancu L, Trouilloud I, Bensenane M, et al. Adalimumab for Crohn's disease with intolerance or lost response to infliximab: a 3-year single-centre experience. Aliment Pharmacol Ther. 2009;29(4):416-23. Does not report side effects by medication class. [pmid: 19035976].
Oussalah A, Chevaux JB, Fay R, Sandborn WJ, Bigard MA, Peyrin-Biroulet L. Predictors of infliximab failure after azathioprine withdrawal in Crohn's disease treated with combination therapy. Am J Gastroenterol. 2010;105(5):1142-9. Other observational study without a comparison group. [pmid: 20389296].
Palacios NL, Mendoza JL, Taxonera C, Lana R, Ferrer MF, Diaz-Rubio M. Adalimumab induction and maintenance therapy from Crohn's diseas: An open-label study. Tratamiento de induccion y mantenimiento con adalimumab en la enfermedad de Crohn: Un estudio abierto. Rev. Esp. Enferm. Dig. 2008;100(11):676-681. Not written in English. [pmid: 19159170].
Pallotta N, Barberani F, Hassan NA, Guagnozzi D, Vincoli G, Corazziari E. Effect of infliximab on small bowel stenoses in patients with Crohn's disease. World J Gastroenterol. 2008;14(12):1885-90. Case report or case series; other observational study without a comparison group. [pmid: 18350627].
Palmieri O, Latiano A, Bossa F, Vecchi M, D'Inca R, Guagnozzi D, et al. Sequential evaluation of thiopurine methyltransferase, inosine triphosphate pyrophosphatase, and HPRT1 genes polymorphisms to explain thiopurines' toxicity and efficacy. Aliment Pharmacol Ther. 2007;26(5):737-45. Does not apply to key questions; does not report side effects by medication class. [pmid: 17697207].
Papadakis KA. Crohn's disease: Adalimumab improves quality of life. Nat Rev Gastroenterol Hepatol. 2009;6(4):200-1. No original data. [pmid: 19347008].
Papadakis KA, Shaye OA, Vasiliauskas EA, Ippoliti A, Dubinsky MC, Birt J, et al. Safety and efficacy of adalimumab (D2E7) in Crohn's disease patients with an attenuated response to infliximab. Am J Gastroenterol. 2005;100(1):75-9. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 15654784].
Papay P, Reinisch W, Ho E, Gratzer C, Lissner D, Herkner H, et al. The impact of thiopurines on the risk of surgical recurrence in patients with Crohn's disease after first intestinal surgery. Am J Gastroenterol. 2010;105(5):1158-64. Does not report side effects by medication class. [pmid: 20010925].
Papi C, Festa V, Leandro G, Moretti A, Tanga M, Koch M, et al. Long-term outcome of Crohn's disease following corticosteroid-induced remission. Am J Gastroenterol. 2007;102(4):814-9. Other observational study without a comparison group. [pmid: 17222316].
Papp JP, Watson DW, Bull FE. Azathioprine treatment in Crohn's disease. Am J Gastroenterol. 74;61(2):136-42. Case report or case series; other observational study without a comparison group. [pmid: 4595064].
Parker R, Dixit A, Fraser A, Creed TJ, Probert CS. Clinical experience of methotrexate in Crohn's disease: response, safety and monitoring of treatment. Postgrad Med J. 2010;86(1014):208-11. No original data; other observational study without a comparison group. [pmid: 20354043].
Parlak E, Ulker A, Alkim C, Tunc B, Tezel A, Dagli U. The efficacy of 5-ASA preparations in prevention of postoperative recurrence of crohn's disease (retrospective assessment). Turk. J. Gastroenterol. 99;10(3):276-279. Not written in English.
Parlak E, Ulker A, Dagli U, Alkim C. A retrospective trial comparing 5-ASA plus ciprofloxacin and metronidazole with 5-ASA and corticosteroids in the treatment of active Crohn's disease. Turk. J. Gastroenterol. 2000;11(3):227-230. Does not evaluate a drug of interest; other observational study without a comparison group.
Parsi MA, Lashner BA. Safety of infliximab: primum non nocere. The safety profile of infliximab in patients with Crohn's disease: the Mayo Clinic experience in 500 patients. Inflamm Bowel Dis. 2004;10(4):486-7. No original data; other observational study without a comparison group. [pmid: 15475765].
Parsi MA. Does smoking decrease the response to infliximab in patients with Crohn's disease?. Inflamm Bowel Dis. Suppl 2. 2008;14:S18-9. No original data. [pmid: 18816687].
Parsi MA, Achkar JP, Richardson S, Katz J, Hammel JP, Lashner BA, et al. Predictors of response to infliximab in patients with Crohn's disease. Gastroenterology. 2002;123(3):707-13. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 12198696].
Patel H, Barr A, Jeejeebhoy KN. Renal effects of long-term treatment with 5-aminosalicylic acid. Can J Gastroenterol. 2009;23(3):170-6. Does not apply to key questions; does not report side effects by medication class. [pmid: 19319380].
Pelletier AL, Kalisazan B, Wienckiewicz J, Bouarioua N, Soule JC. Infliximab treatment for symptomatic Crohn's disease strictures. Aliment Pharmacol Ther. 2009;29(3):279-85. Does not apply to key questions. [pmid: 19035967].
Pena JM, Gonzalez-Garcia JJ, Garcia-Alegria J, Barbado FJ, Vazquez JJ. Thrombocytopenia and sulfasalazine. Ann Intern Med. 85;102(2):277-8. No original data; case report or case series. [pmid: 2857076].
Perez-Perez L, Caeiro JL, Fabeiro JM, Allegue F, Zulaica A. Induction of pustular lesions during infliximab therapy for Crohn's disease. Acta Derm Venereol. 2008;88(3):292-3. No original data; case report or case series. [pmid: 18480940].
Perrett CM, Walker SL, O'Donovan P, Warwick J, Harwood CA, Karran P, et al. Azathioprine treatment photosensitizes human skin to ultraviolet A radiation. Br. J. Dermatol. 2008;159(1):198-204. Does not apply to key questions; case report or case series. [pmid: 18489587].
Persoons P, Vermeire S, Demyttenaere K, Fischler B, Vandenberghe J, Van Oudenhove L, et al. The impact of major depressive disorder on the short- and long-term outcome of Crohn's disease treatment with infliximab. Aliment Pharmacol Ther. 2005;22(2):101-10. Does not report side effects by medication class. [pmid: 16011668].
Petersen JA, Rasmussen SN. Biotechnologically manufactured drugs for inflammatory bowel disease. Scand J Gastroenterol. 2001;36(12):1233-8. No original data. [pmid: 11761010].
Petitpain N, Gambier N, Wahl D, Chary-Valckenaere I, Loeuille D, Gillet P. Arterial and venous thromboembolic events during anti-TNF therapy: a study of 85 spontaneous reports in the period 2000-2006. Biomed Mater Eng. 2009;19(4-5):355-64. Case report or case series; other observational study without a comparison group. [pmid: 20042802].
Petrolati A, Altavilla N, Cipolla R, Fenderico P, Forlini G, Nasoni S, et al. Cutaneous metastatic Crohn's disease responsive to infliximab. Am J Gastroenterol. 2009;104(4):1058. Case report or case series. [pmid: 19259072].
Pettersson B, Almer S, Albertioni F, Soderhall S, Peterson C. Differences between children and adults in thiopurine methyltransferase activity and metabolite formation during thiopurine therapy: possible role of concomitant methotrexate. Ther Drug Monit. 2002;24(3):351-8. Does not apply to key questions; other observational study without a comparison group. [pmid: 12021625].
Peyrin-Biroulet L. Anti-TNF therapy and Crohn's disease. Gastroenterol Clin Biol. 2008;32(5 Pt 1):478-81. Not written in English. [pmid: 18439777].
Peyrin-Biroulet L, Laclotte C, Bigard MA. Adalimumab maintenance therapy for Crohn's disease with intolerance or lost response to infliximab: an open-label study. Aliment Pharmacol Ther. 2007;25(6):675-80. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17311600].
Peyrin-Biroulet L, Oussalah A, Williet N, Pillot C, Bresler L, Bigard MA. Impact of azathioprine and tumour necrosis factor antagonists on the need for surgery in newly diagnosed Crohn's disease. Gut. 2011. Does not evaluate a drug of interest; does not apply to key questions.
Phelan C, Wooltorton E. Infliximab and serious hematologic events. CMAJ. 2004;171(9):1045. No original data. [pmid: 15505264].
Piccin A, Cortelazzo S, Rovigatti U, Bourke B, Smith OP. Immunosuppressive treatments in Crohn. Am J Hematol. 2010. No original data; case report or case series.
Picco MF, Zubiaurre I, Adluni M, Cangemi JR, Shelton D. Immunomodulators are associated with a lower risk of first surgery among patients with non-penetrating non-stricturing Crohn's disease. Am J Gastroenterol. 2009;104(11):2754-9. Does not report side effects by medication class. [pmid: 19584832].
Pillot C, Chevaux JB, Bigard MA, Peyrin-Biroulet L. Infliximab 10 mg/kg every 3 weeks for Crohn's disease. Am J Gastroenterol. 2010;105(11):2509-10. No original data; case report or case series. [pmid: 21048692].
Pinto AL, Chebli LA, Ribeiro MS, Pace FH, Moraes JP, do Amaral FJ Jr, et al. Azathioprine therapy in steroid-dependent patients with Crohn disease: results of a 10-year longitudinal follow-up study. Med Sci Monit. 2009;15(5):PI19-26. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19396048].
Pittet V, Juillerat P, Michetti P, Vader JP, Burnand B, Rogler G, et al. Appropriateness of therapy for fistulizing Crohn's disease: Findings from a national inflammatory bowel disease cohort. Aliment. Pharmacol. Ther. 2010;32(8):1007-1016. Does not apply to key questions; other observational study without a comparison group. [pmid: 20937046].
Poggioli G, Laureti S, Pierangeli F, Rizzello F, Ugolini F, Gionchetti P, et al. Local injection of Infliximab for the treatment of perianal Crohn's disease. Dis Colon Rectum. 2005;48(4):768-74. Other observational study without a comparison group. [pmid: 15768185].
Pohl C, Kruis W. Oral budesonide - A further step in the prevention of relapse in Crohn's disease?. Leber Magen Darm. 97;27(4):235-239. Not written in English.
Pollak RD, Karmeli F, Eliakim R, Ackerman Z, Tabb K, Rachmilewitz D. Femoral neck osteopenia in patients with inflammatory bowel disease. Am J Gastroenterol. 98;93(9):1483-90. Does not report side effects by medication class. [pmid: 9732930].
Poritz LS, Rowe WA, Koltun WA. Remicade does not abolish the need for surgery in fistulizing Crohn's disease. Dis Colon Rectum. 2002;45(6):771-5. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 12072629].
Poupardin C, Lemann M, Gendre JP, Sabate JM, Marteau P, Chaussade S, et al. Efficacy of infliximab in Crohn's disease. Results of a retrospective multicenter study with a 15-month follow-up. Gastroenterol Clin Biol. 2006;30(2):247-52. Does not report side effects by medication class. [pmid: 16565658].
Pozler O, Maly J, Bonova O, Dedek P, Fruhauf P, Havlickova A, et al. Incidence of Crohn disease in the Czech Republic in the years 1990 to 2001 and assessment of pediatric population with inflammatory bowel disease. J Pediatr Gastroenterol Nutr. 2006;42(2):186-9. Does not apply to key questions. [pmid: 16456413].
Prabhakar LP, Laramee C, Nelson H, Dozois RR. Role for segmental or abdominal colectomy in Crohn's colitis. DIS. COLON RECTUM. 97;40(1):71-78. Does not apply to key questions. [pmid: 9102265].
Prajapati DN, Knox JF, Emmons J, Saeian K, Csuka ME, Binion DG. Leflunomide treatment of Crohn's disease patients intolerant to standard immunomodulator therapy. J Clin Gastroenterol. 2003;37(2):125-8. Does not evaluate a drug of interest. [pmid: 12869881].
Prantera C, Pallone F, Brunetti G, Cottone M, Miglioli M, Porro GB, et al. Oral 5-aminosalicylic acid (Asacol) in the maintenance treatment of Crohn's disease. GASTROENTEROLOGY. 92;103(2):363-368. Other reason. [pmid: 1634054].
Present DH, Wisch N, Glass JL, Korelitz BI. The efficacy of immunosuppressive therapy in Crohn's disease. A randomized long term double blind study. Gastroenterology. 77;72(5II):A-91. Abstract only.
Present DH, Meltzer SJ, Krumholz MP, Wolke A, Korelitz BI. 6-Mercaptopurine in the management of inflammatory bowel disease: short- and long-term toxicity. Ann Intern Med. 89;111(8):641-9. Does not report side effects by medication class. [pmid: 2802419].
Prokopova L, Zboril V, Abbe LM. The Problems of Crohn's Disease Treatment by anti-TNF: A Theory and Our Experience. Uskali lecby Crohnovy nemoci anti-TNF: Teorie a vlastni zkusenosti. Ceska Slov. Gastroenterol. Hepatol. 2003;57(5):167-170. Not written in English.
Qasim A, McDonald S, Sebastian S, McLoughlin R, Buckley M, O'Connor H, et al. Efficacy and safety of 6-thioguanine in the management of inflammatory bowel disease. Scand J Gastroenterol. 2007;42(2):194-9. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 17327939].
Radke M, Bartolomaeus G, Muller M, Richter I. Acute pancreatitis in Crohn's disease due to 5-ASA therapy. J Pediatr Gastroenterol Nutr. 93;16(3):337-9. Case report or case series. [pmid: 8492268].
Rahhal RM, Bishop WP. Initial clinical experience with allopurinol-thiopurine combination therapy in pediatric inflammatory bowel disease. Inflamm Bowel Dis. 2008;14(12):1678-82. Does not apply to key questions; other observational study without a comparison group. [pmid: 18521913].
Rahier JF, Colombel JF. Opportunistic infections and anti-tumor necrosis factor antagonists in patients with IBD: prevention and diagnosis. Dig. Liver Dis. Suppl. 2008;2(1):23-24. No original data.
Ramadas AV, Gunesh S, Thomas GA, Williams GT, Hawthorne AB. Natural history of Crohn's disease in a population-based cohort from Cardiff (1986-2003): a study of changes in medical treatment and surgical resection rates. Gut. 2010;59(9):1200-6. Other observational study without a comparison group. [pmid: 20650924].
Rampton DS. Methotrexate in Crohn's disease. Gut. 2001;48(6):790-1. No original data. [pmid: 11358896].
Rao SS. 5-Aminosalicylic acid enemas in distal colitis. Gastroenterology. 88;95(6):1698-9. No original data. [pmid: 3181693].
Rasmussen SN, Binder V, Maier K, Bondesen S, Fischer C, Klotz U, et al. Treatment of Crohn's disease with peroral 5-aminosalicylic acid. Gastroenterology. 83;85(6):1350-3. Other observational study without a comparison group. [pmid: 6354827].
Rasmussen SN, Lauritsen K, Tage-Jensen U, Nielsen OH, Bytzer P, Jacobsen O, et al. 5-Aminosalicylic acid in the treatment of Crohn's disease. A 16-week double-blind, placebo-controlled, multicentre study with Pentasa. Scand J Gastroenterol. 87;22(7):877-83. Other reason. [pmid: 3313678].
Ravikumara M, Hinsberger A, Spray CH. Role of methotrexate in the management of Crohn disease. J Pediatr Gastroenterol Nutr. 2007;44(4):427-30. Case report or case series; other observational study without a comparison group. [pmid: 17414138].
Rayner CK, Hart AL, Hayward CM, Emmanuel AV, Kamm MA. Azathioprine dose escalation in inflammatory bowel disease. Aliment Pharmacol Ther. 2004;20(1):65-71. Does not report side effects by medication class. [pmid: 15225172].
Reffitt DM, Meenan J, Sanderson JD, Jugdaohsingh R, Powell JJ, Thompson RP. Bone density improves with disease remission in patients with inflammatory bowel disease. Eur J Gastroenterol Hepatol. 2003;15(12):1267-73. Does not apply to key questions. [pmid: 14624148].
Regadas FS, Pinto RA, Murad-Regadas SM, Canedo JA, Leal M, Nogueras JJ, et al. Short-term outcome of infliximab and other medications on patients with inflammatory bowel disease undergoing ileostomy reversal. Colorectal Dis. 2010. Does not apply to key questions, Does not report side effects by medication class.
Regueiro M, Mardini H. Treatment of perianal fistulizing Crohn's disease with infliximab alone or as an adjunct to exam under anesthesia with seton placement. Inflamm Bowel Dis. 2003;9(2):98-103. Other observational study without a comparison group. [pmid: 12769443].
Regueiro M, Kip KE, Schraut W, Baidoo L, Sepulveda AR, Pesci M, et al. Crohn's disease activity index does not correlate with endoscopic recurrence one year after ileocolonic resection. Inflammatory Bowel Dis. 2011;17(1):118-126. Does not apply to key questions.
Regueiro M, Schraut W, Baidoo L, Kip KE, Sepulveda AR, Pesci M, et al. Infliximab prevents Crohn's disease recurrence after ileal resection. Gastroenterology. 2009;136(2):441-50.e1. quiz 716. Does not apply to key questions. [pmid: 19109962].
Regueiro M, Siemanowski B, Kip KE, Plevy S. Infliximab dose intensification in Crohn's disease. Inflamm Bowel Dis. 2007;13(9):1093-9. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 17480021].
Reichel C, Streit J, Wunsch S. Significant changes of pharmacotherapy in gastroenterological rehabilitation of Crohn's disease. Rehabilitation (Stuttg). 2009;48(6):354-60. Not written in English. [pmid: 20069519].
Reilly MC, Gerlier L, Brabant Y, Brown M. Validity, reliability, and responsiveness of the work productivity and activity impairment questionnaire in Crohn's disease. Clin. Ther. 2008;30(2):393-404. Does not apply to key questions. [pmid: 18343277].
Reinisch W, Gasche C, Wyatt J, Moser G, Lochs H, Vogelsang H, et al. Steroid dependency in Crohn's disease. Lancet. 95;345(8953):859. No original data. [pmid: 7898245].
Reinshagen M, Schutz E, Armstrong VW, Behrens C, von Tirpitz C, Stallmach A, et al. 6-thioguanine nucleotide-adapted azathioprine therapy does not lead to higher remission rates than standard therapy in chronic active crohn disease: results from a randomized, controlled, open trial. Clin Chem. 2007;53(7):1306-14. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 17495015].
Rhodes J, Bainton D, Beck P. Azathioprine in Crohn's disease. Lancet. 70;2(7683):1142. Other reason. [pmid: 4097954].
Rhodes J. Azathioprine in the treatment of Crohn's disease. Br J Surg. 72;59(10):819-21. No original data. [pmid: 4562174].
Ricart E, Sandborn WJ. Infliximab for the treatment of fistulas in patients with Crohn'S disease. Gastroenterology. 99;117(5):1247-8. No original data; other reason. [pmid: 10535892].
Ricart E. Thiopurine and the risk of lymphoma in inflammatory bowel disease. Tiopurinas y riesgo de linfoma en la enfermedad inflamatoria intestinal. Gastroenterol. Hepatol. Continuada. 2010;9(4):193-196. Not written in English.
Riello L, Talbotec C, Garnier-Lengline H, Pigneur B, Svahn J, Canioni D, et al. Tolerance and efficacy of azathioprine in pediatric Crohn's disease. Inflamm Bowel Dis. 2011. Does not evaluate a drug of interest.
Rijk MC, van Hogezand RA, van Lier HJ, van Tongeren JH. Sulphasalazine and prednisone compared with sulphasalazine for treating active Crohn disease. A double-blind, randomized, multicenter trial. Ann Intern Med. 91;114(6):445-50. Other reason. [pmid: 1671631].
Rintamaki H, Sipponen T, Salo HM, Vaarala O, Kolho KL. Serum immune-activation potency and response to anti-TNF-(alpha) therapy in Crohn's disease. World J. Gastroenterol. 2010;16(46):5845-5851. Does not apply to key questions; does not report side effects by medication class. [pmid: 21155006].
Rizzo G, Armuzzi A, Pugliese D, Verbo A, Papa A, Mattana C, et al. Anti-TNF-alpha therapies do not increase early postoperative complications in patients with inflammatory bowel disease. An Italian single-center experience. Int. J. Colorectal Dis. 2011:1-10. Does not apply to key questions.
Robinson RJ, al-Azzawi F, Iqbal SJ, Kryswcki T, Almond L, Abrams K, et al. Osteoporosis and determinants of bone density in patients with Crohn's disease. Dig Dis Sci. 98;43(11):2500-6. Does not report side effects by medication class. [pmid: 9824142].
Robinson RJ, Iqbal SJ, Wolfe R, Patel K, Abrams K, Mayberry JF. The effect of rectally administered steroids on bone turnover: a comparative study. Aliment Pharmacol Ther. 98;12(3):213-7. Does not report side effects by medication class. [pmid: 9570255].
Roblin X, Biroulet LP, Phelip JM, Nancey S, Flourie B. A 6-thioguanine nucleotide threshold level of 400 pmol/8 null 10 8 erythrocytes predicts azathioprine refractoriness in patients with inflammatory bowel disease and normal TPMT activity. Am. J. Gastroenterol. 2008;103(12):3115-3122. Does not apply to key questions. [pmid: 19086961].
Roblin X, Oussalah A, Chevaux JB, Sparrow M, Peyrin-Biroulet L. Use of thiopurine testing in the management of inflammatory bowel diseases in clinical practice: A worldwide survey of experts. Inflammatory Bowel Dis. 2011. Does not report side effects by medication class; other reason.
Roblin X, Phelip JM, Genevois M, Ducros V, Bonaz B. Hyperhomocysteinaemia is associated with osteoporosis in patients with Crohn's disease. Aliment Pharmacol Ther. 2007;25(7):797-804. Does not apply to key questions. [pmid: 17373918].
Roblin X, Serre-Debeauvais F, Phelip JM, Faucheron JL, Hardy G, Chartier A, et al. 6-thioguanine monitoring in steroid-dependent patients with inflammatory bowel diseases receiving azathioprine. Aliment Pharmacol Ther. 2005;21(7):829-39. Does not apply to key questions, Other observational study without a comparison group. [pmid: 15801918].
Rodrigo L, Perez-Pariente JM, Fuentes D, Cadahia V, Garcia-Carbonero A, Nino P, et al. Retreatment and maintenance therapy with infliximab in fistulizing Crohn's disease. Rev Esp Enferm Dig. 2004;96(8):548-54. 554. 8. Does not report side effects by medication class. [pmid: 15449986].
Roggero P, Santus F, Barabino A, Canani RB, Cucchiara S, Guariso G, et al. A prospective pediatric multicenter trial of enteral nutrition and azathioprine in preventing relapses of Crohn disease: preliminary results. Journal of Pediatric Gastroenterology and Nutrition. 2003;36(4):543. Abstract only.
Romano C, Cucchiara S, Barabino A, Annese V, Sferlazzas C. Usefulness of omega-3 fatty acid supplementation in addition to mesalazine in maintaining remission in pediatric Crohn's disease: a double-blind, randomized, placebo-controlled study. World J Gastroenterol. 2005;11(45):7118-21. Does not evaluate a drug of interest. [pmid: 16437657].
Roseau E. Crohn's disease: prevention of relapse with methotrexate or growth hormone. Presse Med. 2000;29(30):1652-3. Not written in English. [pmid: 11089504].
Rosen A, Ursing B, Alm T, Barany F, Bergelin I, Ganrot-Norlin K, et al. A comparative study of metronidazole and sulfasalazine for active Crohn's disease: the cooperative Crohn's disease study in Sweden. I. Design and methodologic considerations. Gastroenterology. 82;83(3):541-9. No original data; does not evaluate a drug of interest. [pmid: 6124473].
Rosen R, Integlia MJ, Bousvaros A. Severe pancytopenia from thiopurine methyltransferase deficiency: a preventable complication of 6-mercaptopurine therapy in children with Crohn disease. J Pediatr Gastroenterol Nutr. 2002;35(5):695-9. Does not evaluate a drug of interest; does not apply to key questionsCase report or case series. [pmid: 12454589].
Rosh JR, Lerer T, Markowitz J, Goli SR, Mamula P, Noe JD, et al. Retrospective Evaluation of the Safety and Effect of Adalimumab Therapy (RESEAT) in pediatric Crohn's disease. Am J Gastroenterol. 2009;104(12):3042-9. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19724267].
Ross S, Rajwal SK, Sugarman I, Picton S, Devlin J, Davison S, et al. Epstein-Barr Virus-associated Lymphoproliferative Disorder in Crohn Disease Treated With Azathioprine. J Pediatr Gastroenterol Nutr. 2010. Does not apply to key questionsCase report or case series.
Roth M, Gross V, Scholmerich J, Ueberschaer B, Ewe K. Treatment of active Crohn's disease with an oral slow-release budesonide formulation. Am J Gastroenterol. 93;88(6):968-9. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 8503403].
Ruemmele FM, Lachaux A, Cezard JP, Morali A, Maurage C, Ginies JL, et al. Efficacy of infliximab in pediatric Crohn's disease: a randomized multicenter open-label trial comparing scheduled to on demand maintenance therapy. Inflamm Bowel Dis. 2009;15(3):388-94. Does not evaluate a drug of interest. [pmid: 19023899].
Russo EA, Iacucci M, Lindsay JO, Campbell S, Hart A, Hamlin J, et al. Survey on the use of adalimumab as maintenance therapy in Crohn's disease in England and Ireland. Eur J Gastroenterol Hepatol. 2010;22(3):334-9. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19528808].
Rutgeerts P, Vantrappen G. New 5-ASA formulations for inflammatory bowel disease. LE NUOVE PREPARAZIONI DI 5-ASA PER LE MALATTIE INFIAMMATORIE INTESTINALI. ARGOMENTI GASTROENTEROL. CLIN. 93;6(1):8-14. Not written in English.
Rutgeerts P. Budesonide led to a greater remission rate and fewer severe adverse events than did mesalamine in Crohn's disease. Gut. 99;45(1):13-4. No original data; other reason. [pmid: 10498451].
Rutgeerts P. Little benefit from mesalazine taken prophylactically after surgery for Crohn's disease. Gut. 2001;48(4):452-3. No original data. [pmid: 11247886].
Sabate JM, Villarejo J, Lemann M, Bonnet J, Allez M, Modigliani R. An open-label study of thalidomide for maintenance therapy in responders to infliximab in chronically active and fistulizing refractory Crohn's disease. Aliment Pharmacol Ther. 2002;16(6):1117-24. Does not evaluate a drug of interest. [pmid: 12030953].
Sahmoud T, Mary JY, Sahmoud T. Mesalazine as a maintenance treatment in Crohn's disease: is it the long awaited solution?. Gut. 97;40(2):284-5. No original data. [pmid: 9071946].
Saibeni S, Virgilio T, D'Inca R, Spina L, Bortoli A, Paccagnella M, et al. The use of thiopurines for the treatment of inflammatory bowel diseases in clinical practice. Dig Liver Dis. 2008;40(10):814-20. Does not evaluate a drug of interest. [pmid: 18479986].
Salamon A, Simon L, Nemesanszky E. First experiences with infliximab therapy in Crohn's disease - Results of a Hungarian multicentre study. Elso tapasztalatok a Crohn-betegseg infliximabkezelese vel - Magyarorszagi multicentrikus tanulmany eredmenyei. Lege Artis Med. 2004;14(7):483-487. Not written in English.
Salmon-Ceron D, Tubach F, Lortholary O, Chosidow O, Bretagne S, Nicolas N, et al. Drug-specific risk of non-tuberculosis opportunistic infections in patients receiving anti-TNF therapy reported to the 3-year prospective French RATIO registry. Ann. Rheum. Dis. 2011;70(4):616-623. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; case report or case series. [pmid: 21177290].
Sample C, Bailey RJ, Todoruk D, Sadowski D, Gramlich L, Milan M, et al. Clinical experience with infliximab for Crohn's disease: the first 100 patients in Edmonton, Alberta. Can J Gastroenterol. 2002;16(3):165-70. Other observational study without a comparison group. [pmid: 11930194].
San Jose Bermejo F, San Roman AL, Algaba A, Van Domselaar M, Carneros JA, Rivero M, et al. Efficacy of premedication with intravenous corticosteroids and antihistaminics in preventing infusion reactions to infliximab. Eficacia de la premedicacion con un esteroide y un antihistaminico en la prevencion de reacciones infusionales por infliximab. Gastroenterol. Hepatol. 2008;31(10):629-632. Not written in English. [pmid: 19174078].
Sanchez Cano D, Ruiz-Villaverde R, Olvera Porcel MC, Callejas Rubio JL, Perez CC, Garcia MG, et al. Evaluation of bone mineral density, bone turnover markers, the OPG/RANKL system and sTNF-RI in Crohn's disease. Gastroenterol. Hepatol. 2011;34(1):3-9. Not written in English. [pmid: 21216496].
Sanchez JM, Maldonado JC, Torres EA, Rivera C. Infliximab in Hispanics: characterization of response to infliximab in an ethnic minority with Crohn's disease. P R Health Sci J. 2005;24(1):11-7. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 15895872].
Sandborn WJ, Schreiber S, Hanauer SB, Colombel JF, Bloomfield R, Lichtenstein GR, PRECiSE 4 Study Investigators. Reinduction with certolizumab pegol in patients with relapsed Crohn's disease: results from the PRECiSE 4 Study. Clinical gastroenterology and hepatology : the official clinical practice journal of the American Gastroenterological Association. 2010;8(8):696-702.e1. Does not evaluate a drug of interest. [pmid: 20363366].
Sandborn WJ. A controlled trial of anti-tumor necrosis factor alpha antibody for Crohn's disease. Gastroenterology. 97;113(3):1042-3. No original data. [pmid: 9288004].
Sandborn WJ. Certolizumab pegol for moderate-to-severe Crohn's disease. Gastroenterol. Hepatol. 2008;4(7):467-468. No original data.
Sandborn WJ. Initial combination therapy in early Crohn's disease. Lancet. 2008;371(9613):635-636. No original data. [pmid: 18295013].
Sandborn WJ, Abreu MT, D'Haens G, Colombel JF, Vermeire S, Mitchev K, et al. Certolizumab Pegol in Patients With Moderate to Severe Crohn's Disease and Secondary Failure to Infliximab. Clin Gastroenterol Hepatol. 2010. Does not evaluate a drug of interest.
Sandborn WJ, Feagan BG, Fedorak RN, Scherl E, Fleisher MR, Katz S, et al. A randomized trial of Ustekinumab, a human interleukin-12/23 monoclonal antibody, in patients with moderate-to-severe Crohn's disease. Gastroenterology. 2008;135(4):1130-41. Does not evaluate a drug of interest. [pmid: 18706417].
Sandborn WJ, Hanauer S, Loftus EV Jr, Tremaine WJ, Kane S, Cohen R, et al. An open-label study of the human anti-TNF monoclonal antibody adalimumab in subjects with prior loss of response or intolerance to infliximab for Crohn's disease. Am J Gastroenterol. 2004;99(10):1984-9. Does not report side effects by medication class. [pmid: 15447761].
Sandborn WJ, Schreiber S, Hanauer SB, Colombel JF, Bloomfield R, Lichtenstein GR. Reinduction With Certolizumab Pegol in Patients With Relapsed Crohn's Disease: Results From the PRECiSE 4 Study. Clin Gastroenterol Hepatol. 2010. Does not report side effects by medication class.
Sandborn WJ, Tremaine WJ, Wolf DC, Targan SR, Sninsky CA, Sutherland LR, et al. Lack of effect of intravenous administration on time to respond to azathioprine for steroid-treated Crohn's disease. Gastroenterology. 99;117(3):527-535. Other reason. [pmid: 10464128].
Sandborn WJ, Van OEC, Zins BJ, Tremaine WJ, Mays DC, Lipsky JJ. An intravenous loading dose of azathioprine decreases the time to response in patients with Crohn's disease. Gastroenterology. 95;109(6):1808-17. Does not evaluate a drug of interest. [pmid: 7498645].
Sanderson J. Incidence of adverse reactions to azathioprine in patients with Crohn's disease. Nat Clin Pract Gastroenterol Hepatol. 2005;2(11):510-1. No original data; does not evaluate a drug of interest. [pmid: 16355154].
Santos JV, Baudet JA, Casellas FJ, Guarner LA, Vilaseca JM, Malagelada JR. Intravenous cyclosporine for steroid-refractory attacks of Crohn's disease. Short- and long-term results. J Clin Gastroenterol. 95;20(3):207-10. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 7797828].
Savilahti E. Sulphasalazine induced immunodeficiency. Br Med J (Clin Res Ed). 83;287(6394):759. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; case report or case series.
Savoye-Collet C, Savoye G, Koning E, Dacher JN, Lerebours E. Fistulizing perianal Crohn's disease: Contrast-enhanced magnetic resonance imaging assessment at 1 year on maintenance anti-TNF-alpha therapy. Inflamm Bowel Dis. 2010. Does not evaluate a drug of interest; does not apply to key questions.
Sayani FA, Prosser C, Bailey RJ, Jacobs P, Fedorak RN. Thiopurine methyltransferase enzyme activity determination before treatment of inflammatory bowel disease with azathioprine: effect on cost and adverse events. Can J Gastroenterol. 2005;19(3):147-51. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 15776134].
Scheurlen C, Kruis W. 5-Aminosalicylic acid preparations in the therapy of chronic bowel disease. 5-Aminosalicylsaure-Praparate In Der Therapie Chronisch-Entzundlicher Darmerkrankungen. INN. MED. 92;19(3):88-93. Not written in English.
Schmidt C, Wittig BM, Moser C, Zeitz M, Stallmach A. Cyclophosphamide pulse therapy followed by azathioprine or methotrexate induces long-term remission in patients with steroid-refractory Crohn's disease. Aliment Pharmacol Ther. 2006;24(2):343-50. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 16842461].
Schmidt S, Mellstrom D, Norjavaara E, Sundh SV, Saalman R. Low bone mineral density in children and adolescents with inflammatory bowel disease: A population-based study from Western Sweden. Inflamm Bowel Dis. 2009;15(12):1844-1850. Does not apply to key questions; other observational study without a comparison group. [pmid: 19408319].
Schnitzler F, Fidder H, Ferrante M, Noman M, Arijs I, Van Assche G, et al. Long-term outcome of treatment with infliximab in 614 patients with Crohn's disease: results from a single-centre cohort. Gut. 2009;58(4):492-500. Does not report side effects by medication class. [pmid: 18832518].
Schoepfer AM, Vavricka SR, Binek J, Felley C, Geyer M, Manz M, et al. Efficacy and safety of certolizumab pegol induction therapy in an unselected Crohn's disease population: results of the FACTS survey. Inflamm Bowel Dis. 2010;16(6):933-8. Other observational study without a comparison group. [pmid: 20014021].
Schreiber S, Hamling J, Zehnter E, Howaldt S, Daerr W, Raedler A, et al. Renal tubular dysfunction in patients with inflammatory bowel disease treated with aminosalicylate. Gut. 97;40(6):761-6. Does not report side effects by medication class. [pmid: 9245930].
Schroder O, Blumenstein I, Schulte-Bockholt A, Stein J. Combining infliximab and methotrexate in fistulizing Crohn's disease resistant or intolerant to azathioprine. Aliment Pharmacol Ther. 2004;19(3):295-301. Other observational study without a comparison group. [pmid: 14984376].
Schroder O, Naumann M, Stein J. Anti-Saccharomyces cerevisiae antibodies and response to infliximab in refractory Crohn's disease. Aliment Pharmacol Ther. 2004;20(7):823-4. Does not apply to key questions; does not report side effects by medication class. [pmid: 15379845].
Schulte C, Dignass AU, Mann K, Goebell H. Reduced bone mineral density and unbalanced bone metabolism in patients with inflammatory bowel disease. Inflamm Bowel Dis. 98;4(4):268-75. Does not apply to key questions. [pmid: 9836078].
Schwartz DA. What is the optimal maintenance treatment for perianal Crohn's disease?. Inflamm Bowel Dis. Suppl 2. 2008;14:S269-70. No original data. [pmid: 18816761].
Sciaudone G, Di Stazio C, Limongelli P, Guadagni I, Pellino G, Riegler G, et al. Treatment of complex perianal fistulas in Crohn disease: infliximab, surgery or combined approach. Can J Surg. 2010;53(5):299-304. Other observational study without a comparison group; other reason. [pmid: 20858373].
Sciaudone G, Pellino G, Riegler G, Selvaggi F. Infliximab in drug-naive patients with failed ileorectal anastomosis for crohn's disease: A new chance for sparing the rectum?. Eur. Surg. Res. 2011;46(4):163-168. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 21454983].
Scribano ML. Adverse events of IBD therapies. Inflamm Bowel Dis. Suppl 2. 2008;14:S210-1. No original data. [pmid: 18816669].
Scribano ML, Marmo R. Azathioprine and mesalamine for prevention of relapse after conservative surgery for Crohn's disease. Azatioprina e mesalazina nella prevenzione della riaccensione dopo intervento chirurgico conservativo per malattia di Crohn. G. Ital. Endosc. Dig. 2006;29(1):61-67. Not written in English.
Segarra Canton O, Infante Pina D, Tormo Carnice R. Infliximab therapy for inflammatory bowel disease: seven years on. An Pediatr (Barc). 2007;67(4):344-51. Not written in English. [pmid: 17949644].
Seiderer J, Brand S, Dambacher J, Pfennig S, Jurgens M, Goke B, et al. Adalimumab in patients with Crohn's disease--safety and efficacy in an open-label single centre study. Aliment Pharmacol Ther. 2007;25(7):787-96. Does not evaluate a drug of interest. [pmid: 17373917].
Selby LA, Hess D, Shashidar H, de Villiers WJ, Selby LA. Crohn's disease, infliximab and idiopathic thrombocytopenic purpura. Inflamm Bowel Dis. 2004;10(5):698-700. Case report or case series. [pmid: 15472539].
Semeao EJ, Jawad AF, Stouffer NO, Zemel BS, Piccoli DA, Stallings VA. Risk factors for low bone mineral density in children and young adults with Crohn's disease. J Pediatr. 99;135(5):593-600. Does not report side effects by medication class. [pmid: 10547248].
Seo JK, Yeon KM, Chi JG. Inflammatory bowel disease in children--clinical, endoscopic, radiologic and histopathologic investigation. J Korean Med Sci. 92;7(3):221-35. Does not evaluate a drug of interest. [pmid: 1285921].
Serra I, Oller B, Manosa M, Naves JE, Zabana Y, Cabre E, et al. Systemic amyloidosis in inflammatory bowel disease: Retrospective study on its prevalence, clinical presentation, and outcome. J. Crohn's Colitis. 2010;4(3):269-274. Case report or case series. [pmid: 21122515].
Serrano MS, Schmidt-Sommerfeld E, Kilbaugh TJ, Brown RF, Udall JN Jr, Mannick EE. Use of infliximab in pediatric patients with inflammatory bowel disease. Ann Pharmacother. 2001;35(7-8):823-8. Other observational study without a comparison group. [pmid: 11485127].
Serrate C, Silva-Moreno M, Dartigues P, Poujol-Robert A, Sokol H, Gorin NC, et al. Epstein-Barr virus-associated lymphoproliferation awareness in hemophagocytic syndrome complicating thiopurine treatment for Crohn's disease. Inflamm Bowel Dis. 2009;15(10):1449-51. Case report or case series. [pmid: 19177429].
Sesin GP, Mucciardi N, Almeida S. Mesalamine-associated pleural effusion with pulmonary infiltration. Am J Health Syst Pharm. 98;55(21):2304-5. Case report or case series. [pmid: 9825882].
Seydtaghia F, De Saussure P, Hadengue A. High frequency of cutaneous adverse effects under Infliximab. Geneva experience, 1999-2008. Frequence elevee d'Effets secondaires cutanes sous infliximab Experience aGeneve, 1999-2008. Rev. Med. Suisse. 2011;7(286):619-623. Not written in English. [pmid: 21510346].
Shale M, Kanfer E, Panaccione R, Ghosh S. Hepatosplenic T cell lymphoma in inflammatory bowel disease. Gut. 2008;57(12):1639-41. No original data. [pmid: 18667489].
Shanahan F, Bernstein CN. Safety of low-dose purine analogues in inflammatory bowel disease. Gastroenterology. 94;107(6):1905-6. No original data. [pmid: 7958713].
Shaye OA, Yadegari M, Abreu MT, Poordad F, Simon K, Martin P, et al. Hepatotoxicity of 6-mercaptopurine (6-MP) and Azathioprine (AZA) in adult IBD patients. Am J Gastroenterol. 2007;102(11):2488-94. Does not report side effects by medication class. [pmid: 17764490].
Sheehan T, Tansey P, Cochran KM, O'Donnell JR. Inflammatory bowel disease, anaemia and sulphasalazine. Clin Lab Haematol. 85;7(3):275-8. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; case report or case series. [pmid: 2866864].
Sheffield LJ, Irving P, Gupta A, Byron K, Macrae FA, Phillimore H, et al. Thiopurine methyltransferase and thiopurine metabolite testing in patients with inflammatory bowel disease who are taking thiopurine drugs. Pharmacogenomics. 2009;10(7):1091-9. Does not report side effects by medication class. [pmid: 19604082].
Shen B, Remzi FH, Lavery IC, Lopez R, Queener E, Shen L, et al. Administration of adalimumab in the treatment of Crohn's disease of the ileal pouch. Aliment Pharmacol Ther. 2009;29(5):519-26. Does not report side effects by medication class. [pmid: 19183338].
Shergill AK, Terdiman JP. The Early Use of Immunosuppression Reduces Morbidity in Patients With Moderately Severe or Severe Crohn's Disease. Gastroenterology. 2008;135(4):1417-1420. No original data. [pmid: 18773903].
Shipkova M, Franz J, Abe M, Klett C, Wieland E, Andus T. Association between adverse effects under azathioprine therapy and inosine triphosphate pyrophosphatase activity in patients with chronic inflammatory bowel disease. Ther Drug Monit. 2011. Does not evaluate a drug of interest; does not apply to key questions.
Siegel CA, Hur C, Korzenik JR, Gazelle GS, Sands BE. Risks and benefits of infliximab for the treatment of Crohn's disease. Clin Gastroenterol Hepatol. 2006;4(8):1017-24. quiz 976. No original data. [pmid: 16843733].
Siemanowski B, Regueiro M. Management of perianal fistula in Crohn's disease. Inflamm Bowel Dis. Suppl 2. 2008;14:S266-8. No original data. [pmid: 18816659].
Silvennoinen JA, Karttunen TJ, Niemela SE, Manelius JJ, Lehtola JK. A controlled study of bone mineral density in patients with inflammatory bowel disease. Gut. 95;37(1):71-6. Does not apply to key questions. [pmid: 7672685].
Singh H, Demers AA, Nugent Z, Mahmud SM, Kliewer EV, Bernstein CN. Risk of cervical abnormalities in women with inflammatory bowel disease: a population-based nested case-control study. Gastroenterology. 2009;136(2):451-8. RCT patient population not exclusively Crohn's or observational study not exclusively IBD. [pmid: 18996382].
Singleton JW. Azathioprine has a very limited role in the treatment of Crohn's disease. Dig Dis Sci. 81;26(4):368-71. No original data; does not report side effects by medication class. [pmid: 6113105].
Singleton JW, Hanauer SB, Gitnick GL, Peppercorn MA, Robinson MG, Wruble LD, et al. Mesalamine capsules for the treatment of active Crohn's disease: results of a 16-week trial. Pentasa Crohn's Disease Study Group. Gastroenterology. 93;104(5):1293-301. Other reason. [pmid: 8482443].
Skacel M, Petras RE, Gramlich TL, Sigel JE, Richter JE, Goldblum JR. Infliximab in Crohn's disease: First anniversary clinical experience. Am. J. Gastroenterol. 2000;95(12):3469-3477. Does not evaluate a drug of interest; does observational study without a comparison group. [pmid: 11151879].
Skelly MM, Logan RF, Jenkins D, Mahida YR, Hawkey CJ. Toxicity of mycophenolate mofetil in patients with inflammatory bowel disease. Inflamm Bowel Dis. 2002;8(2):93-7. Does not evaluate a drug of interest. [pmid: 11854606].
Slattery E, Keegan D, Hyland J, O'Donoghue D, Mulcahy HE. Surgery, Crohn's disease, and the biological era: Has there been an impact?. J. Clin. Gastroenterol. 2010. Other observational study without a comparison group; does not report side effects by medication class.
Socha P, Wawer Z, Ryzko J, Orlowska E, Szczepanski M, Kierkus J, et al. Efficacy and safety of cyclosporine in the treatment of inflammatory bowel disease in children - a retrospective study. Med Wieku Rozwoj. 2006;10(2):429-35. Not written in English. [pmid: 16825713].
Sokol H, Seksik P, Nion-Larmurier I, Vienne A, Beaugerie L, Cosnes J. Current smoking, not duration of remission, delays Crohn's disease relapse following azathioprine withdrawal. Inflamm Bowel Dis. 2010;16(3):362-3. Other observational study without a comparison group. [pmid: 19462422].
Soon SY, Ansari A, Yaneza M, Raoof S, Hirst J, Sanderson JD. Experience with the use of low-dose methotrexate for inflammatory bowel disease. Eur J Gastroenterol Hepatol. 2004;16(9):921-6. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 15316419].
Sorrentino D, Paviotti A, Terrosu G, Avellini C, Geraci M, Zarifi D. Low-Dose Maintenance Therapy With Infliximab Prevents Postsurgical Recurrence of Crohn's Disease. Clin Gastroenterol Hepatol. 2010. Does not apply to key questions; other observational study without a comparison group.
Sorrentino D, Terrosu G, Avellini C, Maiero S. Infliximab with low-dose methotrexate for prevention of postsurgical recurrence of ileocolonic Crohn disease. Arch Intern Med. 2007;167(16):1804-7. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 17846401].
Sorrentino D, Terrosu G, Vadala S, Avellini C. Fibrotic strictures and anti-TNF-alpha therapy in Crohn's disease. Digestion. 2007;75(1):22-4. Case report or case series. [pmid: 17429204].
Sou S, Matsui T, Yao T, Yorioka M, Tsuda S, Kikuchi Y, et al. Clinical and endoscopic healing after infliximab treatment in patients with Crohn's disease. Dig. Endosc. 2006;18(1):29-33. Other observational study without a comparison group.
Sousa H, Portela F, Cipriano MA. Posttransplant lymphoproliferative disorders in patients with IBD on immunosuppressive treatment. Inflamm Bowel Dis. 2009;15(3):481-3. Case report or case series. [pmid: 18668677].
Sparberg M, Kirsner JB. Long-term corticosteroid therapy for regional enteritis: an analysis of 58 courses in 54 patients. Am J Dig Dis. 66;11(11):865-80. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 5954664].
Sparrow MP, Hande SA, Friedman S, Cao D, Hanauer SB. Effect of allopurinol on clinical outcomes in inflammatory bowel disease nonresponders to azathioprine or 6-mercaptopurine. Clin Gastroenterol Hepatol. 2007;5(2):209-14. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17296529].
Spector R. The use of sulfasalazine in the treatment of inflammatory bowel disease. J Iowa Med Soc. 83;73(6):230-4. No original data. [pmid: 6135735].
Stange EF, Modigliani R, Pena AS, Wood AJ, Feutren G, Smith PR. European trial of cyclosporine in chronic active Crohn's disease: a 12-month study. The European Study Group. Gastroenterology. 95;109(3):774-82. Does not evaluate a drug of interest. [pmid: 7657105].
Stange EF. In the case of nonresponse, what is the second-level treatment for induction of remission in Crohn's disease?. Inflamm Bowel Dis. Suppl 2. 2008;14:S251-2. No original data. [pmid: 18816712].
Steenholdt C, Svenson M, Bendtzen K, Thomsen OO, Brynskov J, Ainsworth MA. Severe infusion reactions to infliximab: Aetiology, immunogenicity and risk factors in patients with inflammatory bowel disease. Aliment. Pharmacol. Ther. 2011. Case report or case seriesOther reason.
Steiner SJ, Pfefferkorn MD, Fitzgerald JF, Denne SC. Effects of infliximab and parenteral nutrition on albumin and fibrinogen synthesis rates in pediatric Crohn disease. J Pediatr Gastroenterol Nutr. 2008;47(5):579-84. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 18979581].
Steinwurz F. Clinical experience with the use of infliximab in 44 patients with Crohn's disease. Arq Gastroenterol. 2003;40(3):198-200. Not written in English. [pmid: 15029398].
Stepanas AV, Grant AK, Alp MH. Corticosteroid therapy in Crohn's colitis. Aust N Z J Med. 71;1(1):30-4. Case report or case seriesOther observational study without a comparison group. [pmid: 5284081].
Stephens MC, Shepanski MA, Mamula P, Markowitz JE, Brown KA, Baldassano RN. Safety and steroid-sparing experience using infliximab for Crohn's disease at a pediatric inflammatory bowel disease center. Am J Gastroenterol. 2003;98(1):104-11. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 12526944].
Sternthal MB, Murphy SJ, George J, Kornbluth A, Lichtiger S, Present DH. Adverse events associated with the use of cyclosporine in patients with inflammatory bowel disease. Am J Gastroenterol. 2008;103(4):937-43. Does not evaluate a drug of interestDoes not report side effects by medication class. [pmid: 18177449].
Stocco G, Martelossi S, Barabino A, Decorti G, Bartoli F, Montico M, et al. Glutathione-S-transferase genotypes and the adverse effects of azathioprine in young patients with inflammatory bowel disease. Inflamm Bowel Dis. 2007;13(1):57-64. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17206640].
Stocco G, Martelossi S, Barabino A, Fontana M, Lionetti P, Decorti G, et al. TPMT genotype and the use of thiopurines in paediatric inflammatory bowel disease. Dig Liver Dis. 2005;37(12):940-5. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 16202677].
Stockbrugger RW, Schoon EJ, Bollani S, Mills PR, Israeli E, Landgraf L, et al. Discordance between the degree of osteopenia and the prevalence of spontaneous vertebral fractures in Crohn's disease. Aliment Pharmacol Ther. 2002;16(8):1519-27. Does not apply to key questions. [pmid: 12182752].
Stokkers PC, Camoglio L, van Deventer SJ. Tumor necrosis factor (TNF) in inflammatory bowel disease: gene polymorphisms, animal models, and potential for anti-TNF therapy. J Inflamm. 95-96;47(1-2):97-103. No original data; does not apply to key questions. [pmid: 8913936].
Stricker T, Braegger CP. Antibody to tumor necrosis factor in the treatment of Crohn's disease. J Pediatr Gastroenterol Nutr. 98;27(3):369-70. No original dataAbstract only. [pmid: 9740217].
Stuby U, Biesenbach G, Pieringer H. Administration of infliximab in general practitioners' offices is safe. Clin Rheumatol. 2007;26(11):1863-6. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 17322962].
Sturdevant RA, Singleton JW, Deren JL, Law DH, McCleery JL. Azathioprine-related pancreatitis in patients with Crohn's disease. Gastroenterology. 79;77(4 Pt 2):883-6. Other reason. [pmid: 38178].
Sutherland LR, Martin F, Bailey RJ, Fedorak RN, Poleski M, Dallaire C, et al. A randomized, placebo-controlled, double-blind trial of mesalamine in the maintenance of remission of Crohn's disease. GASTROENTEROLOGY. 97;112(4):1069-1077. Other reason. [pmid: 9097988].
Suwannalai P, Auethavekiat P, Udomsubpayakul U, Janvitayanujit S. The infectious profiles of anti-tumor necrosis factor agents in a Thai population: A retrospective study a the university-based hospital. Int. J. Rheum. Dis. 2009;12(2):118-124. Does not apply to key questions; other observational study without a comparison group. [pmid: 20374328].
Swaminath A, Lebwohl B, Capiak KM, Present DH. Practice patterns in the use of anti-tumor necrosis factor alpha agents in the management of Crohn's disease: A US national practice survey comparing experts and non-experts. Dig. Dis. Sci. 2011;56(4):1160-1164. RCT patient population not exclusively Crohn's or observational study not exclusively IBD; other reason. [pmid: 21181440].
Swaminath A, Ullman T, Rosen M, Mayer L, Lichtiger S, Abreu MT. Early clinical experience with adalimumab in treatment of inflammatory bowel disease with infliximab-treated and naive patients. Aliment Pharmacol Ther. 2009;29(3):273-8. Does not report side effects by medication class. [pmid: 19006540].
Szamosi T, Banai J, Lakatos L, Czegledi Z, David G, Zsigmond F, et al. Early azathioprine/biological therapy is associated with decreased risk for first surgery and delays time to surgery but not reoperation in both smokers and nonsmokers with Crohn's disease, while smoking decreases the risk of colectomy in ulcerative colitis. Eur J Gastroenterol Hepatol. 2010;22(7):872-9. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19648821].
Takahashi S, Takagi S, Shiga H, Umemura K, Endo K, Kakuta Y, et al. Scheduled maintenance therapy with infliximab improves the prognosis of Crohn's disease: a single center prospective cohort study in Japan. Tohoku J Exp Med. 2010;220(3):207-15. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 20208416].
Takatsu N, Matsui T, Murakami Y, Ishihara H, Hisabe T, Nagahama T, et al. Adverse reactions to azathioprine cannot be predicted by thiopurine S-methyltransferase genotype in Japanese patients with inflammatory bowel disease. J Gastroenterol Hepatol. 2009;24(7):1258-64. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19682195].
Talbot C, Sagar PM, Johnston MJ, Finan PJ, Burke D. Infliximab in the surgical management of complex fistulating anal Crohn's disease. Colorectal Dis. 2005;7(2):164-8. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 15720356].
Tanaka S, Matsuo K, Sasaki T, Nakano M, Sakai K, Beppu R, et al. Clinical advantages of combined seton placement and infliximab maintenance therapy for perianal fistulizing Crohn's disease: when and how were the seton drains removed?. Hepatogastroenterology. 2010;57(97):3-7. Does not apply to key questions; other observational study without a comparison group. [pmid: 20422862].
Tankova L, Mendizova A, Penchev P, Muhtarov M. Therapeutical effect of remicade in Crohn's disease. Gen. Med. 2002;4(1):20-24. Other reason.
Tao QS, Ren JA, Ji ZL, Li JS, Wang XB, Jiang XH. Maintenance effect of polyglycosides of Tripterygium wilfordii on remission in postoperative Crohn disease. Zhonghua Wei Chang Wai Ke Za Zhi. 2009;12(5):491-3. Not written in English. [pmid: 19742342].
Te HS, Schiano TD, Kuan SF, Hanauer SB, Conjeevaram HS, Baker AL. Hepatic effects of long-term methotrexate use in the treatment of inflammatory bowel disease. Am J Gastroenterol. 2000;95(11):3150-6. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 11095334].
Teitelbaum JE, Saeed S, Triantafyllopoulou M, Daum F. Infliximab in pediatric Crohn disease patients with enterovesicular fistulas. J Pediatr Gastroenterol Nutr. 2007;44(2):279-82. Case report or case series. [pmid: 17255846].
Teml A, Schwab M, Hommes DW, Almer S, Lukas M, Feichtenschlager T, et al. A systematic survey evaluating 6-thioguanine-related hepatotoxicity in patients with inflammatory bowel disease. Wien. Klin. Wochenschr. 2007;119(17-18):519-526. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 17943403].
Tenore A, Berman WF, Parks JS, Bongiovanni AM. Basal and stimulated serum growth hormone concentrations in inflammatory bowel disease. J Clin Endocrinol Metab. 77;44(4):622-8. Does not apply to key questions; does not report side effects by medication class. [pmid: 14969].
Terdiman JP. Prevention of postoperative recurrence in Crohn's disease. Clin Gastroenterol Hepatol. 2008;6(6):616-20. No original data. [pmid: 17967564].
Terranova M, Leonello G, Macri A, Versaci A, Scuderi G, Crisafulli C, et al. Enteral nutrition in the short-term treatment of active inflammatory bowel diseases: A single-centre experience. Rivista Italiana di Nutrizione Parenterale Ed Enterale. 2001;19(1):12-17. Not written in English.
Teshima C, Fedorak RN. Are there differences in type, dosage, and method of administration for the systemic steroids in IBD treatment?. Inflamm Bowel Dis. Suppl 2. 2008;14:S216-8. No original data. [pmid: 18816775].
Teshima CW, Thompson A, Dhanoa L, Dieleman LA, Fedorak RN. Long-term response rates to infliximab therapy for Crohn's disease in an outpatient cohort. Can J Gastroenterol. 2009;23(5):348-52. Other observational study without a comparison group. [pmid: 19440565].
Thayu M, Leonard MB, Hyams JS, Crandall WV, Kugathasan S, Otley AR, et al. Improvement in biomarkers of bone formation during infliximab therapy in pediatric Crohn's disease: results of the REACH study. Clin Gastroenterol Hepatol. 2008;6(12):1378-84. Does not evaluate a drug of interest. [pmid: 19081527].
Thia KT, Li M, Ling KL, Kong SC, Ooi CJ. Azathioprine is effective in corticosteroid-dependent Asian inflammatory bowel disease patients. Inflammatory Bowel Dis. 2011;17(3):809-815. Other observational study without a comparison group.
Thodis E, Rossos P, Habal F, Oreopoulos D. Negative impact of Crohn's disease on bone mineral mass. J Musculoskelet Neuronal Interact. 2003;3(3):246-50. Does not report side effects by medication class. [pmid: 15758348].
Thomas MC, Schlup MM. Budesonide substitution in Crohn's disease relieves CNS toxicity of systemic steroids. Med J Aust. 98;169(10):560. Case report or case series. [pmid: 9861918].
Thomas P, Seaton A, Edwards J. Respiratory disease due to sulphasalazine. Clin Allergy. 74;4(1):41-7. Case report or case series. [pmid: 4824571].
Thomsen O, Cortot A, Jewell D, Wright JP, Winter T, Veloso FT, et al. Budesonide CIR is more effective than mesalazine in active Crohn's disease. A 16 week, international randomized, double-blind multicentre trial [abstract]. Gut. Suppl 3. 97;41:A70. Abstract only.
Thomsen O, Cortot A, Jewell D, Wright JP, Winther T, Veloso FT, et al. Budesonide CIR improved quality of life more than mesalazine measured by psychological general well-being index in active Crohn's disease. A 16-week international, randomized, double-blind multicentre trial [abstract]. Gut. Suppl 3. 97;41:A223. Abstract only.
Tiemi J, Komati S, Sdepanian VL. Effectiveness of infliximab in Brazilian children and adolescents with Crohn disease and ulcerative colitis according to clinical manifestations, activity indices of inflammatory bowel disease, and corticosteroid use. J Pediatr Gastroenterol Nutr. 2010;50(6):628-33. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 20386321].
Tietjen K, Behrens R, Weimann E. Growth failure in children and adolescents with Crohn's disease. Turk J Gastroenterol. 2009;20(1):13-9. Does not apply to key questionsOther observational study without a comparison groupDoes not report side effects by medication class. [pmid: 19330730].
Tillinger W, Gasche C, Reinisch W, Lichtenberger C, Bakos S, Dejaco C, et al. Influence of topically and systemically active steroids on circulating leukocytes in Crohn's disease. Am J Gastroenterol. 98;93(10):1848-53. Other reason. [pmid: 9772043].
Tobias JH, Sasi MR, Greenwood R, Probert CS. Rapid hip bone loss in active Crohn's disease patients receiving short-term corticosteroid therapy. Aliment Pharmacol Ther. 2004;20(9):951-7. Does not apply to key questions. [pmid: 15521842].
Tolia V. Sulfasalazine desensitization in children and adolescents with chronic inflammatory bowel disease. Am J Gastroenterol. 92;87(8):1029-32. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 1353658].
Tomecki R, Bartnik W, Butruk E, Kosciuczyk A, Kozlowska A, Marlicz K, et al. Assessment of the efficacy, tolerance and safety of infliximab (Remicade) in the treatment of Crohn's disease - Results of an open, multicentre clinical trial. Gastroenterol. Pol. 2004;11(6):537-542. Does not evaluate a drug of interest; other observational study without a comparison group.
Toovey S, Hudson E, Hendry WF, Levi AJ. Sulphasalazine and male infertility: reversibility and possible mechanism. Gut. 81;22(6):445-51. Other reason. [pmid: 6114897].
Topstad DR, Panaccione R, Heine JA, Johnson DR, MacLean AR, Buie WD. Combined seton placement, infliximab infusion, and maintenance immunosuppressives improve healing rate in fistulizing anorectal Crohn's disease: a single center experience. Dis Colon Rectum. 2003;46(5):577-83. Other observational study without a comparison group. [pmid: 12792431].
Tougeron D, Savoye G, Savoye-Collet C, Koning E, Michot F, Lerebours E. Predicting factors of fistula healing and clinical remission after infliximab-based combined therapy for perianal fistulizing Crohn's disease. Dig Dis Sci. 2009;54(8):1746-52. Does not apply to key questions; other observational study without a comparison group. [pmid: 19003531].
Treton X, Bouhnik Y, Mary JY, Colombel JF, Duclos B, Soule JC, et al. Azathioprine withdrawal in patients with Crohn's disease maintained on prolonged remission: a high risk of relapse. Clin Gastroenterol Hepatol. 2009;7(1):80-5. Does not evaluate a drug of interest. [pmid: 18849016].
Triantafillidis JK, Fouskas J, Malgarinos G, Malli Ch, Gikas A, Mylonaki M, et al. Short and long-term results of adalimumab treatment of patients with active Crohn's disease: Experience of a Greek single center for inflammatory bowel disease. Ann. Gastroenterol. 2009;22(3):168-172. Other observational study without a comparison group; does not report side effects by medication class.
Triantafillidis JK, Mantzaris G, Karagiannis J, Papavasilliou E, Papatheodoridis G, Fouskas J, et al. Similar response to adalimumab in patients with active Crohn's disease either naive to biologic agents or with prior loss of response or intolerance to infliximab. Rev Med Chir Soc Med Nat Iasi. 2010;114(1):85-90. Other observational study without a comparison group. [pmid: 20509281].
Trinder MW, Lawrance IC. Efficacy of adalimumab for the management of inflammatory bowel disease in the clinical setting. J Gastroenterol Hepatol. 2009;24(7):1252-7. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 19220669].
Tripathi RC, Kipp MA, Tripathi BJ, Kirschner BS, Borisuth NS, Shevell SK, et al. Ocular toxicity of prednisone in pediatric patients with inflammatory bowel disease. Lens Eye Toxic Res. 92;9(3-4):469-82. Other reason. [pmid: 1301798].
Tripathi RC, Kirschner BS, Kipp M, Tripathi BJ, Slotwiner D, Borisuth NS, et al. Corticosteroid treatment for inflammatory bowel disease in pediatric patients increases intraocular pressure. Gastroenterology. 92;102(6):1957-61. Does not evaluate a drug of interest. [pmid: 1587414].
Tsujikawa T, Andoh A, Inatomi O, Bamba S, Nakahara T, Sasaki M, et al. Alendronate improves low bone mineral density induced by steroid therapy in Crohn's disease. Intern Med. 2009;48(12):933-7. Does not report side effects by medication class. [pmid: 19525577].
Turner D, Grossman AB, Rosh J, Kugathasan S, Gilman AR, Baldassano R, et al. Methotrexate following unsuccessful thiopurine therapy in pediatric Crohn's disease. Am J Gastroenterol. 2007;102(12):2804-12. quiz 2803, 2813. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18042110].
Tursi A, Elisei W, Brandimarte G, Giorgetti G, Penna A, Castrignano V. Safety and effectiveness of infliximab for inflammatory bowel diseases in clinical practice. Eur Rev Med Pharmacol Sci. 2010;14(1):47-55. No original dataDoes not report side effects by medication class. [pmid: 20184089].
Tursi A, Giorgetti GM, Brandimarte G, Elisei W. Safety and effectiveness of long-term budesonide treatment in maintaining remission in patients with mild-to-moderate Crohn's disease. Inflamm Bowel Dis. 2007;13(9):1184-6. Other observational study without a comparison group. [pmid: 17410564].
Tursi A, Giorgetti GM, Brandimarte G, Elisei W, Aiello F. Beclomethasone dipropionate for the treatment of mild-to-moderate Crohn's disease: an open-label, budesonide-controlled, randomized study. Med Sci Monit. 2006;12(6):PI29-32. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 16733496].
Uchino M, Ikeuchi H, Bando T, Matsuoka H, Takesue Y, Takahashi Y, et al. Long-term efficacy of infliximab maintenance therapy for perianal Crohn's disease. World J. Gastroenterol. 2011;17(9):1174-1179. Does not evaluate a drug of interest. [pmid: 21448422].
Uhlen S, Belbouab R, Narebski K, Goulet O, Schmitz J, Cezard JP, et al. Efficacy of methotrexate in pediatric Crohn's disease: a French multicenter study. Inflamm Bowel Dis. 2006;12(11):1053-7. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17075346].
Umeno J, Matsumoto T, Jo Y, Ichikawa M, Urabe K, Iida M. Psoriasis during anti-tumor necrosis factor-alpha therapy for Crohn's disease. Inflamm Bowel Dis. 2007;13(9):1188-9. Case report or case series. [pmid: 17427237].
Usta Y, Ozen H, Gurakan F, Uslu N, Saltik-Temizel IN, Demir H, et al. Hypereosinophilia due to mesalazine treatment. J Clin Gastroenterol. 2009;43(4):382. Case report or case series. [pmid: 19309777].
Vadan R, Gheorghe LS, Constantinescu A, Gheorghe C. The prevalence of malnutrition and the evolution of nutritional status in patients with moderate to severe forms of Crohn's disease treated with Infliximab. Clin. Nutr. 2011;30(1):86-91. Does not apply to key questions. [pmid: 20719413].
Vadan R, Gheorghe L, Gheorghe C, Badea M, Cotruta B, Angelescu C, et al. The long term efficacy of Infliximab therapy in Crohn's disease: The experience of a tertiary referral center from Romania. Arch. Balk. Med. Union. 2007;42(1):5-10. Other reason.
Vahedi H, Momtahen S, Olfati G, Abtahi A, Hosseini S, Kazzazi AS, et al. A case-control study on risk factors of osteoporosisin patients with Crohn's disease. Arch Iran Med. 2009;12(6):570-5. Does not evaluate a drug of interest. [pmid: 19877750].
Van Assche G. Optimizing the benefit to risk ratio of medical therapy of inflammatory bowel diseases. Verh K Acad Geneeskd Belg. 2008;70(5-6):339-46. No original data. [pmid: 19725393].
Van Assche G, Vermeire S, Noman M, Amant C, Weyts E, Vleminckx A, et al. Infliximab administered with shortened infusion times in a specialized IBD infusion unit: A prospective cohort study. J. Crohn's Colitis. 2010;4(3):329-333. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 21122522].
van Balkom BP, Schoon EJ, Stockbrugger RW, Wolters FL, van Hogezand RA, van Deventer SJ, et al. Effects of anti-tumour necrosis factor-alpha therapy on the quality of life in Crohn's disease. Aliment Pharmacol Ther. 2002;16(6):1101-7. Other observational study without a comparison group. [pmid: 12030951].
van Bodegraven AA, Sloots CE, Felt-Bersma RJ, Meuwissen SG. Endosonographic evidence of persistence of Crohn's disease-associated fistulas after infliximab treatment, irrespective of clinical response. Dis Colon Rectum. 2002;45(1):39-45. discussion 45-6. Case report or case series; does not report side effects by medication class. [pmid: 11786762].
van der Valk ME, van Oijen MG, Ammerlaan M, Siersema PD, Oldenburg B. Crohn's disease patients treated with adalimumab benefit from co-treatment with immunomodulators. Gut. 2011. Does not evaluate a drug of interest; does not report side effects by medication class.
van Deventer SJH, Rutgeerts P, Targan SR, Hanauer SB, Mayer L, Present D, et al. Anti-tumor necrosis factor antibody cA2 treatment induces clinical remissions in patients with active Crohn's disease [abstract]. Gut. 96;39(Suppl 3):A188. Abstract only.
van Deventer SJH, van Hogezand R, Present D, Hanauer S, Targan S, D'haens G, et al. Controlled study of anti-TNF-alfa treatment for enterocutaneous fistulae complicating Crohn's disease [abstract]. Gut. Suppl 3. 97;41:A2. Abstract only.
van Deventer SJ. Anti-TNF antibody treatment of Crohn's disease. Ann Rheum Dis. Suppl 1. 99;58:I114-20. No original data. [pmid: 10577987].
Van Domselaar M, Lopez San Roman A, Bastos Oreiro M, Garrido Gomez E. Lymphoproliferative disorders in an inflammatory bowel disease unit. Trastornos linfoproliferativos en una unidad de enfermedad inflamatoria intestinal. Gastroenterol Hepatol. 2010;33(1):12-16. Not written in English. [pmid: 19889478].
van Dullemen HM, van Deventer SJ, Hommes DW, Bijl HA, Jansen J, Tytgat GN, et al. Treatment of Crohn's disease with anti-tumor necrosis factor chimeric monoclonal antibody (cA2). Gastroenterology. 95;109(1):129-35. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 7797011].
Van Hees P, Ten Velde G, Van Hogezand R, et al. Effect of sulphasalazine in patients with Crohn's disease. A controlled double-blind trial. Hepato-Gastroenterology. 80;27(SUPPL.):E38.5. Abstract only.
Van Hees P, Van Hogezand R, Ten Velde G, et al. Effect of sulphasalazine in patients with active Crohn's disease. A controlled double-blind trial. Netherlands Journal of Medicine. 81;24(4):157. Other reason.
Van Hees PA, Van Lier HJ, Van Elteren PH, Driessen M, Van Hogezand RA, Ten Velde GP, et al. Effect of sulphasalazine in patients with active Crohn's disease: a controlled double-blind study. Gut. 81;22(5):404-9. Other reason. [pmid: 6114023].
Van Staa TP, Travis S, Leufkens HG, Logan RF. 5-aminosalicylic acids and the risk of renal disease: a large British epidemiologic study. Gastroenterology. 2004;126(7):1733-9. Does not report side effects by medication class. [pmid: 15188168].
Vandeputte L, D'Haens G, Baert F, Rutgeerts P. Methotrexate in refractory Crohn's disease. Inflamm Bowel Dis. 99;5(1):11-5. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 10028444].
Vecchi M, Spina L, Pastorelli L, Cavallaro F, Ciscato C. The relevance of mucosal healing. Dig. Liver Dis. Suppl. 2008;2(1):9-10. No original data.
Veres G, Szabo D, Varkonyi A, Tari B, Polgar M, B. Kovacs J, et al. Analysis of infliximab treated pediatric patients with Crohn disease in Hungary. Crohn-beteg gyermekek infliximabkezelesenek kezdeti tapasztalatai hazankban. Orvosi Hetil. 2010;151(5):179-183. Not written in English.
Vernier-Massouille G, Cosnes J, Lemann M, Marteau P, Reinisch W, Laharie D, et al. Nodular regenerative hyperplasia in patients with inflammatory bowel disease treated with azathioprine. Gut. 2007;56(10):1404-9. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 17504943].
Vestergaard P, Krogh K, Rejnmark L, Laurberg S, Mosekilde L. Fracture risk is increased in Crohn's disease, but not in ulcerative colitis. Gut. 2000;46(2):176-81. Does not apply to key questions. [pmid: 10644310].
Viazis N, Vlachogiannakos J, Georgiadis D, Keyoglou A, Vasianopoulou P, Markoutsaki Th, et al. Azathioprine use in patients with inflammatory bowel disease. Adherence to treatment and adverse events. A single center experience. Ann. Gastroenterol. 2009;22(3):173-177. Other observational study without a comparison group; does not report side effects by medication class.
Vihinen MK, Kolho KL, Janne OA, Andersson S, Raivio T. Circulating adiponectin as a marker for glucocorticoid-related side effects in children and adolescents with inflammatory bowel disease. J Pediatr Gastroenterol Nutr. 2009;48(4):504-6. Does not apply to key questions; does not report side effects by medication class. [pmid: 19322063].
Vihinen MK, Raivio T, Verkasalo M, Janne OA, Kolho KL. Circulating glucocorticoid bioactivity during peroral glucocorticoid treatment in children and adolescents with inflammatory bowel disease. J Clin Gastroenterol. 2008;42(9):1017-24. Does not evaluate a drug of interest; does not apply to key questions. [pmid: 18496232].
Vinklerova I, Prochazka M, Prochazka V, Urbanek K. Incidence, Severity, and Etiology of Drug-Induced Acute Pancreatitis. Dig Dis Sci. 2010. Does not apply to key questions.
Viola F, Civitelli F, Di Nardo G, Barbato MB, Borrelli O, Oliva S, et al. Efficacy of adalimumab in moderate-to-severe pediatric Crohn's disease. Am J Gastroenterol. 2009;104(10):2566-71. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19550415].
von Ahsen N, Armstrong VW, Behrens C, von Tirpitz C, Stallmach A, Herfarth H, et al. Association of inosine triphosphatase 94C>A and thiopurine S-methyltransferase deficiency with adverse events and study drop-outs under azathioprine therapy in a prospective Crohn disease study. Clin Chem. 2005;51(12):2282-8. Does not evaluate a drug of interest. [pmid: 16214825].
von Scheven E, Gordon CM, Wypij D, Wertz M, Gallagher KT, Bachrach L. Variable deficits of bone mineral despite chronic glucocorticoid therapy in pediatric patients with inflammatory diseases: a Glaser Pediatric Research Network study. J Pediatr Endocrinol Metab. 2006;19(6):821-30. Other observational study without a comparison group. [pmid: 16886590].
von Tirpitz C, Epp S, Klaus J, Mason R, Hawa G, Brinskelle-Schmal N, et al. Effect of systemic glucocorticoid therapy on bone metabolism and the osteoprotegerin system in patients with active Crohn's disease. Eur J Gastroenterol Hepatol. 2003;15(11):1165-70. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 14560148].
Vos AC, Bakkal N, Minnee RC, Casparie MK, de Jong DJ, Dijkstra G, et al. Risk of malignant lymphoma in patients with inflammatory bowel diseases: A Dutch nationwide study. Inflamm Bowel Dis. 2010. Other observational study without a comparison group; does not report side effects by medication class.
Wahed M, Louis-Auguste JR, Baxter LM, Limdi JK, McCartney SA, Lindsay JO, et al. Efficacy of methotrexate in Crohn's disease and ulcerative colitis patients unresponsive or intolerant to azathioprine /mercaptopurine. Aliment Pharmacol Ther. 2009;30(6):614-20. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19552632].
Wallensten S, Persson S. Azathioprine therapy for Crohn's disease. Acta Chir Scand. 72;138(5):521-6. Case report or case series. [pmid: 5055985].
Warman JI, Korelitz BI, Fleisher MR, Janardhanam R. Cumulative experience with short- and long-term toxicity to 6-mercaptopurine in the treatment of Crohn's disease and ulcerative colitis. J Clin Gastroenterol. 2003;37(3):220-5. Other observational study without a comparison group. [pmid: 12960720].
Waugh AW, Garg S, Matic K, Gramlich L, Wong C, Sadowski DC, et al. Maintenance of clinical benefit in Crohn's disease patients after discontinuation of infliximab: long-term follow-up of a single centre cohort. Aliment Pharmacol Ther. 2010;32(9):1129-34. Does not report side effects by medication class. [pmid: 20807218].
Weersma RK, Batstra MR, Kleibeuker JH, van Dullemen HM. Are pancreatic autoantibodies associated with azathioprine-induced pancreatitis in Crohn's disease?. JOP. 2008;9(3):283-9. Does not apply to key questions. [pmid: 18469440].
Wenckert A, Kristensen M, Eklund AE, Barany F, Jarnum S, Worning H, et al. The long-term prophylactic effect of salazosulphapyridine (Salazopyrin) in primarily resected patients with Crohn's disease. A controlled double-blind trial. Scand J Gastroenterol. 78;13(2):161-7. Other reason. [pmid: 24891].
Wenzl HH, Reinisch W, Jahnel J, Stockenhuber F, Tilg H, Kirchgatterer A, et al. Austrian infliximab experience in Crohn's disease: a nationwide cooperative study with long-term follow-up. Eur J Gastroenterol Hepatol. 2004;16(8):767-73. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 15256978].
Werlin SL, Grand RJ. Bloody diarrhea--a new complication of sulfasalazine. J Pediatr. 78;92(3):450-1. Case report or case series. [pmid: 24681].
West RL, Zelinkova Z, Wolbink GJ, Kuipers EJ, Stokkers PC, van der Woude CJ. Immunogenicity negatively influences the outcome of adalimumab treatment in Crohn's disease. Aliment Pharmacol Ther. 2008;28(9):1122-6. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18691349].
Wewer V, Riis L, Vind I, Husby S, Munkholm P, Paerregaard A. Infliximab dependency in a national cohort of children with Crohn's disease. J Pediatr Gastroenterol Nutr. 2006;42(1):40-5. Does not apply to key questions; does not report side effects by medication class. [pmid: 16385252].
Wiese D, Lashner B, Seidner D. Measurement of nutrition status in Crohn's disease patients receiving infliximab therapy. Nutr Clin Pract. 2008;23(5):551-6. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 18849561].
Williams CN. Is the incidence of cancer increased in patients with Crohn's disease or after its complications or treatment?. Can J Gastroenterol. 97;11(5):397-8. No original data. [pmid: 9286471].
Williams CN, Haber G, Aquino JA. Double-blind, placebo-controlled evaluation of 5-ASA suppositories in active distal proctitis and measurement of extent of spread using 99mTc-labeled 5-ASA suppositories. Dig Dis Sci. 87;32(12 Suppl):71S-75S. RCT patient population not exclusively Crohn's or observational study not exclusively IBD. [pmid: 3319461].
Willot S, Noble A, Deslandres C. Methotrexate in the treatment of inflammatory bowel disease: An 8-year retrospective study in a Canadian pediatric IBD center. Inflamm Bowel Dis. 2011. Other observational study without a comparison group.
Willoughby JM, Kumar P, Beckett J, Dawson AM. A double-blind trial of azathioprine in Crohn's disease. Gut. 71;12(10):864. Other observational study without a comparison group; other reason. [pmid: 4941688].
Winship DH, Summers RW, Singleton JW, Best WR, Becktel JM, Lenk LF, et al. National Cooperative Crohn's Disease Study: study design and conduct of the study. Gastroenterology. 79;77(4 Pt 2):829-42. Other reason. [pmid: 38175].
Winter H. Initial maintenance therapy (relapse prevention) and therapy of steroid resistance and dependence. Inflamm Bowel Dis. 98;4(3):209-13. No original data. [pmid: 9741023].
Winter JW, Gaffney D, Shapiro D, Spooner RJ, Marinaki AM, Sanderson JD, et al. Assessment of thiopurine methyltransferase enzyme activity is superior to genotype in predicting myelosuppression following azathioprine therapy in patients with inflammatory bowel disease. Aliment Pharmacol Ther. 2007;25(9):1069-77. Does not apply to key questions; other observational study without a comparison group. [pmid: 17439508].
Witthoft T, Ludwig D. Effectiveness and tolerability of repeated treatment with infliximab in patients with Crohn's disease: a retrospective data analysis in Germany. Int J Colorectal Dis. 2005;20(1):18-23. Does not report side effects by medication class. [pmid: 15459773].
Wong DR, De Boer NKH, Jharap B, De Graaf P, Van Bodegraven AA, Mulder CJJ, et al. Influence of mesalazine on thiopurine metabolism in inflammatory bowel disease patients. Prospective multicenter pharmacokinetic study. Pharm. Weekbl. 2008;143(12):62-65. Not written in English.
Wong JM, Wei SC. Efficacy of Pentasa tablets for the treatment of inflammatory bowel disease. J Formos Med Assoc. 2003;102(9):613-9. Does not evaluate a drug of interest. [pmid: 14625605].
Wusk B, Kullak-Ublick GA, Rammert C, von Eckardstein A, Fried M, Rentsch KM. Therapeutic drug monitoring of thiopurine drugs in patients with inflammatory bowel disease or autoimmune hepatitis. Eur J Gastroenterol Hepatol. 2004;16(12):1407-13. Does not apply to key questions; does not report side effects by medication class. [pmid: 15618853].
Wyneski MJ, Green A, Kay M, Wyllie R, Mahajan L. Safety and efficacy of adalimumab in pediatric patients with Crohn disease. J Pediatr Gastroenterol Nutr. 2008;47(1):19-25. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 18607264].
Yamagata S, Baba S, Hosoda S. Salazopyrin in the management of Crohn's disease. GASTROENTEROL. JPN. 85;20(1):71-81. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 2862089].
Yang YX, Lichtenstein GR. Methotrexate for the maintenance of remission in Crohn's disease. Gastroenterology. 2001;120(6):1553-5. No original data. [pmid: 11313329].
Yeckes AR, Hoffenberg EJ. Rapid infliximab infusions in pediatric inflammatory bowel disease. J Pediatr Gastroenterol Nutr. 2009;49(1):151-4. Other observational study without a comparison group; does not report side effects by medication class. [pmid: 19516188].
Yu AP, Johnson S, Wang ST, Atanasov P, Tang J, Wu E, et al. Cost utility of adalimumab versus infliximab maintenance therapies in the United States for moderately to severely active Crohn's disease. Pharmacoeconomics. 2009;27(7):609-21. Does not apply to key questions. [pmid: 19663531].
Zabana Y, Domenech E, Manosa M, Garcia-Planella E, Bernal I, Cabre E, et al. Infliximab safety profile and long-term applicability in inflammatory bowel disease: 9-year experience in clinical practice. Aliment Pharmacol Ther. 2010;31(5):553-60. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 20002026].
Zali M, Bahari A, Firouzi F, Daryani NE, Aghazadeh R, Emam MM, et al. Bone mineral density in Iranian patients with inflammatory bowel disease. Int J Colorectal Dis. 2006;21(8):758-66. Does not apply to key questions. [pmid: 16463035].
Zboril V, Prokopova L, Abbe ML. Anti-TNF Alfa in Combination with Immunosuppresive Agents in the Management of Aggressive Perforating Type of Crohn's Disease. Ceska Slov. Gastroenterol. Hepatol. 2003;57(4):140-145. Not written in English.
Zheng JJ, Chu XQ, Shi XH, Zhou CL, Seng BW. Efficacy and safety of azathioprine maintenance therapy in a group of Crohn's disease patients in China. J Dig Dis. 2008;9(2):84-8. Does not evaluate a drug of interest; does not report side effects by medication class. [pmid: 18419641].
Zheng JJ, Zhi P, Wang YM, Zhu F, Gu W, Xing YC, et al. Short-term study of infliximab treatment for Crohn's disease in China. J. Dig. Dis. 2011;12(2):105-109. Does not evaluate a drug of interest. [pmid: 21401895].
Adalimumab: Hepatosplenic T-cell lymphoma. WHO Drug Inf. 2008;22(3):198. No original data.
Azathioprine in Crohn's disease. Drug Ther Bull. 73;11(18):71-2. No original data. [pmid: 4770778].
Betamethasone 17-valerate and prednisolone 21-phosphate retention enemata in proctocolitis. A multicentre trial. Br Med J. 71;3(5766):84-6. Does not evaluate a drug of interest.
Certolizumab (Cimzia) for Crohn's disease. Med Lett Drugs Ther. 2008;50(1297):81-2. No original data. [pmid: 18927521].
Coated oral 5-aminosalicylic acid versus placebo in maintaining remission of inactive Crohn's disease. International Mesalazine Study Group. Aliment Pharmacol Ther. 90;4(1):55-64. Other reason. [pmid: 2104074].
Evaluating the safety and efficacy of biologic agents in Crohn's disease. Gastroenterol. Hepatol. 2007;3(8 SUPPL. 23):5-12. No original data.
Heart failure on infliximab. Prescrire Int. 2002;11(59):86-7. No original data.
Infliximab (Remicade) for Crohn's disease. Med Lett Drugs Ther. 99;41(1047):19-20. No original data. [pmid: 10076592].
Infliximab provides short-term relief in Crohn's disease. Drugs Ther. Perspect. 99;13(8):1-5. No original data.
Quality of life and chronic inflammatory bowel diseases. Chronisch entzundliche darmerkrankungen: Im visier die lebensqualitat. Coloproctology. 2000;22(6):246-247. Not written in English.
Salazopyrin in the management of Crohn's disease. The Japanese Research Committee for Crohn's disease. Gastroenterol Jpn. 85;20(1):71-81. Does not evaluate a drug of interest; other observational study without a comparison group. [pmid: 2862089].