# Forms

Title review

Appendix B shows the forms from the online database and extraction software called Distiller SR by Evidence Partners. The first form is a sample of the title review form. The title is displayed with the author and the reviewer can select yes or no to the question “Does this article potentially apply to any of our key questions.”

Abstract review

The next form is the abstract review form from the online database and extraction software called Distiller SR by Evidence Partners. The title and author and abstract are displayed, along with the choices for the reviewer to exclude for various reason from our exclusion criteria, mark as unclear to pull for review, include for review, or pull for handsearch. There is also a box for comments.

Article review

The next form is the full article review form from the online database and extraction software called Distiller SR by Evidence Partners. The title and author and abstract are displayed, along with a link to the PDF version of the full article. There are then checkboxes with the choices for the reviewer to exclude for various reason from our exclusion criteria, mark as unclear to pull for review, include for review, or pull for handsearch. There is also a box for comments.

Study design form

The next form is the study design data abstraction form. There are questions, checkboxes, and fill in areas to input the data pertaining to the design of the study described in the article, and three comment boxes.

Intervention/population characteristics form

The next form is the intervention and population characteristics abstraction form. There are questions, checkboxes, and fill in areas to input the data pertaining the study's population and the interventions in each study arm described in the article, and three comment boxes.

Case control population form

The next form is the case control data abstraction population form for the case-control studies. There is one group per form and there are various checkboxes, fill ins, and comments boxes to describe the population of a group in a case-control study.

Outcomes form

The next form is the outcomes form for RCT and cohort studies. Reviewers are instructed to submit one form per relevant outcome. The type of outcome and how it is measured is abstracted into tables that indicate outcome definition, timing, and how it was reported.

Case control outcomes form

The case control outcomes form is where reviewers abstract the data from case-control studies for the outcomes. They complete one form per outcome described, indicating the outcome data on the form through checkboxes, fill-ins, and comment boxes.

Quality form for RCTs

The quality form for RCTs records the answers to various questions that pertain to the trial quality and validity.

Quality form for observational studies

The quality form for observational studies records the answers to various questions in yes, no, unable to determine answers that pertain to the study quality and validity.