# Detailed Electronic Database Search Strategies

## PubMed Strategy

Terms | Returns
(“Crohn Disease”[mh] OR “Crohn's Disease”[tiab] OR “Crohn Disease”[tiab] OR “Crohns Disease”[tiab] OR (Crohn*[tiab] AND (ileitis[tiab] OR enteritis[tiab] OR ileocolitis[tiab] OR colitis[tiab])) OR “inflammatory bowel diseases”[mh] OR “inflammatory bowel disease”[tiab] OR “inflammatory bowel diseases”[tiab] OR IBD[tiab]) AND (“Aminosalicylic acids”[mh] OR “Anti-inflammatory agents, non-steroidal”[mh] OR mesalamine[mh] OR sulfasalazine[mh] OR “5-aminosalicylic acid”[tiab] OR “5-aminosalicylic acids”[tiab] OR “5-aminosalicylate”[tiab] OR “5-aminosalicylates”[tiab] OR “5-ASA”[tiab] OR aminosalicyl*[tiab] OR mesalamine*[tiab] OR mesalazine*[tiab] OR sulfasalazine*[tiab] OR sulphasalazine*[tiab] OR balsalazide[tiab] OR olsalazine[tiab] OR “immunosuppressive agents”[mh] OR azathioprine[mh] OR methotrexate[mh] OR “6-mercaptopurine”[mh] OR immunosuppression[tiab] OR immunosuppressive[tiab] OR immunosuppressives[tiab] OR immunomodulator*[tiab] OR immunomodulating[tiab] OR “anti-metabolite”[tiab] OR “anti-metabolites”[tiab] OR antimetabolit*[tiab] OR azathioprine[tiab] OR methotrexate[tiab] OR “6-mercaptopurine”[tiab] OR “antibodies, monoclonal/therapeutic use”[mh] OR “antibodies, monoclonal/administration and dosage”[mh] OR “antibodies, monoclonal/adverse effects”[mh] OR “anti-inflammatory agents”[mh] OR ((“tumour necrosis factor”[tiab] OR “tumour necrosis factor-alpha”[tiab] OR “tumor necrosis factor”[tiab] OR “tumor necrosis factor-alpha”[tiab] OR TNF[tiab] OR TNF-alpha[tiab]) AND (antibod*[tiab] OR antagonist[tiab] OR antagonists[tiab] OR inhibitor*[tiab]) AND (agent*[tiab] OR treatment*[tiab] OR treated[tiab] OR therap*[tiab] OR drug[tiab] OR drugs[tiab] OR medication*[tiab])) OR “anti-tumour necrosis”[tiab] OR “anti-tumor necrosis”[tiab] OR anti-TNF*[tiab] OR biologic[tiab] OR biologics[tiab] OR adalimumab[tiab] OR infliximab[tiab] OR certolizumab[tiab] OR natalizumab[tiab] OR ustekinumab[tiab] OR budesonide[mh] OR glucocorticoids[mh] OR hydrocortisone[mh] OR methylprednisolone[mh] OR prednisolone[mh] OR prednisone[mh] OR “6-methylprednisolone”[tiab] OR budesonide[tiab] OR corticosteroid*[tiab] OR glucocorticosteroid*[tiab] OR prednisolone[tiab] OR prednisone[tiab]) NOT (animal[mh] NOT human [mh]) NOT (comment[pt] or editorial[pt]) | 11717

## EMBASE Strategy

‘crohn disease’/exp OR ‘crohn disease’ OR (crohn* NEXT/2 (disease OR ileitis OR enteritis OR ileocolitis OR colitis)):ab,ti OR ‘inflammatory bowel disease’:ab,ti OR ‘inflammatory bowel diseases’:ab,ti OR ibd:ab,ti AND (‘mesalazine’/exp OR ‘mesalazine’ OR ‘salazosulfapyridine’/exp OR ‘salazosulfapyridine’ OR ‘5-aminosalicylic acid’:ab,ti OR ‘5-aminosalicylic acids’:ab,ti OR ‘5-aminosalicylate’:ab,ti OR ‘5-aminosalicylates’:ab,ti OR ‘5-asa’:ab,ti OR aminosalicyl*:ab,ti OR mesalamine*:ab,ti OR mesalazine*:ab,ti OR salazosulfapyridine*:ab,ti OR sulfasalazine*:ab,ti OR sulphasalazine*:ab,ti OR balsalazide:ab,ti OR olsalazine:ab,ti OR ‘azathioprine’/exp OR ‘azathioprine’ OR ‘methotrexate’/exp OR ‘methotrexate’ OR ‘mercaptopurine’/exp OR ‘mercaptopurine’ OR immunosuppression:ab,ti OR immunosuppressive:ab,ti OR immunosuppressives:ab,ti OR immunomodulator*:ab,ti OR immunomodulating:ab,ti OR ‘anti-metabolite’:ab,ti OR ‘anti-metabolites’:ab,ti OR antimetabolit*:ab,ti OR azathioprine:ab,ti OR methotrexate:ab,ti OR ‘6-mercaptopurine’:ab,ti OR ‘adalimumab’/exp OR ‘adalimumab’ OR ‘infliximab’/exp OR ‘infliximab’ OR ‘certolizumab pegol’/exp OR ‘certolizumab pegol’ OR ‘natalizumab’/exp OR ‘natalizumab’ OR ‘ustekinumab’/exp OR ‘ustekinumab’ OR (((‘tumour necrosis factor’ OR ‘tumor necrosis factor’ OR tnf) NEXT/2 (antibod* OR antagonist OR antagonists OR inhibitor*)):ab,ti AND (agent*:ab,ti OR treatment*:ab,ti OR treated:ab,ti OR therap*:ab,ti OR drug:ab,ti OR drugs:ab,ti OR medication*:ab,ti)) OR ‘anti-tumour necrosis’:ab,ti OR ‘anti-tumor necrosis’:ab,ti OR ‘anti tnf’:ab,ti OR ‘anti tnfalpha’:ab,ti OR ‘anti tnf alpha’:ab,ti OR biologic:ab,ti OR biologics:ab,ti OR adalimumab:ab,ti OR infliximab:ab,ti OR certolizumab:ab,ti OR natalizumab:ab,ti OR ustekinumab:ab,ti OR ‘budesonide’/exp OR ‘budesonide’ OR ‘methylprednisolone’/exp OR ‘methylprednisolone’ OR ‘prednisolone’/exp OR ‘prednisolone’ OR ‘prednisone’/exp OR ‘prednisone’ OR ‘6-methylprednisolone’:ab,ti OR budesonide:ab,ti OR corticosteroid*:ab,ti OR glucocorticosteroid*:ab,ti OR prednisolone:ab,ti OR prednisone:ab,ti) NOT ([animals]/lim NOT [humans]/lim) NOT (letter:it OR comment:it OR editorial:it) AND (‘article’/it OR ‘review’/it OR ‘article in press’/it) | 12653

## The Cochrane Central Register of Controlled Trials (CENTRAL)

((crohn* NEAR/2 (disease OR ileitis OR enteritis OR ileocolitis OR colitis)):ti,ab,kw OR “inflammatory bowel disease”:ti,ab,kw OR “inflammatory bowel diseases”:ti,ab,kw OR ibd:ti,ab,kw) AND (“5-aminosalicylic acid”:ti,ab,kw OR “5-aminosalicylic acids”:ti,ab,kw OR “5-aminosalicylate”:ti,ab,kw OR “5-aminosalicylates”:ti,ab,kw OR “5-asa”:ti,ab,kw OR aminosalicyl*:ti,ab,kw OR mesalamine*:ti,ab,kw OR mesalazine*:ti,ab,kw OR salazosulfapyridine*:ti,ab,kw OR sulfasalazine*:ti,ab,kw OR sulphasalazine*:ti,ab,kw OR balsalazide:ti,ab,kw OR olsalazine:ti,ab,kw OR immunosuppression:ti,ab,kw OR immunosuppressive:ti,ab,kw OR immunosuppressives:ti,ab,kw OR immunomodulator*:ti,ab,kw OR immunomodulating:ti,ab,kw OR “anti-metabolite”:ti,ab,kw OR “anti-metabolites”:ti,ab,kw OR antimetabolit*:ti,ab,kw OR azathioprine:ti,ab,kw OR methotrexate:ti,ab,kw OR “6-mercaptopurine”:ti,ab,kw OR (((“tumour necrosis factor” OR “tumor necrosis factor” OR tnf) NEAR/2 (antibod* OR antagonist OR antagonists OR inhibitor*)):ti,ab,kw AND (agent*:ti,ab,kw OR treatment*:ti,ab,kw OR treated:ti,ab,kw OR therap*:ti,ab,kw OR drug:ti,ab,kw OR drugs:ti,ab,kw OR medication*:ti,ab,kw)) OR “anti-tumour necrosis”:ti,ab,kw OR “anti-tumor necrosis”:ti,ab,kw OR “anti tnf”:ti,ab,kw OR “anti tnfalpha”:ti,ab,kw OR “anti tnf alpha”:ti,ab,kw OR biologic:ti,ab,kw OR biologics:ti,ab,kw OR adalimumab:ti,ab,kw OR infliximab:ti,ab,kw OR certolizumab:ti,ab,kw OR natalizumab:ti,ab,kw OR ustekinumab:ti,ab,kw OR “6-methylprednisolone”:ti,ab,kw OR budesonide:ti,ab,kw OR corticosteroid*:ti,ab,kw OR glucocorticosteroid*:ti,ab,kw OR prednisolone:ti,ab,kw OR prednisone:ti,ab,kw) | 577