# Results

The literature search yielded 4,581 citations (Appendix A). From these, 220 articles were provisionally accepted for review based on abstracts and titles (Figure 2). After screening the full text, 57 studies (in 58 articles) were found to have met the inclusion criteria. Fourteen of the 57 studies were comparative,25-39 and the remainder were single-group studies.4,5,40-81 The Summary Tables, with the descriptions and results of each study, are in Appendix C.

Figure 2 Literature flow

* The “process” outcomes included procedure or anesthesia delay, procedure cancellation, and other resource utilization, including unplanned followup tests or procedures and changes to perioperative patient management.

† Thallium scintigraphy, heart rate variability, Holter monitor, iron status.

‡ Analyses of combined tests and history and physical examination, analysis of only abnormal test results, analysis of test results as predictor of associations with outcomes, case report, could not retrieve article, diagnostic test, emergency surgery or trauma, mix of elective and emergency surgery, no results specific to preoperative tests, not an evaluation of routine preoperative tests, trial of preoperative interventions, referral to preoperative clinic, survey of anesthesiologists, test performed to diagnose or evaluate severity or stage of illness, too unclear a link between test results and subsequent management.

This figure is a flow chart that summarizes the study retrieval and selection process of articles relevant to the two key questions. The figure displays the same information as enumerated in the first paragraph of the Results section. In addition, the figure includes the following information: Of the 160 excluded full-text articles, 41 had only ad hoc testing, 26 were not published in English, 25 were noncomparative studies with no process outcome (the “process” outcomes included procedure or anesthesia delay, procedure cancellation, and other resource utilization including unplanned followup tests or procedures and changes to perioperative patient management), 21 were not primary studies, 12 did not evaluate an anesthesia-involved procedure, 13 did not include a preoperative test of interest (they included thallium scintigraphy, heart rate variability, Holter monitor, iron status), 9 had no outcome of interest, and 13 were rejected for other reasons including analyses of combined tests and history and physical examination, analysis of only abnormal test results, analyze test results as predictor of/association with outcomes, case report, could not retrieve article, diagnostic test, emergency surgery or trauma, mix of elective and emergency surgery, no results specific to preoperative tests, not evaluation of routine preoperative tests, trial of preoperative interventions, referral to preoperative clinic, survey of anesthesiologists, test performed to diagnose or evaluate severity or stage of illness, too unclear a linkage between test results and subsequent management.

The remaining 160 retrieved articles were rejected for not meeting the eligibility criteria (see Appendix B for the list of rejected articles and the reasons for their rejection). The most common reasons for article rejection were that the article only analyzed test results as predictor of association with outcomes, the test evaluated in the article was not performed on all patients (only ad hoc testing done where testing was done at the clinician's discretion), the article was non-comparative and did not include a process outcome (e.g., surgical delay/cancellation, followup testing), the article was not a primary study, the article dealt with a surgery or procedure that did not involve anesthesia, the test reported was not a test of interest, the diagnostic test study design was not appropriate, the test was performed to diagnose or evaluate severity/stage of illness, or the article could not be retrieved.

The study designs and baseline characteristics of the 57 studies are shown in Appendix C, Table C1-3. They include six RCTs; one prospective, six retrospective, and one combined prospective and retrospective nonrandomized studies; 22 prospective and 21 retrospective cohort (noncomparative, single group) studies. Three RCTs were focused on cataract surgery, two RCTs and six nonrandomized studies focused on general or various surgeries, one RCT focused on vascular surgery, and one nonrandomized comparative study each focused on tonsillectomy and orthopedics. Overall, the studies evaluated the preoperative tests for the following procedures: general or various surgeries (37 studies), tonsillectomy (5 studies), cataract surgery (4 studies), orthopedic surgery (4 studies), vascular surgery (3 studies), head and neck/ear, nose, throat (ENT) surgery (2 studies), and one study each for neurosurgery and electroconvulsive therapy (ECT). Seventeen of the studies were conducted in children, 25 in adults, and 15 in a mixed population of adults and children.

The studies were conducted in the U.S. (30), England (5), Thailand (4), France (4), Canada (4), Italy (3), Brazil (1), Spain (1), India (1), Kuwait (1), Belgium (1), the Ivory Coast (1), and Saudi-Arabia (1). Forty studies were published before 2000, including seven of the 14 comparative studies; 17 studies were published after 2000. Thirteen studies had a high risk of bias, 10 had a medium risk of bias, and 34 had a low risk of bias.

The preoperative tests evaluated in the studies fall into the following categories: basic metabolic panel (electrolytes, kidney function, glucose), extended metabolic panel (liver function tests [LFT] and other serum tests), blood counts (including hemoglobin, hematocrit, white blood cells, and platelets), hemostasis tests (including prothrombin time [PT], partial thromboplastin time [PTT], and bleeding time), urinalysis, pregnancy tests, ECG, chest x ray (CXR), pulmonary function testing (PFT), and echocardiography. The specific tests used in the comparative studies are included in tables within each surgery-specific section of the Results; for cohort studies, see Appendix C Table C-4).

The Results section is structured as follows: the first major section presents the comparative studies (both RCTs and nonrandomized studies), followed by a summary of the cohort studies. Within the comparative study section, the results are divided by category of surgery, within which each Key Question and subquestion is addressed. Within the cohort study section, the results are again divided by category of surgery (or procedure).

## Comparative Studies

Six RCTs (in seven publications)26,29-31,33,36,37 and one prospective,27 six retrospective,25,28,32,34,35,38 and one combined prospective and retrospective nonrandomized study39 compared alternative strategies regarding the use of routine or per protocol preoperative testing. Three RCTs were focused on cataract surgery, two RCTs and six nonrandomized studies were conducted in adults or children (two studies) undergoing a variety of minor or elective or routine surgeries, one RCT was conducted in adults undergoing vascular surgery, one nonrandomized study was conducted in adults undergoing orthopedic surgery, and one nonrandomized study was conducted in children undergoing tonsillectomy and/or adenoidectomy.

The comparative studies were conducted in the U.S. (six studies), Canada (3 studies), Italy (2 studies), Brazil (1 study), the Ivory Coast (one study), and England (one study). Among the RCTs, four were deemed to have a low risk of bias and two a medium risk of bias (Appendix D Table D-1). Among the nonrandomized studies, all were deemed to have high risk of bias (Appendix D Table D-2).

### Cataract Surgery

Three RCTs (in four articles) randomized adults undergoing cataract surgery (Appendix C Tables C-1 and C-2 and Tables 3 and 4).26,30,31,33 Two of the trials (from the United States and Brazil) had similar eligibility criteria, excluding patients under 40 or 50 years of age, those receiving general anesthesia, or those who had had a recent myocardial infarction. The third (Italian) trial also included only patients undergoing local anesthesia but excluded those undergoing anticoagulant or insulin therapy. All compared routine preoperative testing in all patients with no required testing (ad hoc testing generally allowed if warranted). All have been published since 2000. The Brazilian and Italian studies were deemed to have a low risk of bias. The U.S. study was deemed to have a medium risk of bias, primarily because it was a multicenter study, which was not accounted for in the analyses.

Table 3 Comparative study: Tests by study arm in cataract surgery

Author Year PMID | Arm | ECG | CXR | Basic Metabolic | Extended Metabolic | CBC | Hemostasis Tests | Urinalysis | Pregnancy Test | Stress Test | Echo | Other
Cavallini 2004 15506597 | Routine | Yes | | | | | | | | | | “Routine medical tests”
| No testing
Lira 2001 11558245 | Routine | Yes | | Glucose | | Yes
| No testing^*^
Schein 2000 10639542 | Routine | Yes | | Electrolytes, BUN, creatinine, glucose | | Yes | | Yes
| No testing

BUN = blood urea nitrogen; CBC = complete blood count; CXR = chest x ray; ECG= electrocardiogram; Echo = echocardiogram.

* Some undefined testing was allowed if “the patient presented with anew or worsening medical problem that would warrant medical evaluation with testing, even if surgery were not planned.”

Table 4 Routine or per protocol versus ad hoc preoperative testing: Strength of evidence domains for cataract surgery

Outcome | Surgery | Tests | Study Design: No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Strength of Evidence
Perioperative complications, total | Cataract surgery | ECG, metabolic panel, CBC | RCT: 3 (21,531) | Medium | Direct | Consistent | Precise | Undetected | None | High
Procedure cancellation | Cataract surgery | ECG, metabolic panel, CBC | RCT: 2 (20,562) | Low | Direct | Consistent | Precise | Undetected | None | High

CBC = complete blood count; CI = confidence interval; ECG = electrocardiogram; N/A = not applicable (when strength of evidence is insufficient based on the other four domains); NRS = nonrandomized comparative study; RCT=randomized controlled trial.

In all three trials, routine testing included an ECG (Table 3). One trial described the remaining tests only as “routine medical tests.”26 The other two trials included a complete blood count. One included glucose, and one included a full basic metabolic panel.

All trials found no significant differences in perioperative complication rates (Appendix C Table C-5). The RRs of various specific perioperative complications ranged from 0.70 to 2.0 (P=0.30-1.00) and all 95% CI spreads were broader than 0.77 (lower CI) to more than 1.34 (upper CI). Only the Schein et al. trial found evidence of no clinically important difference (based on an MID of 0.8-1.2) for total intraoperative and postoperative (up to 1 week) complications; there were 301 complications in each arm, resulting in RR = 1.00 (95% CI 0.85, 1.17). The trials each lumped or split complications differently, but generally reported on intraoperative and postoperative ophthalmic complications and systemic complications including acute anxiety, cardiovascular events, respiratory events, and metabolic events (see Appendix C Table C-5). By meta-analysis (Figure 3), the studies were consistent (homogeneous), and the summary RR = 0.99 (95% CI 0.86, 1.14) indicated overall evidence of no clinically important difference in perioperative complication rates between routine and ad hoc testing. The much larger Schein et al. trial (with 19,000 patients) provided 80 percent of the weight to the meta-analysis, but the smaller studies were fully consistent in their findings with the large trial.

Figure 3 Perioperative total complications in cataract surgery: Routine versus ad hoc testing

CBC = complete blood count; ECG = electrocardiogram; n/N = number with outcome/number analyzed; P_het_ = P value of statistical heterogeneity; RR = relative risk.

* Total complications not reported; assumes that all reported complications were independent of each other.

This forest plot displays the relative risk of total perioperative complications for patients undergoing cataract surgery based on whether they had routine versus ad hoc testing. Three trials reported data. They are homogeneous with relative risks for complications near 1.0 and/or wide confidence intervals. Two trials had low risk of bias and one had medium risk of bias. One trial of 1005 patients evaluated ECG, glucose, and CBC. One trial of 19,250 patients evaluated ECG, a basic metabolic panel, and urinalysis. One trial of 1276 patients evaluated ECG and routine medical tests. The summary relative risk is 0.99 with a 95 percent confidence interval of 0.86 to 1.14). The I-squared statistic is 0 percent and the P value for heterogeneity is 0.82.

Two of the cataract trials also reported on rates of procedure cancellation. 30,33 The studies had RRs of 1.00 (95% CI 0.42, 2.38) and 0.97 (95% CI 0.78, 1.21), with wide confidence intervals, suggesting no difference in cancellation rates. (Appendix C Table C-6).

No trial reported on quality of life or satisfaction, surgical delay, change in anesthesia or procedure plan, or resource utilization. No trial addressed Key Question 2 regarding harms of routine preoperative testing.

#### Subgroup Analyses

The studies consistently found no evidence of a difference in outcomes between those who did or did not have routine preoperative tests. Therefore, no differences in outcomes could be discerned among the specific type of anesthesia planned (all excluded general anesthesia), comorbidities, other patient characteristics (in general, all were over 40 or 50 years old), or who ordered the tests (this was generally not reported). These trials compared routine (everyone tested) versus no or ad hoc testing, so there is no evidence specifically regarding per protocol testing. The trials did not provide evidence regarding possible differences in outcomes based on the length of time prior to the procedure that the tests were conducted.

#### Summary: Cataract Surgery

Three RCTs—two with low, one with moderate risk of bias—compared routine versus no (or ad hoc) preoperative testing with ECG, basic metabolic panel, and CBC for patients undergoing cataract surgery. The studies were clinically similar to each other and consistent; there is a high strength of evidence of no clinically important difference in complication rates. By meta-analysis, for total complications, the RR = 0.99 (95% CI 0.86, 1.14). There is also a high strength of evidence suggesting that routine testing does not affect rates of procedure cancellation, but the confidence intervals were too wide to definitely exclude clinically important (i.e., more than 20 percent) difference. No other outcomes were reported. The evidence is inadequate to evaluate potential differences based on subgroups of patients. Overall, there is no evidence of different outcomes related to routine preoperative testing (Table 4).

### General or Various Surgeries, Adults

One RCT 36 and four nonrandomized studies (one prospective 27 and three retrospective25,28,34) compared routine or per protocol testing with ad hoc or no testing in adults undergoing a variety of elective surgeries. A sixth nonrandomized study (combined prospective and retrospective) compared routine and per protocol testing 39 (Appendix C Tables C-1, C-2, C-7, Tables 5–7). These studies included general, orthopedic, urologic, neurologic, and other surgeries;27,36 elective noncardiac surgeries;25,39 cataract surgery, transurethral resection of the prostate, laparoscopic cholecystectomy, hip arthroplasty, abdominal hysterectomy, breast reduction, radical neck dissection, any cardiovascular surgery, and any thoracic surgery surgeries;28 and “ambulatory” surgery.34 The studies generally included all patients who underwent the indicated surgeries, except that the prospective study excluded patients undergoing dialysis.27 As described in the following paragraphs, each study evaluated a different panel of tests. Two of the retrospective nonrandomized studies were published in 1989 and 1994, the combined prospective and retrospective study was published in 1996; the other studies were published in 2005 and 2009. The nonrandomized studies all have a high risk of bias, primarily because their analyses did not adjust for baseline characteristics or other differences among the compared groups in these three studies, including patient characteristics, surgeries performed, surgeons and anesthesiologists, their experience, or other confounders. Particularly for the three retrospective studies that all compared outcomes for time periods at their hospitals before and after a change in testing policy, the lack of adjustment for covariables and confounders is a substantial analytic flaw that calls into question the validity of their findings. The RCT was rated as having a low risk of bias.

Table 5 Comparative study: Tests by study arm in general/various surgeries in adults

Author Year PMID | Arm | ECG | CXR | Basic Metabolic | Extended Metabolic | CBC | Hemostasis Tests | Urinalysis | Pregnancy Test | Stress Test | Echo | Other
Almanaseer 2005 15528897 | Per protocol | ACC/AHA Class I^*^ | | | | | | | | ACC/AHA Class I * | ACC/AHA Class I^*^ | 2002 ACC/AHA cardiac workup, Coronary angiography: ACC/AHA Class I^*^
Almanaseer 2005 15528897 | Ad hoc | Yes | | | | | | | | | ACC/AHA Class I^*^
Chung 2009 19151274 | Per protocol | >45 yo, cardiac history or HTN | Pulmonary disease or “heavy” smoker | Electrolytes, creatinine if taking diuretics, renal disease, or DM; Glucose if diabetes | | >60 yo or suspected anemia | PT, PTT If on anticoagulant, coagulopathy, or chronic liver disease | | | | | Sickle cell if African or Caribbean origin
Chung 2009 19151274 | No testing | | | Glucose of diabetes (on day of surgery)
Finegan 2005 15983141 | Routine | Yes | Yes | Electrolytes, creatinine, BUN, glucose | ALP, bilirubin | Yes | PT-INR, PTT | Yes
Finegan 2005 15983141 | Ad hoc | Yes | Yes | Electrolytes, creatinine, BUN, glucose | ALP, bilirubin | Yes | PT-INR, PTT | Yes
Larocque 1994 7922901 | Per protocol | 77% of patients^†^ | 45% of patients^†^ | Electrolytes (76% of patients), Glucose (65% of patients)^†^ | LFTs (6% of patients) | Yes | INR, PTT (23% of patients)^†^ | 93% of patients
Larocque 1994 7922901 | Ad hoc | 75% of patients | 57% of patients | Electrolytes (97% of patients), Glucose (95% of patients) | LFTs (11% of patients) | Yes | INR, PTT (26% of patients) | 97% of patients
Mignonsi, 1996 8762245 | Routine | 67% of patients | 71% of patients | Glucose (92% of patients), Creatinine (45% of patients), Urea (90% of patients) | | 95% of patients | PT (50% of patients); PTT (35% of patients) | 58% of patients | | | | Hb electrophoresis (12% of patients)
Mignonsi, 1996 8762245 | Per protocol | 47% of patients | 37% of patients | Glucose (38% of patients), Creatinine (15% of patients), Urea (9% of patients) | | 59% of patients | PT (100% of patients); PTT (0% of patients) | 0.5% of patients | | | | Hb electrophoresis (27% of patients)
Wyatt 1989 2729769 | Per protocol | ≥40 yo | ≥50 yo | Na, K, glucose, BUN, creatinine, CO_2_, Cl | LFTs, Ca, P, uric acid, cholesterol | Yes | PT, PTT | Yes
Wyatt 1989 2729769 | Ad hoc | Yes | Yes | Na, K, glucose, BUN, creatinine, CO_2_, Cl | LFTs, Ca, P, uric acid, cholesterol | Yes | PT, PTT | | | | | EtOH, Cardiac enzymes

ALP = alkaline phosphatase; BUN = blood urea nitrogen; Ca = calcium; CBC = complete blood count; Cl = chloride; CO_2_ = carbon dioxide; CXR = chest x ray; ECG = electrocardiogram; Echo = echocardiogram; EtOH = alcohol; HTN = hypertension; K = potassium; LFT = liver function tests; Na = sodium; P = phosphorus; PT-INR = prothrombin time and international normalized ratio; PTT = partial thromboplastin time; yo = years old

* American College of Cardiology/American Heart Association Class I recommendations: ECG: If recent chest pain or ischemic equivalent in clinically intermediate- or high-risk patients scheduled for an intermediate- or high-risk operative procedure; Stress test: If intermediate pretest probability of CAD, significant change in clinical CAD status; Echo: Left ventricular function, resting (if current or poorly controlled heart failure); Coronary angiography: if high risk of adverse outcome based on noninvasive tests, angina unresponsive to adequate medical therapy, unstable angina, equivocal noninvasive tests in patients at high clinical risk undergoing high-risk surgery

† ECG: ⩾40 yo, cardiovascular disease, pulmonary disease; CXR: cardiovascular disease, pulmonary disease; Electrolytes: >70 yo, diabetes mellitus, renal disease, taking corticosteroids digitalis diuretic; Glucose: diabetes mellitus, taking corticosteroids; INR, PTT: bleeding disorder, hepatobiliary disease, malignancy, vascular disease, taking anticoagulants

Table 6 Perioperative complications of general or various surgeries

Author Year PMID | Study Design Risk of Bias | Tests | Outcome | Arm | N Analyzed | Events (%) | RR (95% CI)
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline | Total complications^*^ | Per protocol testing | 314 | 21 (6.7%) | 0.56 (0.33, 0.96)
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline | Total complications^*^ | Ad hoc testing | 261 | 31 (11.9%) | 0.56 (0.33, 0.96)
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline | Death, total | Per protocol testing | 314 | 1 (0.3%) | 0.28 (0.03, 2.65)
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline | Death, total | Ad hoc testing | 261 | 3 (1.1%) | 0.28 (0.03, 2.65)
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline | Pneumonia | Per protocol testing | 314 | 2 (0.6%) | 0.21, 0.04, 0.97)
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline | Pneumonia | Ad hoc testing | 261 | 8 (3.1%) | 0.21, 0.04, 0.97)
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline | Renal failure | Per protocol testing | 314 | 4 (1.3%) | 1.11 (0.25, 4.91)
Almanaseer 2005 15528897 | rNRS High | ECG, Cardiac tests per ACC/AHA guideline | Renal failure | Ad hoc testing | 261 | 3 (1.1%) | 1.11 (0.25, 4.91)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Total complications (nonspecified) | Per protocol | 527 | 7 (1.3%) | 0.95 (0.33, 2.68)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Total complications (nonspecified) | No testing | 499 | 7 (1.4%) | 0.95 (0.33, 2.68)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Postoperative morbidity | Per protocol | 527 | 21 (4.0%) | 1.24 (0.66, 2.35)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Postoperative morbidity | No testing | 499 | 16 (3.2%) | 1.24 (0.66, 2.35)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Arrhythmia | Per protocol | 527 | 2 (0.4%) | 0.95 (0.13, 6.7)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Arrhythmia | No testing | 499 | 2 (0.4%) | 0.95 (0.13, 6.7)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | HTN | Per protocol | 527 | 2 (0.4%) | 0.95 (0.13, 6.7)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | HTN | No testing | 499 | 2 (0.4%) | 0.95 (0.13, 6.7)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Hypotension | Per protocol | 527 | 1 (0.2%) | Not calculated
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Hypotension | No testing | 499 | 0 (0%) | Not calculated
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Oxygen desaturation | Per protocol | 527 | 2 (0.4%) | Not calculated
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Oxygen desaturation | No testing | 499 | 0 (0%) | Not calculated
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Laryngospasm | Per protocol | 527 | 0 (0%) | Not calculated
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Laryngospasm | No testing | 499 | 2 (0.4%) | Not calculated
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Bronchospasm | Per protocol | 527 | 0 (0%) | Not calculated
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Bronchospasm | No testing | 499 | 1 (0.2%) | Not calculated
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Nausea | Per protocol | 527 | 3 (0.6%) | 0.71 (0.16, 3.16)
Chung 2009 19151274 | RCT Low | ECG, CXR, Basic panel, CBC, Hemostasis tests, Sickle cell | Nausea | No testing | 499 | 4 (0.8%) | 0.71 (0.16, 3.16)
Finegan 2005 15983141 | pNRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Perioperative surgical Complications | Routine testing | 507 | 4 (0.8%) | 0.43 (0.13, 1.40)
Finegan 2005 15983141 | pNRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Perioperative surgical Complications | Ad hoc testing | 431 | 8 (1.9%) | 0.43 (0.13, 1.40)
Finegan 2005 15983141 | pNRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis
Finegan 2005 15983141 | pNRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Death | Routine testing | 507 | 0 (0%) | Not calculated
Finegan 2005 15983141 | pNRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Death | [underlined: Ad hoc] testing | 431 | 4 (0.9%) | Not calculated
Finegan 2005 15983141 | pNRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis
Finegan 2005 15983141 | pNRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Renal failure | Routine testing | 507 | 0 (0%) | Not calculated
Finegan 2005 15983141 | pNRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Renal failure | Ad hoc testing | 431 | 4 (0.9%) | Not calculated
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Perioperative surgical Complications | Per protocol testing | 501 | 46 (9.2%) | 0.71 (0.49, 1.01)
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Perioperative surgical Complications | Ad hoc testing | 492 | 64 (13%) | 0.71 (0.49, 1.01)
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Morbidity attributable to test^†^ | Per protocol testing | 501 | 0 (0%) | Not calculated
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Morbidity attributable to test^†^ | Ad hoc testing | 492 | 0 (0%) | Not calculated
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Death | Per protocol testing | 501 | 0 (0%) | Not calculated
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Death | Ad hoc testing | 492 | 2 (0.4%) | Not calculated
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Death, attributable to test^†^ | Per protocol testing | 501 | 0 (0%) | Not calculated
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Death, attributable to test^†^ | Ad hoc testing | 492 | 0 (0%) | Not calculated
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Pneumonia | Per protocol testing | 501 | 0 (0%) | Not calculated
Larocque 1994 7922901 | NRS High | ECG, CXR, Basic panel, Extended panel, CBC, Hemostasis tests, Urinalysis | Pneumonia | Ad hoc testing | 492 | 7 (1.4%) | Not calculated
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis | Bleeding | Routine | 200 | 1 (1%) | Not calculated
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis | Bleeding | Per protocol | 200 | 0 (0%) | Not calculated
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis | Delayed awakening | Routine | 200 | 0 (0%) | Not calculated
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis | Delayed awakening | Per protocol | 200 | 1 (0.5%) | Not calculated
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis | Death | Routine | 200 | 0 (0%) | Not calculated
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis | Death | Per protocol | 200 | 0 (0%) | Not calculated
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis | Postoperative morbidity | Routine | 200 | 0 (0%) | Not calculated
Mignonsin, 1996 8762245 | p,rNRS High | ECG, CXR, Basic panel, CBC, Hemostasis test, Urinalysis, Hb Electrophoresis | Postoperative morbidity | Per protocol | 200 | 0 (0%) | Not calculated

ACC/AHA = American College of Cardiology/American Heart Association; CBC = complete blood count; CI = confidence interval; CXR = chest x ray; ECG = electrocardiogram; pNRS = prospective nonrandomized (comparative) study; p =rNRS = combined pro- and retrospective nonrandomized (comparative) study; rNRS = retrospective nonrandomized (comparative) study; RR = relative risk

* Assuming that each patient who had a complication had only one of the reported complications (i.e., that the complications were independent of each other).

† Attributable to preoperative laboratory investigation(s), either done or not done

Table 7 Routine or per protocol testing: Strength of evidence domains for general/various surgeries in adults

Outcome | Surgery | Tests | Study Design: No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Strength of Evidence
Routine or per protocol vs. ad hoc testing
Perioperative complications, total | Various, adults | Multiple^*^ | NRS: 5 (3932) | High | Direct | Consistent | Imprecise^†^ | Undetected | Unadjusted analyses | Insufficient
Perioperative death | Various, adults | Multiple^*^ | NRS: 4 (2906) | High | Direct | Consistent | Imprecise^†^ | Undetected | Unadjusted analyses | Insufficient
Perioperative complications, specific (selected) | Various, adults | Multiple^*^ | NRS: 3 (2506) | High | Direct | NA | Variable | N/A | Unadjusted analyses | Insufficient
Return to operating room | Various, adults | Multiple^*^ | NRS: 1 (993) | High | Direct | NA | Imprecise | N/A | Unadjusted analysis | Insufficient
Procedure cancellation | Various, adults | Multiple^*^ | NRS: 1 (5892) | High | Direct | NA | Precise | N/A | Unadjusted analysis | Insufficient
Procedure delay | Various, adults | Multiple^*^ | NRS: 1 (575) | High | Direct | NA | Imprecise | N/A | Unadjusted analysis | Insufficient
Length of stay | Various, adults | Multiple^*^ | NRS: 1 (575) | High | Direct | NA | Imprecise | N/A | Unadjusted analysis | Insufficient
Routine vs. per protocol testing
Perioperative complications, total | Various, adults | Multiple | NRS: 1 (575) | High | Direct | NA | Imprecise | N/A | Unadjusted analysis | Insufficient
Perioperative death | Various, adults | Multiple | NRS: 1 (575) | High | Direct | NA | Imprecise | N/A | Unadjusted analysis | Insufficient
Perioperative complications, specific (selected) | Various, adults | Multiple | NRS: 1 (575) | High | Direct | NA | Imprecise | N/A | Unadjusted analysis | Insufficient

CBC = complete blood count; CI = confidence interval; ECG = electrocardiogram; N/A = not applicable (when strength of evidence is insufficient based on the other four domains); NRS = nonrandomized comparative study; RCT = randomized controlled trial.

* ECG, CXR, basic and extended metabolic panels, CBC, coagulation tests, and urinalysis

† Summary RR 95% does not meet 20% threshold for MID

The RCT (Chung et al.36) compared per protocol ECG, CXR, basic metabolic panel, CBC, coagulation tests, and sickle cell testing with no testing (except for day-of-surgery glucose for people with diabetes and ad hoc testing was allowed at the discretion of the anesthesiologist) (Table 5).

The prospective nonrandomized study (Finegan et al.27) compared routine testing, using ECG, CXR, basic and extended metabolic panels, CBC, hemostasis tests, and urinalysis, with ad hoc use of the same tests at the discretion of the staff anesthesiologist or anesthesiology resident (Table 5), but did not adjust their analyses.

The three retrospective studies compared outcomes for time periods at their hospitals before and after an algorithm, hospital policy, or program defining protocols for preoperative testing was implemented. In no study was testing done routinely in all patients. The per protocol testing in Larocque et al.28 consisted of ECGs in patients at least 40 years old or with cardiovascular or pulmonary disease, CXRs in patients with cardiovascular or pulmonary disease, basic metabolic panels (or just glucose), extended metabolic panels, and hemostasis tests by indication; all patients had CBCs and urinalysis (Table 5). Importantly, testing was generally more common in the ad hoc group than in the per protocol group and rates of testing with ECG, hemostasis tests, and urinalysis were very similar between groups (Table 5). Almanaseer et al.25 evaluated the implementation of recommendations for preoperative testing based on the 2002 ACC/AHA guideline update for perioperative cardiovascular evaluation for noncardiac surgery,82 although details regarding the protocol were not reported. As part of implementing the ACC/AHA recommendations, patients had clinical evaluations but all analyses were based on the use of per protocol testing. Wyatt et al.34 evaluated a standardized preadmission screening program that included per protocol ECG in patients at least 40 years old; CXR in patients at least 50 years old; and routine basic and extended metabolic panels, CBC, prothrombin time (PT), and urinalysis in all patients.

The final study (Mignonsin et al.39) compared a retrospective period when patients routinely were tested with ECG, CXR, basic metabolic panel, CBC, hemostasis tests, urinalysis and hemoglobin electrophoresis, and a prospective period when patients were tested per a protocol based on H&P. Of note, during the “routine” period many patients did not receive the recommended tests, although usually more patients were tested than during the per protocol period. The percentages who were tested during the routine and per protocol periods were: ECG 67 and 47 percent, CXR 71 and 37 percent, glucose 92 and 38 percent, creatinine 45 and 15 percent, blood urea nitrogen 90 and 9 percent, CBC 95 and 59 percent, partial thromboplastin time 35 and 0 percent, urinalysis 58 and 0.5 percent. However, prothrombin time and hemoglobin electrophoresis were less commonly conducted during the routine period (50% and 12%) than during the per protocol period (99.5% and 27%). The patients underwent elective surgeries, including gastrointestinal, trauma/orthopedic, urologic, and gynecologic. The study may have been conducted in the Ivory Coast (the location of the surgeries was unclear).

Perioperative complications were reported in five of the studies (Table 6, Appendix C Table C-7). The RCT, Chung et al., “intraoperative events” occurred at the same rate in both patients with per protocol and no testing (1.4%; RR = 1.0; 95% CI 0.4, 3.0). Almanaseer et al. reported results only for specific perioperative complications; they did not report total complications. Using a Poisson model to allow for multiple events per person, there was a borderline nonsignificant difference favoring per protocol testing (21/314; 6.7%) over ad hoc testing (31/261; 12%) with RR = 0.56 (95% CI 0.31, 1.01).

Among the specific complications reported, only pneumonia occurred significantly more commonly among the ad hoc than the per protocol testing group. Other complications reported included myocardial infarction, heart failure, unstable angina, cardiac death, stroke, renal failure, pneumonia, respiratory failure, and noncardiac death (Appendix C Table C-7). Finegan et al. reported significantly more total perioperative complications in patients with ad hoc than per protocol testing (by Chi squared or Fisher's exact tests; ad hoc: 16 complications in 8/431 [1.9%] patients vs. per protocol: 4 complications in 4/507 [0.8%] patients; RR = 0.43 [95% CI 0.13, 1.40]). The study also found significantly more deaths and episodes of renal failure in the ad hoc cohort (4/431 [0.9%] vs. 0/507 for both death and renal failure). Other complications were not reported per study arm; overall, complications included heart failure (3 patients), myocardial infarction (2 patients), deep vein thrombosis (2 patients), stroke (1 patient), and pneumonia (1 patient). Larocque et al. also reported significantly more total complications in patients undergoing ad hoc testing (13%) than per protocol testing (9.2%) They reported a P value of <0.001 by Chi squared or Fisher's exact tests, but our calculation of the RR was nonsignificant (RR=0.73; 95% CI 0.51, 1.04). The study failed to find that any specific perioperative complication was more common with ad hoc testing only. A long list of complications were reported, including specific infectious, cardiac, respiratory surgical trauma, gastrointestinal, genitourinary, neurologic, and miscellaneous complications (Appendix C Table C-7). The study evaluated deaths and complications based on whether they may have been attributable to any preoperative tests, either done or not done. They concluded that neither of the deaths and none of the complications were attributable to any specific test.

The studies lumped many tests ordered for patients undergoing many different types of surgeries. It is reasonable to assume that there are undetected differences in effects based on which tests were used and which surgeries people underwent. Due to the clinical differences across studies in patients, surgeries, and testing protocols, we did not meta-analyze the results from these studies.

Among the specific perioperative complications, in-hospital death was reported by four of the studies (Table 6, Appendix C Table C-7). All studies reported lower perioperative death rates in the groups undergoing routine (or per protocol) testing. The same caveats about interpretation of the complications results apply to the death results. Notably, there were few deaths in all studies.

Larocque et al. also reported nonsignificantly higher rates of return to the operating room and of prolonged hospital stay (not defined) for patients who had ad hoc (both outcomes: 4/492, 0.8%) rather than per protocol testing (both outcomes: 1/501, 0.2%; RR = 0.25; 95% CI 0.03, 2.19) (Appendix C Tables C-8 & C-10). Similarly, Almanaseer et al. found that patients who underwent ad hoc testing had almost statistically significantly longer hospital lengths of stay (mean 6.5, range 1-42 days) compared to those who had testing per protocol (mean 5.6, range 1-30 days; P = 0.055) (Appendix C Table C-11).

For all reported outcomes, there was no clear difference in effect between Larocque et al.,28 published in 1994, and the more recent studies published in 2005. However, given advances in surgical management over the past 20 years, the applicability of the older studies may be limited.

Only Wyatt et al., which was published in 1989, reported on surgical cancellation. Including miscellaneous and unknown reasons for cancellation, the rates of cancellation were similar with ad hoc (127/1834, 6.9%) and per protocol testing (261/4058, 6.4%; RR = 0.93; 95% CI 0.76, 1.14) (Appendix C Table C-6). The study also reported numbers of patients who had their surgeries canceled because of specific tests; however, the study failed to report the numbers of patients who had each of the tests, hampering the ability to analyze these data. Significantly more cancellations occurred due to laboratory tests. Of note, though, is the fact that three of the four cancellations (across both study arms) due to abnormal CXRs were in patients with known pulmonary disease and all nine cancellations due to abnormal ECGs were in patients with known cardiac disease.

Almanaseer et al. found no significant difference in the proportion of patients who had their surgery deferred (delayed) before or after the testing algorithm was implemented (3.3% vs. 4.7%, respectively; RR = 1.33; 95% CI 0.61, 2.88) (Appendix C Table C-12).

No trial reported on quality of life or satisfaction, change in anesthesia or procedure plan, or resource utilization. No trial addressed Key Question 2 regarding harms of routine preoperative testing.

#### Subgroup Analyses

The studies did not report outcomes specific to any subgroups of interest and did not differ appreciably from each other based on any of the subgroup characteristics. Therefore, no differences in outcomes could be discerned among the specific type of anesthesia planned, comorbidities, other patient characteristics, who ordered the tests (this was generally not reported), or whether testing was conducted per protocol or routinely. The trials did not provide evidence regarding possible differences in outcomes based on the length of time prior to the procedure that the tests were conducted.

#### Summary: General or Various Surgeries, Adults

One low risk of bias RCT and four high risk of bias nonrandomized studies compared routine (2 studies) or per protocol testing (3 studies) with ad hoc testing, using ECG, CXR, basic and extended metabolic panels, CBC, hemostasis tests, and urinalysis in adult patients undergoing a broad range of elective surgeries. A sixth study compared time periods when patients were to receive either routine testing (during a retrospective period) or per protocol testing (during a prospective period) with a large number of tests. None of the nonrandomized studies adjusted for baseline differences in patient characteristics, types of surgery, surgeons or anesthesiologist, their experience, or other confounders. They also did not analyze how or whether the routine or per protocol tests were linked to resulting outcomes (complications). The RCT reported only on complications, of which there were only a small number; therefore, this trial was underpowered to provide any reliable estimate of relative differences in complications. We have no confidence in the estimate of effects across these studies due to these methodological deficiencies, the important clinical heterogeneity (differences) across all studies, and the high risk of bias of the nonrandomized studies (particularly related to lack of necessary adjustments). Another point that may call into question the validity of the four studies that evaluated ad hoc testing 25,27,28,34 is that the single study to report testing rates in the ad hoc group (Larocque et al.28) had similar or higher rates of testing than the per protocol group. This decrease in testing was the goal of implementing the protocol. Thus, comparisons with ad hoc testing do not adequately assess the actual effect of routine or per protocol testing, since the comparator is not no testing.

There is insufficient evidence regarding perioperative complications (Table 7). There is also insufficient evidence of a clinically significant difference in the rate of perioperative death. The clinical heterogeneity of studies, without reporting of subgroup analyses of patients or procedures within studies, further precludes a conclusion about which patients would benefit from routine testing. There is also insufficient evidence regarding other specific outcomes, including return to the operating room, prolonged hospital stay, or surgical cancellation or delay. No trial reported on quality of life or satisfaction, change in anesthesia or procedure plan, or resource utilization. A single high risk of bias nonrandomized study provided insufficient evidence regarding the comparison of routine and per protocol testing. Given the deficiencies in the evidence across studies, it was not possible to compare the effects of routine and per protocol testing. No trial addressed Key Question 2 regarding harms of routine preoperative testing. The evidence is inadequate to evaluate potential differences based on subgroups of interest.

### Orthopedic Surgery, Adults

A single retrospective nonrandomized study, published in 1999,^38^ evaluated preoperative testing in adults (including children >16 years old) undergoing various elective orthopedic (foot/ankle, knee, hand/wrist, shoulder) surgeries (Appendix C Tables C-1, C-2). The study compared routine testing with ECG, CXR, CBC, basic and extended metabolic profiles, urinalysis, hemostasis tests, and syphilis testing with per protocol use of CBC for all and ECG for patients greater than 45 years old (Table 8). It was deemed to be of high risk of bias, primarily because of the retrospective study design without appropriate adjustments and inadequate reporting of the analysis. Only one relevant outcome was reported, unplanned hospital admission or readmission within 30 days of surgery (Table 9, Appendix C Table C-9). There was no significant difference in unplanned hospital admission or readmission within 30 days of surgery between the two groups (P>0.6).

Table 8 Comparative study: Tests by study arm in orthopedic surgery

Author Year PMID | Arm | ECG | CXR | Basic Metabolic | Extended Metabolic | CBC | Hemostasis tests | Urinalysis | Pregnancy Test | Stress Test | Echo | Other
Mancuso 1999 10203622 | Routine | Yes | Yes | Yes | Yes | Yes | PT, PTT, ESR | Yes | | | | RPR
Mancuso 1999 10203622 | Per protocol | ≥50 yo | | | | Yes

CBC = complete blood count; CXR = chest x ray; ECG = electrocardiogram; Echo = echocardiogram; ESR = erythrocyte sedimentation rate; PT = prothrombin time; PTT = partial thromboplastin time; RPR = reactive plasma regain.

Table 9 Routine or per protocol versus ad hoc preoperative testing: Strength of evidence domains for orthopedic surgery

Outcome | Surgery | Tests | Study Design: No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Strength of Evidence
Unplanned hospital admission | Orthopedics, Adults | Various | NRS: 1 (640) | High | Direct | NA | Imprecise | N/A | Unadjusted analyses | Insufficient

CI = confidence interval; N/A = not applicable (when strength of evidence is insufficient based on the other four domains); NRS = nonrandomized comparative study.

No other relevant outcomes were reported. No subgroup analyses were reported.

#### Summary: Orthopedic Surgery, Adults

There is insufficient evidence regarding the comparison of routine versus per protocol preoperative testing in adults undergoing orthopedic surgery (Table 9). A single high-risk-of bias retrospective nonrandomized study found no difference in the rate of unplanned hospital admissions within 30 days of surgery.

### Vascular Surgeries, Adults

One low risk of bias RCT,37 published in 2003, compared routine stress dobutamine echocardiography versus no testing in people undergoing vascular surgery (Table 10). Three outcomes were reported, perioperative cardiac death, respiratory death, and congestive heart failure or elevated troponin I levels. (Table 11, Appendix C Table C-13). The trial was small, with only 99 patients, and there were few perioperative complications, including no cardiac deaths and only a single respiratory death in a patient who did not have a preoperative stress echocardiogram. A perioperative cardiac event occurred in 3/53 (5.7%) of patients without testing and 1/46 (2.2%) of patients with testing, yielding a RR = 0.38 (95% CI 0.04, 3.57).

Table 10 Comparative study: Tests by study arm in vascular surgery

Author Year PMID | Arm | ECG | CXR | Basic Metabolic | Extended Metabolic | CBC | Hemostasis tests | Urinalysis | Pregnancy Test | Stress Test | Echo | Other
Falcone 2003 14689407 | Routine | | | | | | | | | | Yes
Falcone 2003 14689407 | No testing

CBC = complete blood count; CXR = chest x ray; ECG = electrocardiogram; Echo = echocardiogram; ESR = erythrocyte sedimentation rate; PT = prothrombin time; PTT = partial thromboplastin time; RPR = reactive plasma regain.

Table 11 Routine preoperative testing: Strength of evidence domains for vascular surgery

Outcome | Surgery | Tests | Study Design: No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Strength of Evidence
Cardiac death | Vascular | Echo | RCT: 1 (99) | Low | Direct | NA | Imprecise | N/A | | Insufficient
Respiratory death | Vascular | Echo | RCT: 1 (99) | Low | Direct | NA | Imprecise | N/A | | Insufficient
Cardiac complication | Vascular | Echo | RCT: 1 (99) | Low | Direct | NA | Imprecise | N/A | | Insufficient

CI = confidence interval; Echo = dobutamine stress echocardiogram; N/A = not applicable (when strength of evidence is insufficient based on the other four domains); NRS = nonrandomized comparative study.

No other relevant outcomes were reported. No subgroup analyses were reported.

#### Summary: Vascular Surgery, Adults

There is insufficient evidence regarding the comparison of routine versus per protocol preoperative testing in adults undergoing vascular surgery (Table 11). A single low risk of bias RCT failed to find differences in rates of perioperative death or cardiac complications.

### General or Various Surgeries, Children

One English RCT 29 and an Italian nonrandomized study 32 evaluated preoperative testing in children undergoing various elective surgeries (Appendix C Tables C-1, C-2, Tables 12 and 13).

Table 12 Comparative study: Tests by study arm in general/various surgeries in children

Author Year PMID | Arm | ECG | CXR | Basic Metabolic | Extended Metabolic | CBC | Hemostasis tests | Urinalysis | Pregnancy Test | Stress Test | Echo | Other
Leonard 1975 1095116 | Routine | | | Na, K, CO_2_, BUN, “Reducing sugar” | Ca, P, ALP, total protein, Alb, cholesterol, SGOT, Mg | Hb
Leonard 1975 1095116 | Routine (Hb only) | | | | | Hb
Meneghini 1998 9483592 | Routine | | | | | Hb | | Yes | | | | CPK, cholinesterase
Meneghini 1998 9483592 | No testing

Alb = albumin; ALP = alkaline phosphatase; BUN = blood urea nitrogen; Ca = calcium; CBC = complete blood count; CO_2_ = carbon dioxide; CPK = creatine phosphokinase; CXR = chest x ray; ECG = electrocardiogram; Echo = echocardiogram; Hb = hemoglobin; K = potassium; Na = sodium; Mg = magnesium; P = phosphorus; SGOT = serum glutamic-oxaloacetic transaminase; yo = years old.

Table 13 Routine or per protocol versus ad hoc preoperative testing: Strength of evidence domains for general/various surgeries in children

Outcome | Surgery | Tests | Study Design: No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Strength of Evidence
Perioperative complications, total | Various, children | Multiple^*^ | NRS: 1 (10,656) | High | Direct | NA | Imprecise^†^ | N/A | Unadjusted analysis | Insufficient
Perioperative complications, major (total) | Various, children | Multiple^*^ | NRS: 1 (10,656) | High | Direct | NA | Imprecise^†^ | N/A | Unadjusted analysis | Insufficient
Perioperative complications, specific (selected) | Various, children | Multiple^*^ | NRS: 1 (10,656) | High | Direct | NA | Variable | N/A | Unadjusted analyses | Insufficient
Procedure cancellation | Various, children | Multiple^*^ | NRS: 1 (10,656) | High | Direct | NA | Imprecise | N/A | Unadjusted analysis | Insufficient
Length of stay | Various, children | Multiple^*^ | RCT: 1 (789) NRS: 1 (10,656) | High | Direct | Consistent | Imprecise | N/A | Unadjusted analyses | Insufficient

CBC = complete blood count; CI = confidence interval; ECG = electrocardiogram; N/A = not applicable (when strength of evidence is insufficient based on the other four domains); NRS = nonrandomized comparative study; RCT=randomized controlled trial.

* Nonrandomized study evaluated hemoglobin, urinalysis, creatine phosphokinase, and cholinesterase

† Summary RR 95% does not meet 20% threshold for MID

The RCT29 (which was published in 1975) compared a routine basic metabolic panel, an extended metabolic panel, and hemoglobin with routine hemoglobin only in all pediatric surgical patients expected to stay in the hospital less than 1 week (Table 12). It was deemed to be of medium risk of bias, primarily because inadequate reporting of the study design hampered assessment of their methods. The study did not report which specific surgeries were included. The only reported pertinent outcome was hospital length of stay (Appendix C Table C-11). There was no significant difference in length of stay between the two group (P>0.1). Those children who had the full panel of tests performed routinely had a mean hospital stay of 3.7 days (no range or measure of variability was reported); those who had only the routine hemoglobin performed had a mean hospital stay of 3.4 days.

The retrospective nonrandomized study,32 published in 1998, included children (who had not been delivered preterm) with ASA physical status 1 or 2 who underwent “elective minor surgery.” The study was deemed to be of high risk of bias, primarily because it failed to adjust for differences between the groups. The study compared an earlier 3-year period when it was hospital policy to routinely perform hemoglobin, urinalysis, creatine phosphokinase, and cholinesterase with a later 12-year period when there was no policy regarding preoperative testing (Table 12). The results of the study are unadjusted, but they reported that the two study groups were comparable with respect to age, type of surgery, and ASA physical status classification. Major complications occurred rarely (2/1884 [0.11%] during routine testing; 4/8772 [0.05%] during ad hoc testing) with RR = 2.33 (95% CI 0.43, 12.7). Minor complications were more common, but all resolved without sequelae (routine 292/1884 [15%] vs. ad hoc 1123/8772 [13%]); although the rates were similar (15% vs. 13%), they were significantly different (RR = 1.21; 95% CI 1.08, 1.36), favoring ad hoc testing. The rates of specific minor complications were also generally more common during the period of routine preoperative testing (Appendix C Table C-7), with clinically important differences for persistent vomiting and restlessness. The study found no significant difference in rates of longer than expected hospital stay because of surgical complications (routine 51/1884 [2.7%] vs. 266/8772 [3.0%]; RR = 0.89; 95% CI 0.66, 1.20) (Appendix C Table C-10). No planned surgeries were canceled due to abnormal test results.

The two studies did not report on other outcomes, including quality of life, satisfaction, surgical delay, change in anesthesia or procedure plan, resource utilization, or harms of routine testing.

#### Subgroup Analyses

The studies did not provide results data to allow analyses of any differences by subgroups of interest or based on who ordered the tests or the length of time prior to the procedure that the tests were conducted.

#### Summary: General or Various Surgeries, Children

One RCT from 1975 with medium risk of bias reported limited outcome data. A second retrospective, high risk of bias nonrandomized study failed to provide sufficient evidence regarding the effect on patient and resource outcomes of routine or per protocol preoperative testing. The limited data suggest no difference in length of hospital stay related to routine testing with basic and extended metabolic panels, and a counterintuitive increase in minor perioperative complications with routine preoperative testing. The age of the studies (38 and 15 years) further calls into question the applicability of their findings to modern pediatric surgical management. No study reported on quality of life, satisfaction, surgical delay, change in anesthesia or procedure plan, resource utilization, or harms of routine testing. The evidence is inadequate to evaluate potential differences based on subgroups of interest (Table 13).

### Tonsillectomy and/or Adenoidectomy, Children

A single retrospective nonrandomized study, published in 1997, compared perioperative complication rates among children scheduled for tonsillectomy and/or adenoidectomy (Appendix C Tables C-1, C-2, Tables 14 and 15).35 Zwack et al. compared the patients of 11 surgeons who routinely tested all patients with the hemostasis tests PT and partial thromboplastin time (PTT) and the patients of two surgeons who tested them with PT, PTT, and bleeding time based on their H&P (or if genetic family history information was unavailable) (Table 14). This study was deemed to have a high risk of bias. Of note, the two surgeons who did per protocol testing performed 50 percent more surgeries than the other 11 surgeons combined. The 11 surgeons conducting routine testing (who performed relatively few tonsillectomies) had significantly more perioperative bleeding complications (22/1750 [1.3%]) than the two more experienced surgeons conducting per protocol testing (16/2624 [0.7%]; P=0.027) (Appendix C Table C-14). Only 1 of the 22 children with bleeding complications after routine testing had a minimally abnormal PT (0.1 second above normal). Of the 16 children with bleeding complications after per protocol testing, 8 had normal hemostasis tests and 8 had had no hemostasis testing done.

Table 14 Comparative study: Tests by study arm in tonsillectomy

Author Year PMID | Arm | ECG | CXR | Basic Metabolic | Extended Metabolic | CBC | Hemostasis tests | Urinalysis | Pregnancy Test | Stress Test | Echo | Other
Zwack 1997 9051441 | Routine | | | | | Yes | PT, PTT
| Per protocol | | | | | Yes | PT, PTT, bleeding time (if the history and physical exam were suggestive or genetic [family] information was unavailable)

CBC = complete blood count; CXR = chest x ray; ECG = electrocardiogram; Echo = echocardiogram; PT = prothrombin time; PTT = partial thromboplastin time.

Table 15 Routine or per protocol vs. ad hoc preoperative testing: Strength of evidence domains for tonsillectomy

Outcome | Surgery | Tests | Study Design: No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Strength of Evidence
Perioperative complications, specific (selected) | Tonsillectomy, children | Coagulation tests | NRS: 1 (4374) | High | Direct | NA | Imprecise | N/A | Unadjusted analyses | Insufficient

CBC = complete blood count; CI = confidence interval; ECG = electrocardiogram; N/A = not applicable (when strength of evidence is insufficient based on the other four domains); NRS = nonrandomized comparative study; RCT=randomized controlled trial.

No other relevant outcomes were reported. No subgroup analyses were reported.

#### Summary: Tonsillectomy and/or Adenoidectomy, Children

There is insufficient evidence regarding routine (or per protocol) preoperative testing in children undergoing tonsillectomy and/or adenoidectomy (Table 15). A single, flawed, 16 year old, retrospective nonrandomized study found significantly higher rates of perioperative bleeding among patients of less experienced surgeons who routinely conducting hemostasis tests than more experienced surgeons who performed per protocol testing. However, none of the bleeding episodes were related to clinically significant abnormal coagulation tests, and the difference in bleeding rates was more likely to have been related to the experience and surgical volume of the surgeons.

## Cohort Study Findings

Given how few comparative studies were available, we looked at cohort studies to test the indirect link between testing and outcomes, since if tests can be shown not to affect management, they cannot affect outcomes. The weaknesses with this approach are that it is not possible to determine if the change in management led to better or worse outcomes and that the implicit comparison can be made only with no testing. No implicit comparison can be made with ad hoc testing based on H&P since there are no data on management changes based on the ad hoc testing. For the purposes of this section, we combined data from the true cohort studies and the routine or per protocol arms from the comparative studies. This section focuses on the rates of specific outcomes, and the data from the comparative studies are equivalent to those from the cohort studies. Among the 57 studies eligible for this review, the 47 with relevant outcomes are summarized in this section.

The 47 studies report a total of five “process” outcomes of interest, including change in patient management (4 studies conducted in adults), change in surgical technique (3 studies conducted in adults; 1 study conducted in children), change in anesthetic management (10 studies conducted in adults; 6 studies conducted in children), procedure cancellation (19 studies conducted in adults; 11 studies conducted in children), and procedure or anesthetic delay (19 studies conducted in adults; 7 studies conducted in children). Thirty-three (70%) of the studies were published before 2000. Thirty-nine (83%) of the studies evaluated routine preoperative testing; the other eight evaluated per protocol testing. An important caveat for the analysis of these studies is that, in general, it is only implied that procedure changes or cancellations were truly due to abnormal test results as opposed to changes that may have occurred for reasons separate from testing. While this caveat also applies to the comparative studies, in these analyses there is no reference group for comparison.

We summarize the information extracted from these studies in a series of tables (Appendix C Tables C15-18) and graphs (Figures 4–7). The underlying data, together with additional extracted information, is accessible online (at http://srdr.ahrq.gov/) in the project “Routine Preoperative Testing—Comparative Effectiveness Review 2013”.

Figure 4 Scatter: Change in surgical technique

ECT = electroconvulsive therapy; ENT = ear; nose; throat or head & neck surgery; Gen = general (or various) surgery; Neuro = neurologic surgery; Ophth = ophthalmic surgery (including cataract); Ortho = orthopedic surgery; T&A = tonsillectomy and/or adenoidectomy; Vasc = vascular surgery.

a/A = panel of tests; b/B = metabolic tests; c/C = blood counts; d/D = coagulation tests; e/E = urinalysis; f/F = electrocardiogram; g/G = chest x-ray; h/H = cardiac stress test; i/I = pregnancy test; j/J = sickle cell test. Upper case letters indicate routine tests; lower case letters indicate per protocol tests.

This scatter plot displays the proportion of patients who underwent a change in surgical technique (along the y-axis) based on what type of surgery they underwent (along the x-axis). Studies are coded based on which tests they underwent, as listed in the legend. Five studies reported data for general adult, general pediatric, and vascular surgery. Most reported 0 complications and one reported complications in less than 1 percent.

Figure 5 Scatter: Change in anesthesia management

ECT = electroconvulsive therapy; ENT = ear; nose; throat or head & neck surgery; Gen = general (or various) surgery; Neuro = neurologic surgery; Ophth = ophthalmic surgery (including cataract); Ortho = orthopedic surgery; T&A = tonsillectomy and/or adenoidectomy; Vasc = vascular surgery.

a/A = panel of tests; b/B = metabolic tests; c/C = blood counts; d/D = coagulation tests; e/E = urinalysis; f/F = electrocardiogram; g/G = chest x ray; h/H = cardiac stress test; i/I = pregnancy test; j/J = sickle cell test. Upper case letters indicate routine tests; lower case letters indicate per protocol tests.

This scatter plot displays the proportion of patients who underwent a change in anesthesia management (along the y-axis) based on what type of surgery they underwent (along the x-axis). Studies are coded based on which tests they underwent, as listed in the legend. Numerous studies reported data for general adult and six for general pediatric surgery. For adult surgery the surgeries with changes in anesthesia management ranged from 0 to 10.5 percent. For pediatric surgeries, most studies reported no changes in anesthesia management; two studies reported changes in 2 percent or fewer patients.

Figure 6 Scatter: Procedure cancellation

ECT = electroconvulsive therapy; ENT = ear; nose; throat or head & neck surgery; Gen = general (or various) surgery; Neuro = neurologic surgery; Ophth = ophthalmic surgery (including cataract); Ortho = orthopedic surgery; T&A = tonsillectomy and/or adenoidectomy; Vasc = vascular surgery.

a/A = panel of tests; b/B = metabolic tests; c/C = blood counts; d/D = coagulation tests; e/E = urinalysis; f/F = electrocardiogram; g/G = chest x ray; h/H = cardiac stress test; i/I = pregnancy test; j/J = sickle cell test. Upper case letters indicate routine tests; lower case letters indicate per protocol tests.

This scatter plot displays the proportion of patients who underwent a change in procedure cancellation (along the y-axis) based on what type of surgery they underwent (along the x-axis). Studies are coded based on which tests they underwent, as listed in the legend. Between 1 and 5 studies reported cancellations for most other surgeries. The majority of studies reported no cancellations. For general surgery, two of numerous surgeries had cancellations of 4 and 6.5%. For all other surgeries no more than 2 percent of surgeries were cancelled.

Figure 7 Scatter: Procedure delay

ECT = electroconvulsive therapy; ENT = ear, nose, throat or head & neck surgery; Gen = general (or various) surgery; Neuro = neurologic surgery; Ophth = ophthalmic surgery (including cataract); Ortho = orthopedic surgery; T&A = tonsillectomy and/or adenoidectomy; Vasc = vascular surgery.

a/A = panel of tests; b/B = metabolic tests; c/C = blood counts; d/D = coagulation tests; e/E = urinalysis; f/F = electrocardiogram; g/G = chest x ray; h/H = cardiac stress test; i/I = pregnancy test; j/J = sickle cell test. Upper case letters indicate routine tests; lower case letters indicate per protocol tests.

This scatter plot displays the proportion of patients who underwent a change in procedure delay (along the y-axis) based on what type of surgery they underwent (along the x-axis). Studies are coded based on which tests they underwent, as listed in the legend. Procedure delays were reported for most surgeries, most frequently for general adult surgery, of which one study reported delays in 5 percent of patients. All other studies (across surgeries) reported delays in fewer than 3 percent of patients.

The tables include information regarding the number of studies reported for each outcome by preoperative test category, the total number of subjects, and the range of patients with a given outcome across studies as a percentage. For each outcome within a preoperative test category, we also provide the combined (summary) percentages by test, along with their 95% confidence intervals. These were calculated by simple pooling (equivalent to fixed effect model for meta-analysis) and thus should not be construed as estimates of the true rates of the outcomes in the broader population. Instead, they provide a simple comparison of the rates found in existing studies across different procedures and tests. The scatter plots present the study specific proportion of subjects with each outcome by procedure. Given the vast clinical heterogeneity across studies, in terms of procedures, populations, and tests ordered, the scatter plots provide only a basic comparison across studies and not a true estimate of rates.

An analysis of all cohort data across outcomes, by publication year, raises a concern regarding the applicability and interpretation of the studies in regard to assessing the degree to which routine or per protocol tests result in changes in patient management. Namely, across all studies, almost all of the most frequent management changes (changes in anesthesia or surgery technique, delays, and cancellations) occurred in studies published prior to 2000. Except for a 5.1 percent rate of procedure delays in one study from 2005,^25^ all patient management changes that occurred in over 2 percent of patients were in older studies. As noted, only 8 (17%) studies used per protocol testing. Given the large clinical heterogeneity across studies, of which routine versus per protocol testing was only one difference, it was not possible to distinguish any differences in outcome rates based on whether testing was done routinely or per protocol.

### Change in Surgical Technique

Change in surgical technique was reported in three studies conducted in adults,52,73,79 and one study conducted in children.76 All studies were published prior to 1998. Three studies evaluated either hemostasis tests, a combined panel with various tests, or CXR in patients undergoing various or general surgical procedures; one study evaluated the outcome of a stress test before vascular surgery. The proportion of patients for whom the surgical technique was changed following the preoperative test was relatively low, ranging between 0 and 0.7 percent (Appendix C Tables C-15, C-23; Figure 4).

### Change in Anesthetic Management

Change in anesthetic management was evaluated in 10 studies of adults undergoing various/general procedures5,41,44,48,52,53,57,61,73,77 and 6 studies conducted in children.42,43,65,66,75,76 These 16 studies evaluated various preoperative tests, including a metabolic panel (2 adult studies), CXR (4 adult studies and 1 pediatric study), ECG (1 adult study), CBC (1 adult study and 2 pediatric studies), hemostasis (2 adult studies), combined panel with various tests (5 adults studies and 1 pediatric study), pregnancy test (2 pediatric studies).

The proportion of pediatric patients experiencing a change in anesthetic management across all tests is low, ranging between 0 and 2.3 percent. The proportion of adults for whom anesthetic management was changed following any preoperative test or combination of tests was higher, ranging between 0 and 10 percent. The highest proportion (10%) was in the study that evaluated electrolytes as part of the metabolic panel for 1001 patients. Notably, the studies that evaluated combined panels had inconsistent results, with four studies reporting 0 percent of patients experiencing the outcome and one study reporting 9 percent of patients experiencing the outcome (Appendix C Tables C-16, C-19; Figure 5). Among studies published between 1977 and 1988, between 0 and 10.5 percent (median 2.9%) of patients had anesthesia management changed, compared with 0 to 3.7 percent (median 0.1%) in the 1990s and 0 percent from 2002 to 2006. Among studies of routine testing, between 0 and 2.3 percent (median 0%) of patients had anesthesia management changed, compared with 0 to 10.5 percent (median 4.3%) with per protocol testing.

### Procedure Cancellation

Procedure cancellation was evaluated in 23 studies conducted in adults 4,5,30,33,34,40,41,47,50,52-54,56-58,61-63,68,69,72,79 and 11 studies conducted in children 32,42,43,49,55,59,65,67,70,71,74,80 (Appendix C Tables C-17, C-20, Figure 6).

The adult studies were conducted in patients undergoing various/general procedures (19 studies), ECT (5), cataract surgery (2), and one of each of the following procedures: head & neck, neurosurgery, orthopedic, and vascular surgery. These studies evaluated variety of preoperative tests. The only test that was evaluated in more than one or two studies was the combined panel test, which was evaluated in 11 studies, but the panel was not consistent across studies. The proportion of patients with procedure cancellation was low, ranging between 0 and 6.4 percent with eight combinations of test and procedure yielding a 0 percent cancellation rate.

The pediatric studies were conducted in children undergoing various/general procedures (6 studies), tonsillectomy (5), and head & neck/ENT surgery (1). The studies evaluated a variety of preoperative tests, including CBC, combined panel (1 study included a panel of the following tests: CBC, CXR, ECG, and metabolic panel; 11 studies included various tests; 1 study included a panel of the following tests: ECG, CXR, basic metabolic, CBC, urinalysis, and pregnancy test; and 1 study included a panel of the following tests: ECG, CXR, basic metabolic, CBC, and HIV), pregnancy test, hemostasis, and sickle cell. The proportion of children with procedure cancellation was relatively low, ranging between 0% - 0.5%.

Among studies published between 1983 and 1989, between 0 and 6.4 percent (median 0.1%) of patients had anesthesia management changed, compared with 0 to 2.0 percent (median 0%) in the 1990s and 0 to 2.0 (median 0%) percent from 2002 to 2009. Among studies of routine testing between 0 and 2.0 percent (median 0%) of patients had anesthesia management changed, compared with 0 to 6.4 percent (median 0.4%) with per protocol testing.

### Procedure or Anesthesia Delay

Procedure or anesthetic delay was evaluated in 19 studies conducted in adults 4,5,40,41,44,50,51,54,57,58,62,64,68,69,73,78,79,81 and 7 studies conducted in children 42,59,60,66,71,75,76,80 (Appendix C Tables C-18, C-21, Figure 7).

The adult studies were conducted in patients undergoing various or general surgeries (15 studies) with a variety of tests: seven of the 15 studies evaluated various combined panels, two studies evaluated patients undergoing orthopedic surgery, two studies vascular surgery, one study neurosurgery, and one head & neck/ENT surgery. The proportion of patients with procedure cancellation was relatively small across all procedures and tests, ranging from 0 to 5.1 percent.

The eight studies that evaluated this outcome in pediatric patients included children undergoing various/general procedures (6 studies) with various preoperative tests, including CXR (1 study), CBC (2), urinalysis (1), and pregnancy test (2). The other two studies evaluated the outcome of procedure or anesthetic delay in children undergoing head & neck/ENT surgery with CBC (1) and in children undergoing orthopedic surgery with a combined panel. The proportion of children with procedure or anesthetic delay ranged from 0 to 2.7 percent.

Among studies published between 1977 and 1989, between 0 and 1.2 percent (median 0.5%) of patients had anesthesia management changed, compared with 0 to 3.6 percent (median 0.5%) in the 1990s, and 0 to 5.1 percent (median 0.6%) from 2001 to 2013. Among studies of routine testing between 0 and 3.6 percent (median 0.4%) of patients had anesthesia management changed, compared with 1.0 to 5.1 percent (median 1.1%) with per protocol testing.

### Procedures for Which Testing Did Not Affect Outcomes

As noted, knowing the percentage of patients who had changes in their management provides very limited information regarding whether the tests affects patient outcomes in the absence of a contemporaneous comparison group. It remains unknown whether the patients benefited or were harmed by the changes in management. However, when a study finds that a test (or tests) led to no changes in management, it may be possible to conclude that the test did not affect patient clinical outcomes (other than possibly providing reassurance). However, this conclusion relies on the accuracy of the point estimate (of 0%) and ignores the possibility that the lack of events occurred by random chance. Nevertheless, the following is a summary of the studies and tests that led to no changes in patient management.

Of the 47 studies, 20 reported that the routine or per protocol tests evaluated did not lead to either procedure delay (7 studies),4,5,40,41,68,69,71 cancellation (17 studies),4,5,32,40,41,43,47,50,55,58,61-63,65,68-70 change in anesthesia management (5 studies),5,41,43,61,65 or surgical technique (2 studies).73,76 No study reported all four outcomes, and only two studies reported three of the outcomes (not change in surgical technique).5,41

However, in no scenario (specific test(s) used prior to the same category of procedures in the same population [adults vs. children]) were there at least two studies that both found no changes in patient management.

Nevertheless, among these 20 studies, patients undergoing ECT had no change in management based on CBC, metabolic panel, or CXR (1 study). Adults scheduled for a variety of elective surgeries had no changes in management based on metabolic panels, CBC, hemostasis tests, ECG, urinalysis, or pregnancy test (in 9 of 25 such studies). Children scheduled for a variety of elective surgeries had no changes in management based on metabolic panels, CBC, urinalysis, creatine phosphokinase, cholinesterase, or CXR (in 5 of 10 such studies). In one study each, adults having a panel of tests for neurosurgery, a panel for head & neck surgery, or hemostasis tests for orthopedic surgery had no changes in management. In two (of 5 such studies), children scheduled for tonsillectomy or adenoidectomy had no changes in management based on hemostasis tests, hemoglobin, or sickle cell testing.

### Change in Patient Management (With Subgroup Analyses)

Change in patient management was reported in four studies evaluating CBC, CXR, or ECG in adult patients undergoing various/general procedures.44-46,77 The proportion of patients experiencing this outcome was higher than for any other outcome, ranging between 2.5%-9.9%.

This was not a “clean” outcome for the purposes of this review, since it included medical consultations, new drugs administered, or “further evaluation.” However, we included this outcome because it was the only outcome that was analyzed by patient subgroup (Table 16). Four studies evaluated the proportion of various different patient age groups undergoing various/general procedures for the preoperative test of CXR (2 studies), CBC (1 study), or ECG (1 study).

Table 16 Subgroup analysis of changes in patient management

Author Year PMID | Study Design | Arm | Test | Subgroup | Subgroup Category | N Analyzed | Events (%) | P-value Between Subgroups
Age
Bhuripanyo 1990 2345323 | Retrospective cohort | Routine | CXR | Age | 15-29 | 223 | 2 (1%) | NR
Bhuripanyo 1990 2345323 | Retrospective cohort | Routine | CXR | Age | 30-44 | 291 | 3 (1%) | NR
Bhuripanyo 1990 2345323 | Retrospective cohort | Routine | CXR | Age | 45-59 | 223 | 12 (5%) | NR
Bhuripanyo 1990 2345323 | Retrospective cohort | Routine | CXR | Age | ≥60 | 196 | 17 (9%) | NR
Bhuripanyo 1995 7622976 | Prospective cohort | Routine | CBC | Age | 15-29 | 5 | 3 (60%) | NR
Bhuripanyo 1995 7622976 | Prospective cohort | Routine | CBC | Age | 30-44 | 10 | 8 (80%) | NR
Bhuripanyo 1995 7622976 | Prospective cohort | Routine | CBC | Age | 45-59 | 13 | 11 (95%) | NR
Bhuripanyo 1995 7622976 | Prospective cohort | Routine | CBC | Age | ≥60 | 10 | 8 (80%) | NR
Bhuripanyo 1992 1293256 | Prospective cohort | Routine | ECG | Age | 40-49 | 92 | 1 (1%) | NR
Bhuripanyo 1992 1293256 | Prospective cohort | Routine | ECG | Age | 50-59 | 123 | 4 (3%) | NR
Bhuripanyo 1992 1293256 | Prospective cohort | Routine | ECG | Age | 60-69 | 102 | 3 (3%) | NR
Bhuripanyo 1992 1293256 | Prospective cohort | Routine | ECG | Age | ≥70 | 76 | 2 (3%) | NR
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Age | ≤60 | 3257 | 66 (2%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Age | >60 | 2636 | 232 (9%) | <0.01
Sex
Bhuripanyo 1992 1293256 | Prospective cohort | Routine | ECG | Sex | Male | 145 | 4 (3%) | NR
Bhuripanyo 1992 1293256 | Prospective cohort | Routine | ECG | Sex | Female | 250 | 6 (2%) | NR
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Sex | Male | 2760 | 188 (7%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Sex | Female | 3306 | 125 (4%) | <0.01
Normal vs. Abnormal physical examination (PE)
Bhuripanyo 1992 1293256 | Prospective cohort | Routine | ECG | PE result | Normal | 357 | 8 (2%) | NR
Bhuripanyo 1992 1293256 | Prospective cohort | Routine | ECG | PE result | Abnormal | 38 | 2 (5%) | NR
ASA category
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | ASA | ASA 1-2 | 5062 | 155 (3%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | ASA | ASA 3-5 | 1018 | 158 (16%) | <0.01
Coexisting diseases
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Coexisting disease | None | 3569 | 90 (3%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Coexisting disease | Cardiac disease | 472 | 14 (5%) | <0.01
| | | | | Respiratory disease | 207 | 43 (21%)
Surgery severity
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery severity | Major | 659 | 66 (10%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery severity | Minor | 870 | 32 (4%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery severity | Standard | 4529 | 215 (5%) | <0.01
Surgery type
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Cardiac | 18 | 2 (11%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | General | 1860 | 112 (6%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Gynecologic | 527 | 14 (3%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Maxillofacial | 73 | 5 (7%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Neurosurgery | 121 | 9 (1%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Ophthalmology | 546 | 16 (3%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Orthopedic | 1367 | 62 (5%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Obstetric | 74 | 1 (1%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Ear, Nose, & Throat | 419 | 3 (1%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Plastic | 119 | 9 (8%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Thoracic | 65 | 21 (32%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Urologic | 459 | 37 (8%) | <0.01
Silvestri 1999 10713868 | Prospective cohort | Per protocol | CXR | Surgery type | Vascular | 225 | 23 (10%) | <0.01

ASA = American Surgical Association; CBC = complete blood count; CXR = chest x ray; ECG = electrocardiogram; NR = not reported

* See Appendix Table C-4 for details of the tests given for each arm.

Changes in patient management were reported by age in all studies. In both studies of CXR, change in patient management was significantly or substantially more common in older cohorts (9% among those >60 years old vs. 1-5% in younger cohorts). In two studies, CBC and ECG may have led to changes in management somewhat less frequently in younger people. In two studies that evaluated patients by sex, change in patient management related to ECG occurred equally among men and women, but CXRs yielded significantly more changes in management among men. In one study, the effect of ECG testing on change in patient management was similar among patients with normal and abnormal physical examinations. In another study, CXR resulted in significantly more changes in patient management among patients with a higher ASA category, those with respiratory disease, and those with “major” surgeries planned (as opposed to “minor” or “standard” surgeries), particularly patients undergoing thoracic, cardiac, and vascular surgeries. In summary, these cohort studies confirm a greater impact on management by increasing age, ASA category, and surgery risk.

### Summary

In all preoperative testing scenarios for which more than a single study was available (i.e., approaching a sufficient evidence base to form a conclusion) testing resulted in some changes in management. In other words, the evidence suggests that in most situations, routine preoperative testing will result in some delay or cancellation of the procedure (in most studies <2%) or some changes to anesthetic management (up to 11%) or surgical procedure (<1%). However, it is not possible to say whether the changes led to benefit or harm for patients because without a comparator group one cannot assess how the changes in management may have been associated with perioperative outcomes. Two studies suggest that change in management from CXR is more common for older patients (primarily >60 years), and one study each suggests that the effect of ECG is similar in men and women, but that CXR results in change in management in more men, those in a higher ASA risk category, those with respiratory disease, and those with “major” surgeries planned (as opposed to “minor” or “standard” surgeries), particularly patients undergoing thoracic, cardiac, and vascular surgeries. Two studies suggest that change in management from CXR is more common for older patients (primarily >60 years). Two other studies also looked at CXR and ECG by sex and other factors. One of these studies suggests that the effect of ECG is similar in men and women but the second study suggests that CXR results in change in management in more men, those with higher ASA category, those with respiratory disease, and those with “major” surgeries planned (as opposed to “minor” or “standard” surgeries), particularly in patients undergoing thoracic, cardiac, and vascular surgeries. The studies were too clinically heterogeneous to ascertain whether there were any patterns suggesting a difference in process outcomes based on whether preoperative testing was conducted routinely or per protocol.