# References

1 Apfelbaum JL, Connis RT, Nickinovich DG, et al. Practice advisory for preanesthesia evaluation: an updated report by the American Society of Anesthesiologists Task Force on Preanesthesia Evaluation. Anesthesiology. Mar. 2012;116(3):522-38. [pmid: 22273990].
2 Kumar A, Srivastava U. Role of routine laboratory investigations in preoperative evaluation. J Anaesthesiol Clin Pharmacol. Apr. 2011;27(2):174-79. [pmid: 21772675].
3 Bryson GL. Has preoperative testing become a habit?. Can J Anaesth. Jun. 2005;52(6):557-61. [pmid: 15983138].
4 Kaplan EB, Sheiner LB, Boeckmann AJ, et al. The usefulness of preoperative laboratory screening. JAMA. Jun. 28. 1985;253(24):3576-81. [pmid: 3999339].
5 Johnson RK, Mortimer AJ. Routine pre-operative blood testing: is it necessary?. Anaesthesia. Sep. 2002;57(9):914-17. [pmid: 12190758].
6 Pasternak LR. Preoperative testing: moving from individual testing to risk management. Anesth Analg. Feb. 2009;108(2):393-94. [pmid: 19151262].
7 MacPherson RD, Reeve SA, Stewart TV, et al. Effective strategy to guide pathology test ordering in surgical patients. ANZ J Surg. Mar. 2005;75(3):138-43. [pmid: 15777393].
8 Klein AA, Arrowsmith JE. Should routine pre-operative testing be abandoned?. Anaesthesia. Oct. 2010;65(10):974-76. [pmid: 21198466].
9 National Collaborating Centre for Acute Care (UK). Preoperative Tests: The use of routine preoperative tests for elective surgery. London. National Institute for Health and Clinical Excellence. Guidance. 2003. [pmid: 21089235].
10 Czoski-Murray C, Lloyd Jones M, McCabe C, et al. What is the value of routinely testing full blood count, electrolytes and urea, and pulmonary function tests before elective surgery in patients with no apparent clinical indication and in subgroups of patients with common comorbidities: a systematic review of the clinical and cost-effective literature. Health Techol Assess. 2012;16(50):1-159. [pmid: 23302507].
11 Keay L, Lindsley K, Tielsch J, et al. Routine preoperative medical testing for cataract surgery. Cochrane Database of Systematic Reviews. 2012;(3):CD0079293.
12 Fleisher LA, Beckman JA, Brown KA, et al. ACC/AHA 2007 Guidelines on Perioperative Cardiovascular Evaluation and Care for Noncardiac Surgery: Executive Summary: A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Writing Committee to Revise the 2002 Guidelines on Perioperative Cardiovascular Evaluation for Noncardiac Surgery) Developed in Collaboration With the American Society of Echocardiography, American Society of Nuclear Cardiology, Heart Rhythm Society, Society of Cardiovascular Anesthesiologists, Society for Cardiovascular Angiography and Interventions, Society for Vascular Medicine and Biology, and Society for Vascular Surgery. J Am Coll Cardiol. Oct. 23. 2007;50(17):1707-32. [pmid: 17950159].
13 American College of Radiology. ACR Appropriateness Criteria: Routine Admission and Preoperative Chest Radiography. http://www.acr.org/∼/media/ACR/Documents/AppCriteria/Diagnostic/RoutineAdmissionAndPreoperativeChestRadiography.pdf. 2013.
14 American Society of Anesthesiologists. ASA Physical Status Classification System. http://www.asahq.org/Home/For-Members/Clinical-Information/ASA-Physical-Status-Classification-System. Last accessed 7/1/2013.
15 Wallace BW, Small K, Brodley CE, et al. Deploying an interactive machine learning system in an evidence-based practice center: Abstrackr. Proceedings of the ACM International Health Informatics Symposium (IHI). 2012:819-24.
16 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
17 Higgins JP. Cochrane handbook for systematic reviews of interventions. Version 5.0.2. [updated September 2009]. The Cochrane Collaboration. 2009.
18 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
19 Santaguida P, Raina P, Ismaila A. McMaster Quality Assessment Scale of Harms (McHarm) for primary studies. http://bmg.cochrane.org/sites/bmg.cochrane.org/files/uploads/McHarm%20for%20Primary%20Studies.pdf, last accessed 1/8/13.
20 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
21 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
22 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
23 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):491-501. [pmid: 19540721].
24 Berkman ND, Lohr KN, Ansari Meal. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Research Report. PENDING. 2013.
25 Almanaseer Y, Mukherjee D, Kline-Rogers EM, et al. Implementation of the ACC/AHA guidelines for preoperative cardiac risk assessment in a general medicine preoperative clinic: improving efficiency and preserving outcomes. Cardiology. 2005;103(1):24-29. [pmid: 15528897].
26 Cavallini GM, Saccarola P, D'Amico R, et al. Impact of preoperative testing on ophthalmologic and systemic outcomes in cataract surgery. Eur J Ophthalmol. Sep. 2004;14(5):369-74. [pmid: 15506597].
27 Finegan BA, Rashiq S, McAlister FA, et al. Selective ordering of preoperative investigations by anesthesiologists reduces the number and cost of tests. Can J Anaesth. Jun. 2005;52(6):575-80. [pmid: 15983141].
28 Larocque BJ, Maykut RJ. Implementation of guidelines for preoperative laboratory investigations in patients scheduled to undergo elective surgery. Can J Surg. Oct. 1994;37(5):397-401. [pmid: 7922901].
29 Leonard JV, Clayton BE, Colley JR. Use of biochemical profile in children's hospital: results of two controlled trials. Br Med J. Jun. 21. 1975;2(5972):662-65. [pmid: 1095116].
30 Lira RP, Nascimento MA, Moreira-Filho DC, et al. Are routine preoperative medical tests needed with cataract surgery?. Rev Panam Salud Publica. Jul. 2001;10(1):13-17. [pmid: 11558245].
31 Nascimento MA, Lira RP, Soares PH, et al. Are routine preoperative medical tests needed with cataract surgery? Study of visual acuity outcome. Curr Eye Res. Apr. 2004;28(4):285-90. [pmid: 15259298].
32 Meneghini L, Zadra N, Zanette G, et al. The usefulness of routine preoperative laboratory tests for one-day surgery in healthy children. Paediatr Anaesth. 1998;8(1):11-15. [pmid: 9483592].
33 Schein OD, Katz J, Bass EB, et al. The value of routine preoperative medical testing before cataract surgery. Study of Medical Testing for Cataract Surgery. N Engl J Med. Jan. 20. 2000;342(3):168-75. [pmid: 10639542].
34 Wyatt WJ, Reed DN Jr., Apelgren KN. Pitfalls in the role of standardized preadmission laboratory screening for ambulatory surgery. Am Surg. Jun. 1989;55(6):343-46. [pmid: 2729769].
35 Zwack GC, Derkay CS. The utility of preoperative hemostatic assessment in adenotonsillectomy. Int J Pediatr Otorhinolaryngol. Feb. 14. 1997;39(1):67-76. [pmid: 9051441].
36 Chung F, Yuan H, Yin L, et al. Elimination of preoperative testing in ambulatory surgery. Anesth Analg. 2009;108(2):467-75. [pmid: 19151274].
37 Falcone RA, Nass C, Jermyn R, et al. The value of preoperative pharmacologic stress testing before vascular surgery using ACC/AHA guidelines: a prospective, randomized trial. J Cardiothorac Vasc Anesth. 2003;17(6):694-98. [pmid: 14689407].
38 Mancuso CA. Impact of new guidelines on physicians' ordering of preoperative tests. J Gen Intern Med. 1999;14(3):166-72. [pmid: 10203622].
39 Mignonsin D, Degui S, Kane M, et al. Value of selective prescription of preanesthetic laboratory tests. [French]. Cah Anesthesiol. 1996;44(1):13-17. [pmid: 8762245].
40 Aghajanian A, Grimes DA. Routine prothrombin time determination before elective gynecologic operations. Obstet Gynecol. Nov. 1991;78(5:Pt 1):837-39. [pmid: 1923209].
41 Alsumait BM, Alhumood SA, Ivanova T, et al. A prospective evaluation of preoperative screening laboratory tests in general surgery patients. Med Princ Pract. Jan. 2002;11(1):42-45. [pmid: 12116695].
42 Azzam FJ, Padda GS, DeBoard JW, et al. Preoperative pregnancy testing in adolescents. Anesth Analg. Jan. 1996;82(1):4-7. [pmid: 8712424].
43 Baron MJ, Gunter J, White P. Is the pediatric preoperative hematocrit determination necessary?. South Med J. Dec. 1992;85(12):1187-89. [pmid: 1470961].
44 Bhuripanyo K, Prasertchuang C, Chamadol N, et al. The impact of routine preoperative chest X-ray in Srinagarind Hospital, Khon Kaen. J Med Assoc Thai. Jan. 1990;73(1):21-28. [pmid: 2345323].
45 Bhuripanyo K, Prasertchuang C, Viwathanatepa M, et al. The impact of routine preoperative electrocardiogram in patients age > or = 40 years in Srinagarind Hospital. J Med Assoc Thai. Jul. 1992;75(7):399-406. [pmid: 1293256].
46 Bhuripanyo K, Khumsuk K, Sornpanya N, et al. The impact of routine preoperative complete blood count (CBC) in elective operations in Srinagarind Hospital. J Med Assoc Thai. Jan. 1995;78(1):42-47. [pmid: 7622976].
47 Bhuripanyo K, Prasertchuang C, Khumsuk K, et al. The impact of routine preoperative urinalysis in Srinagarind Hospital, Khon Kaen. J Med Assoc Thai. Feb. 1995;78(2):94-98. [pmid: 7629451].
48 Bouillot JL, Fingerhut A, Paquet JC, et al. Are routine preoperative chest radiographs useful in general surgery? A prospective, multicentre study in 3959 patients. Association des Chirurgiens de l'Assistance Publique pour les Evaluations medicales. Eur J Surg. Aug. 1996;162(8):597-604. [pmid: 8891616].
49 Burk CD, Miller L, Handler SD, et al. Preoperative history and coagulation screening in children undergoing tonsillectomy. Pediatrics. Apr. 1992;89(4:Pt 2):691-95. [pmid: 1557263].
50 Bushick JB, Eisenberg JM, Kinman J, et al. Pursuit of abnormal coagulation screening tests generates modest hidden preoperative costs. J Gen Intern Med. Nov. 1989;4(6):493-97. [pmid: 2585157].
51 Carliner NH, Fisher ML, Plotnick GD, et al. The preoperative electrocardiogram as an indicator of risk in major noncardiac surgery. Can J Cardiol. May. 1986;2(3):134-37. [pmid: 3719447].
52 Charpak Y, Blery C, Chastang C, et al. Usefulness of selectively ordered preoperative tests. Med Care. Feb. 1988;26(2):95-104. [pmid: 3339918].
53 Charpak Y, Blery C, Chastang C, et al. Prospective assessment of a protocol for selective ordering of preoperative chest x-rays. Can J Anaesth. May. 1988;35(3:(Pt 1)):259-64. [pmid: 3383317].
54 Correll DJ, Hepner DL, Chang C, et al. Preoperative electrocardiograms: patient factors predictive of abnormalities. Anesthesiology. Jun. 2009;110(6):1217-22. [pmid: 19417620].
55 Gabriel P, Mazoit X, Ecoffey C. Relationship between clinical history, coagulation tests, and perioperative bleeding during tonsillectomies in pediatrics. J Clin Anesth. Jun. 2000;12(4):288-91. [pmid: 10960200].
56 Gold BS, Young ML, Kinman JL, et al. The utility of preoperative electrocardiograms in the ambulatory surgical patient. Arch Intern Med. Feb. 1992;152(2):301-05. [pmid: 1739358].
57 Golub R, Cantu R, Sorrento JJ, et al. Efficacy of preadmission testing in ambulatory surgical patients. Am J Surg. 1992;163(6):565-70. [pmid: 1595835].
58 Haug RH, Reifeis RL. A prospective evaluation of the value of preoperative laboratory testing for office anesthesia and sedation. J Oral Maxillofac Surg. Feb. 21. 1999;57(1):16-20. [pmid: 9915390].
59 Hoare TJ. Pre-operative haemoglobin estimation in paediatric ENT surgery. J Laryngol Otol. Dec. 1993;107(12):1146-48. [pmid: 8289005].
60 Ipp L, Flynn P, Blanco J, et al. The findings of preoperative cardiac screening studies in adolescent idiopathic scoliosis. J Pediatr Orthop. Oct. 2011;31(7):764-66. [pmid: 21926874].
61 Johnson H Jr., Knee-Ioli S, Butler TA, et al. Are routine preoperative laboratory screening tests necessary to evaluate ambulatory surgical patients?. Surgery. Oct. 1988;104(4):639-45. [pmid: 3175862].
62 Kahn RL, Stanton MA, Tong-Ngork S, et al. One-year experience with day-of-surgery pregnancy testing before elective orthopedic procedures. Anesth Analg. 2008;106(4):1127-31. [pmid: 18349183].
63 Lafferty JE, North CS, Spitznagel E, et al. Laboratory screening prior to ECT. J ECT. Sep. 2001;17(3):158-65. [pmid: 11528304].
64 Lawrence VA, Kroenke K. The unproven utility of preoperative urinalysis. Clinical use. Arch Intern Med. Jun. 1988;148(6):1370-73. [pmid: 3377621].
65 Mallick MS. Is routine pre-operative blood testing in children necessary?. Saudi Med J. Dec. 2006;27(12):1831-34. [pmid: 17143358].
66 Malviya S, D'Errico C, Reynolds P, et al. Should pregnancy testing be routine in adolescent patients prior to surgery?. Anesth Analg. Oct. 1996;83(4):854-58. [pmid: 8831334].
67 Manning SC, Beste D, McBride T, et al. An assessment of preoperative coagulation screening for tonsillectomy and adenoidectomy. Int J Pediatr Otorhinolaryngol. Oct. 1987;13(3):237-44. [pmid: 3679679].
68 Mantha S, Roizen MF, Madduri J, et al. Usefulness of routine preoperative testing: a prospective single-observer study. J Clin Anesth. Feb. 2005;17(1):51-57. [pmid: 15721730].
69 Narr BJ, Hansen TR, Warner MA. Preoperative laboratory screening in healthy Mayo patients: cost-effective elimination of tests and unchanged outcomes. Mayo Clin Proc. Feb. 1991;66(2):155-59. [pmid: 1899710].
70 Nigam A, Ahmed K, Drake-Lee AB. The value of preoperative estimation of haemoglobin in children undergoing tonsillectomy. Clin Otolaryngol Allied Sci. Dec. 1990;15(6):549-51. [pmid: 2073764].
71 O'Connor ME, Drasner K. Preoperative laboratory testing of children undergoing elective surgery. Anesth Analg. Feb. 1990;70(2):176-80. [pmid: 2301750].
72 Paterson KR, Caskie JP, Galloway DJ, et al. The pre-operative electrocardiogram: an assessment. Scott Med J. Apr. 1983;28(2):116-18. [pmid: 6867689].
73 Perez A, Planell J, Bacardaz C, et al. Value of routine preoperative tests: a multicentre study in four general hospitals. Br J Anaesth. Mar. 1995;74(3):250-56. [pmid: 7718366].
74 Pierre N, Moy LK, Redd S, et al. Evaluation of a pregnancy-testing protocol in adolescents undergoing surgery. J Pediatr Adolesc Gynecol. Aug. 1998;11(3):139-41. [pmid: 9704304].
75 Roy WL, Lerman J, McIntyre BG. Is preoperative haemoglobin testing justified in children undergoing minor elective surgery?. Can J Anaesth. Sep. 1991;38(6):700-03. [pmid: 1914052].
76 Sane SM, Worsing RA Jr., Wiens CW, et al. Value of preoperative chest X-ray examinations in children. Pediatrics. Nov. 1977;60(5):669-72. [pmid: 917629].
77 Silvestri L, Maffessanti M, Gregori D, et al. Usefulness of routine pre-operative chest radiography for anaesthetic management: a prospective multicentre pilot study. Eur J Anaesthesiol. Nov. 1999;16(11):749-60. [pmid: 10713868].
78 Tape TG, Mushlin AI. How useful are routine chest x-rays of preoperative patients at risk for postoperative chest disease?. J Gen Intern Med. Jan. 1988;3(1):15-20. [pmid: 3339483].
79 Van Damme H, Pierard L, Gillain D, et al. Cardiac risk assessment before vascular surgery: a prospective study comparing clinical evaluation, dobutamine stress echocardiography, and dobutamine Tc-99m sestamibi tomoscintigraphy. Cardiovasc Surg. Feb. 1997;5(1):54-64. [pmid: 9158124].
80 Leppo J, Plaja J, Gionet M, et al. Noninvasive evaluation of cardiac risk before elective vascular surgery. J Am Coll Cardiol. Feb. 1987;9(2):269-76. [pmid: 3805515].
81 Phillips MB, Bendel RE, Crook JE, et al. Global health implications of preanesthesia medical examination for ophthalmic surgery. Anesthesiology. 2013;118(5):1038-45. [pmid: 23508220].
82 Eagle KA, Berger PB, Calkins H, et al. ACC/AHA guideline update for perioperative cardiovascular evaluation for noncardiac surgery--executive summary: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Update the 1996 Guidelines on Perioperative Cardiovascular Evaluation for Noncardiac Surgery). J Am Coll Cardiol. Feb. 6. 2002;39(3):542-53. [pmid: 11823097].
83 Qaseem A, Snow V, Fitterman N, et al. Risk assessment for and strategies to reduce perioperative pulmonary complications for patients undergoing noncardiothoracic surgery: a guideline from the American College of Physicians. Ann Intern Med. Apr. 18. 2006;144(8):575-80. [pmid: 16618955].
84 Smetana GW, Lawrence VA, Cornell JE, et al. Preoperative pulmonary risk stratification for noncardiothoracic surgery: systematic review for the American College of Physicians. Ann Intern Med. Apr. 18. 2006;144(8):581-95. [pmid: 16618956].
85 Schein OD, Katz J, Bass EB, et al. The value of routine preoperative medical testing before cataract surgery. Study of Medical Testing for Cataract Surgery. N Engl J Med. Jan. 20. 2000;342(3):168-75. [pmid: 10639542].
86 Myers E, Sanders GD, Ravi D, et al. Evaluating the Potential Use of Modeling and Value-of-Information Analysis for Future Research Prioritization Within the Evidence-based Practice Center Program. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.) AHRQ Publication No. 11-EHC030-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.