# Methods

The present Comparative Effectiveness Review (CER) follows the methodology outlined in the Agency for Healthcare Research and Quality's (AHRQ) 2012 “Methods Guide for Effectiveness and Comparative Effectiveness Reviews,” available at http://effectivehealthcare.ahrq.gov/ehc/products/60/318/MethodsGuide_Prepublication-Draft_20120523.pdf.

## AHRQ Task Order Officer

The AHRQ Task Order Officer (TOO) was responsible for overseeing all aspects of this project. The TOO facilitated a common understanding among all parties involved in the project, resolved ambiguities, and fielded all Evidence-based Practice Center (EPC) queries regarding the scope and processes of the project. The TOO and other staff at AHRQ helped to establish the Key Questions and protocol and reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## External Expert Input

During a topic refinement phase, the questions that had initially been nominated for this report were refined with input from a panel of Key Informants. The Key Informants included experts in anesthesia, general surgery, thoracic surgery, ophthalmology, radiology, internal medicine, and epidemiology. After a public review of the proposed Key Questions, a new panel of experts was convened to form the TEP. The TEP included experts in anesthesia, general surgery, urology, cardiology, internal medicine, and family medicine. The TEP provided input to help refine the protocol, identify important issues, and define the parameters for the review of evidence. The TEP was also asked to suggest additional studies.

## Literature Search

We conducted literature searches of studies in MEDLINE® and Ovid Healthstar® (inception – 22 July 2013), as well as the Cochrane Central Trials Registry® and Cochrane Database of Systematic Reviews® (through 2^nd^ Quarter, 2013). The reference lists of prior systematic reviews and relevant guidelines were hand-searched. All citations were screened to identify articles relevant to each Key Question. The search included terms for surgical procedures, preoperative care, diagnostic tests, including the specific tests ECG, chest radiography, blood counts, coagulation tests, biochemistry, glucose, urinalysis, kidney function tests, liver function tests, pregnancy tests, hemoglobinopathies, and pulmonary function tests (see Appendix A for complete search strings).

Scientific Information Packets were not solicited from industry, professional societies, or other interested researchers because all the tests have been in use for a long time and additional proprietary information is unlikely.

## Study Selection and Eligibility Criteria

The EPC has developed a computerized screening program, Abstrackr, to automate the screening of abstracts for eligible articles for full-text screening (http://sunfire34.eecs.tufts.edu).15 Three team members double-screened all abstracts after an iterative training period to ensure that all screeners agreed upon the eligibility criteria. Abstrackr allowed us to label each citation as “accept,” “reject,” or “maybe.” All abstracts with disagreements between readers or labeled as “maybe” were reconciled by the whole team in conference.

Full-text articles were retrieved for all potentially relevant articles. These were rescreened for eligibility. All rejected articles were confirmed by the team leader. The reasons for excluding these articles are tabulated in Appendix B.

Study eligibility was based on the following selection criteria: population and surgical procedure of interest, interventions (i.e., tests) and comparators of interest, outcomes of interest, and study designs. We did not consider outcomes when conducting abstract screening.

### Population and Condition of Interest

We included studies conducted in both adults (≥18 years) and children undergoing surgical procedures requiring either anesthesia or sedation. This included

- Patients undergoing any elective or ambulatory surgical or other invasive procedure that commonly requires anesthesia or sedation of any type or approach that is administered by an anesthesia team member. Cataract surgery was included regardless of local practice regarding anesthesia or sedation.
- Procedures in any setting, including inpatient, outpatient, and office-based.
- Any category of risk for surgical or anesthetic complications.
- Surgical procedures in any risk category, ranging from minor and minimally invasive through high risk, maximally invasive surgeries (e.g., vascular, neurologic, thoracic, abdominal, and pelvic surgeries).
- Patients undergoing nonsurgical diagnostic procedures that may require anesthesia or sedation (e.g., biopsy, colonoscopy) were excluded.

### Interventions of Interest

We included all preoperative tests likely to be conducted routinely (or on a per protocol basis). These included basic laboratory tests, simple radiography, and selective other relatively simple diagnostic tests.

We included:

- Electrolytes (e.g., sodium, potassium, bicarbonate, chloride)
- Kidney function tests (e.g., blood urea nitrogen, creatinine, glomerular filtration rate)
- Liver function tests (or other components of a “complete metabolic panel”)
- Glycemia measures (e.g., glucose, hemoglobin A1c)
- Blood counts (e.g., hemoglobin, hematocrit, white blood cells, platelets)
- Bleeding and coagulation tests (e.g., prothrombin time, bleeding test)
- Hemoglobinopathy tests (e.g., sickle cell)
- Urinalysis
- Pregnancy tests
- Chest radiography
- Electrocardiograms (ECG), 12 lead
- Cardiac stress tests
- Basic echocardiogram
- Pulmonary function tests

Other tests of potential interest were considered on a case-by-case basis and discussed with the TEP prior to inclusion. We excluded costly and invasive testing since these are not routinely performed in all patients or in a large group of patients per protocol or are used only in highly selective patients. Examples of excluded tests were computed tomography and magnetic resonance imaging tests, tests requiring markers or dyes (e.g., thallium stress testing), and invasive tests (e.g., angiography).

The tests had to have been conducted in the preoperative period (although we did not apply a maximum duration of time prior to the surgical procedure). At least implicitly, the tests had to have been performed for the purpose of assessing the patient's risk and status prior to the planned procedure. We excluded tests performed for the purpose of diagnosis or staging the disease for which the surgery was being performed or for specific surgical planning (e.g., imaging tests to determine the extent of cancer or echocardiography to evaluate valvular dysfunction prior to cardiac surgery). We also excluded patient factors other than tests, including patient history, symptoms, physical examination signs or findings, and demographic features, or panels of “tests” that included any of these factors. While patient symptoms, such as decompensated congestive heart failure, may be important reasons for altering, delaying, or canceling surgery, these should be routinely assessed as part of an appropriate standard of care.

In addition, for a given surgical procedure (or set of procedures), the tests had to have been conducted either routinely (i.e., in all patients undergoing the procedure, regardless of age, sex, or medical condition) or based on a standard protocol (i.e., in all patients who met certain predetermined criteria based on age, sex, medical condition, or other factors).

Intervention and comparator arms were sorted into four categories: routine (everyone was scheduled to have all tests), per protocol (a protocol was used to determine who had which tests), ad hoc (testing was done at a clinician's discretion), or no testing. The distinction between routine and per protocol testing was not always clear. If a study did not report sufficient information to distinguish the two, we assumed that routine testing was conducted. In a few instances, when a large number of tests were done routinely and a single test (e.g., ECG) was done per protocol, we also categorized this as routine testing.

### Comparators of Interest

Comparators of interest included no preoperative testing (of a panel of tests or by individual test), “ad hoc” testing (i.e., the tests were conducted at the discretion of the ordering clinician, regardless of the reason), per protocol testing (as a comparator to routine testing), a different panel of routine tests, testing conducted in a different setting or by a different type of clinician (e.g., in a specialized preoperative testing clinic versus by the patient's primary care physician), and testing done at different presurgery time points (e.g., within 30 days vs. within 6 months).

### Outcomes of Interest

For Key Question 1, outcomes of interest included clinical, other patient-centered, and intermediate outcomes. The outcomes were confined to those related to the conduct of the surgical procedures and anesthesia, perioperative events, patient satisfaction, and resource utilization. Specifically, these included:

- Clinical and other patient-centered outcomes
  ○ Procedure or anesthesia delay
  ○ Procedure cancellation
  ○ Perioperative clinical outcomes
    ■ Mortality
    ■ Surgical complications
  ○ Patient quality of life
  ○ Patient satisfaction
  ○ Patient resources, including time and lost work
  ○ Unplanned hospital admission or readmission within 30 days
  ○ Change in disposition of care (e.g., unplanned intensive care unit admission)
  ○ Length of hospital stay
  ○ Other resource utilization, including unplanned followup tests or procedures
- Intermediate outcome
  ○ Changes to perioperative patient management (other than procedure delay or cancellation)

For Key Question 2, outcomes of interest included adverse events or harms related to testing. Specifically, these included:

- Unnecessary or inappropriate procedure or anesthesia delays (based on an adjudication decision regarding appropriateness)
- Unnecessary or inappropriate procedure cancellation (based on an adjudication decision regarding appropriateness)
- Harms from testing or from interventions that resulted from test results
- “Unnecessary” followup tests or procedures (i.e., negative followup tests suggesting the preoperative test was false positive; e.g., a normal chest CT performed as followup to an abnormal routine preoperative chest radiography)

### Eligible Study Designs

We included published, peer-reviewed articles. We included studies in any patient setting where testing or surgical procedures may be conducted, including hospitals, inpatient and outpatient clinics, and clinicians' offices. We included studies that covered any timeframe, although they had to be longitudinal in design to the extent that testing was done prior to the planned procedure and followup occurred at least to the time of the procedure.

We included comparative studies (in which one or more protocols for testing was compared with other protocols for testing, including protocols for no testing), whether randomized or not. We included both prospective and retrospective studies. Eligible retrospective studies must have clearly included a sample of patients who received routine preoperative testing, not just patients who had preoperative testing done on an ad hoc basis. These could have included pre-post studies (e.g., before or after a testing policy was implemented) or studies with historical controls (where current practice is compared with a prior period at the same or a different institution).

Because we expected the comparative studies to be limited in quantity and quality, we also evaluated cohort (noncomparative, single group studies in which all study participants had the same testing battery or protocol). However, we limited these studies to those that reported “process” outcomes where the process of care was altered, including procedure or anesthesia delay, procedure cancellation, and other resource utilization, such as unplanned followup tests or procedures and changes to perioperative patient management. As discussed above in the Statement of Work, rates of other outcomes without a comparator would not provide interpretable data about the true benefits or harms of routine testing.

## Data Extraction and Summaries

Data from each study were extracted by one experienced methodologist. The extraction was reviewed and confirmed by at least one other methodologist. Data were extracted into customized forms in the Systematic Review Data Repository at http://srdr.ahrq.gov. Relevant data captured included publication information, study design, intervention and comparator arms, baseline characteristics, outcome definitions, results, and study quality. The forms were tested on several studies and revised before the commencement of full data extraction.

## Quality Assessment

We assessed the methodological quality of studies based on predefined criteria. We used a three-category grading system (Low, Medium, or High Risk of Bias) to denote the methodological quality of each study as described in the AHRQ methods guide.16 This system defines a generic grading scheme that is applicable to varying study designs, including RCTs, nonrandomized comparative trials, and cohort studies. We reviewed the Cochrane Risk of Bias list,17 the amended Newcastle-Ottawa Scale for cohort studies (http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp), the McMaster Quality Assessment Scale for Harms (McHarms), 18,19 and a list of quality measures commonly used by EPCs for relevant questions. We used all the concepts from the Cochrane Risk of Bias list but chose simpler, more straightforward questions from other sources.

For RCTs, we asked about clarity of eligibility criteria, avoidance of inappropriate exclusions, representativeness of the included patients, adequacy of the patient descriptions, full definitions of outcomes, outcome assessment blinding, dropout rate, use of intention-to-treat analyses, accounting for multicenter studies, reporting clarity without discrepancies, appropriateness of randomization technique, and allocation concealment. We omitted patient and caretaker blinding since this would not be feasible for almost all studies.

For nonrandomized studies, we asked about clarity of eligibility criteria, avoidance of inappropriate exclusions, representativeness of the included patients, adequacy of the patient descriptions, full definitions of outcomes, outcome assessment blinding, dropout rate, accounting for multicenter studies, reporting clarity without discrepancies, selection of the nonexposed cohort, and whether analyses adjusted for any baseline characteristics or confounders.

For cohort studies, we asked about clarity of eligibility criteria, avoidance of inappropriate exclusions, representativeness of the included patients, adequacy of the patient descriptions, full definitions of outcomes, dropout rate, reporting clarity without discrepancies, and whether a consecutive or random sample of patients was enrolled.

Based on the responses to the quality questions, we determined a risk of bias for each study. This was based on an overall assessment of the study. As a general guide, we used the following formulation.

Low Risk of Bias. These studies have the least apparent bias, and their results are considered valid. They generally possess the following: a clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; clear reporting of dropouts and a dropout rate less than 20 percent; and no obvious bias.

Medium risk of bias. These studies are susceptible to some bias, but it is not sufficient to invalidate the results. They do not meet all the criteria for low risk of bias due to some deficiencies, but none are likely to introduce major bias. They may be missing information, making it difficult to assess limitations, including risk of bias per se, and potential problems.

High risk of bias. These studies have been judged to carry a significant risk of bias that may invalidate the reported findings. These studies have serious errors in design, analysis, or reporting and contain discrepancies in reporting or have large amounts of missing information.

## Data Synthesis

We summarized all included studies in narrative form, as well as in summary tables (see below) that condense the important features of the study populations, design, intervention, outcomes, and results.

For comparisons of the same intervention and control arms in patients scheduled for sufficiently similar surgical procedures with the same outcomes in at least three studies, we performed DerSimonian & Laird random effects model meta-analyses of RRs.20 For each meta-analysis, the statistical heterogeneity was assessed with the I^2^ statistic, which describes the percentage of variation across studies that is due to heterogeneity rather than chance.21,22

To provide estimates of summary complication rates from cohort (single-group) studies, we performed simple pooling (dividing the sum of events by the sum of total patients), which is equivalent to a fixed effect model meta-analysis of proportions. This approach was chosen because it was the simplest and best accounted for the heterogeneity across studies and small numbers of events. The purpose of these summary estimates is only to compare reported rates of complications, not to determine a generalizable estimate of complication rates.

## Minimal Important Difference

P values, and by extension 95 percent confidence intervals (CI), assess the statistical significance of a difference between interventions (or other comparisons). Of greater relevance for users of the evidence is the concept of clinical significance, which addresses the question of whether a difference is clinically important. With sufficient power, a study can easily find a highly statistically significant difference that is of little importance to a patient, clinician, or other decisionmaker. To address this issue, with input from the TEP, we made a priori definitions for a line of difference in relation to clinically important thresholds, which are referred to as minimally important differences (MID).23 The MID is a clearly defined clinical threshold, below which the evidence (effect estimates and corresponding CIs) shows no meaningful difference and above which the evidence shows a benefit or harm of one intervention over another.24 Notably, for the purposes of a comparative effectiveness review, the utility of MID pertains primarily to bodies of evidence for which there is sufficient evidence.

We determined different MIDs for different outcomes. For mortality and major or severe life- or health-altering morbidities and complications (such as stroke, myocardial infarction, or life-threatening hemorrhage), the MID is 0 percent when determining if there is a clinically important difference. For this low risk (and generally low-cost) intervention (preoperative testing), any difference is of concern to patients and clinicians. In other words, all statistically significant differences are deemed to be clinically important. However, to make the determination that there is evidence of no difference, we used a threshold of 20 percent. Thus, only in cases where the 95 percent CI of a difference was within the boundaries of 0.80 to 1.20 (on the relative risk [RR] scale), did we determine that there was evidence of no important difference.

For other, noncritical outcomes, we also used a MID of 20 percent, based on agreement that smaller differences would not be clinically important. To determine that there is evidence of a clinically important difference, the 95 percent CI of the difference had to be fully beyond 0.80 or 1.20 (on the RR scale). Alternatively, to determine that there is evidence of no clinically important difference, the 95 percent CI of the difference had to fully within the range of 0.80 to 1.20 on the RR scale.

## Grading the Body of Evidence

We graded the strength of the body of evidence as per the AHRQ methods guide.16 Based on the division of outcomes within the Key Questions, we determined the strengths of evidence for the following three categories of outcomes: 1) clinical outcomes; 2) intermediate outcomes; and 3) harms.

We summarized study limitations, directness, consistency, precision, publication and reporting bias, and other issues. Study limitations (based on risk of bias) were defined as low, medium, or high based methodological quality, as described above. Directness pertained to whether the studies directly compared the interventions and the relevance of the specific outcomes assessed. We assessed the consistency of the data as either “no inconsistency” or “inconsistency present” (or not applicable, if there was only one study) based on the direction and magnitude of effects across studies. Precision was based primarily on whether the effect estimates fell within the MID. A precise estimate would allow a clinically useful conclusion based on the MID. An imprecise estimate was one for which the CI is wide enough to preclude a conclusion based on the MID. We evaluated publication and outcome reporting bias as a single domain (Reporting Bias) per AHRQ draft methods.10,24 The domain was assessed only if there was sufficient evidence based on the other four domains.24 Quantitative methods to assess reporting bias, including funnel plots, were planned if at least 10 studies reported an outcome for a given testing scenario.24 When there were fewer studies, we assessed the completeness of reporting of each outcome across studies and investigated unexplained statistical heterogeneity to assess the likelihood of reporting bias.10,24

We rated the strength of evidence for a particular comparison for each outcome category using one of the following four labels (as per the AHRQ methods guide): high, moderate, low, or insufficient. Ratings were assigned based on our level of confidence that the evidence reflected the true effect for the major comparisons of interest. Ratings were defined as follows:

High. We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable (i.e., another study would not change the conclusions).

Moderate. We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.

Low. We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.

Insufficient. We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion

We further assessed the body of evidence regarding its applicability to the U.S. population of patients undergoing surgical procedures. Where appropriate we assessed whether the studies were applicable to patients undergoing a specific procedures (e.g., cataract surgery) or to patients undergoing a category of procedures (e.g., children having general surgery). The assessment of applicability took into account the range of surgeries investigated, the severity of illness and other features of the included patients, and the currency of the evidence (e.g., whether the studies were done within the past 10 years).

## Peer Review

The initial draft report was prereviewed by the TOO and an AHRQ Associate Editor (a senior member of a sister EPC). Following revisions, the draft report was sent to invited peer reviewers and simultaneously uploaded to the AHRQ Web site where it was available for public comment for 30 days. All reviewer comments (both invited and from the public) were collated and individually addressed. The revised report and the EPC's responses to invited and public reviewers' comments were again reviewed by the TOO and Associate Editor prior to completion of the report. The authors of the report had final discretion as to how the report was revised based on the reviewer comments, with oversight by the TOO and Associate Editor.