# Introduction

Traditionally, preoperative testing has been part of the preoperative care process to inform patient selection by determining fitness for anesthesia and identifying patients at high risk for perioperative complications. Routine preoperative tests are defined by the American Society of Anesthesiologists (ASA) as those done in the absence of any specific clinical indication or purpose and typically include a panel of blood tests, urine tests, chest radiography, and electrocardiogram (ECG).1,2 These tests are performed to find latent abnormalities, such as anemia or silent heart disease, that could impact how, when, or whether the planned surgical procedure and concomitant anesthesia are performed. Tests performed either to assess the condition for which the procedure is being performed (e.g., visual acuity testing prior to cataract surgery) or to plan the surgery (e.g., imaging tests prior to cancer excision) are not considered routine preoperative testing.

Many hospitals have instituted protocols to perform a series of laboratory tests prior to any operative procedure under the assumption that this information will enhance safety for surgical patients and reduce liability for adverse events.2 During the past three decades routine preoperative testing has been challenged by several academic publications with concerns about the sizable cost of testing, overtesting and the consequences of false positive tests (leading to unnecessary workups and treatments), and the unknown benefit to patients.3-8 Preoperative testing is estimated to cost the U.S. $18 billion annually.2 In addition to increasing the cost of surgical care,2 nonselective preoperative testing may result in false positive or borderline results (in the absence of clinical indication), which require further investigation. Additional investigation may cause unnecessary psychological and economic burdens, postponement of surgery, and even morbidity and mortality (e.g., complications due to unnecessary biopsies performed to follow up false positive laboratory tests).2 As all routine testing does, preoperative testing will find some abnormal test results that will lead to new diagnoses (such as previously undetected lung cancer), but it is unclear whether the benefits of identifying and treating unsuspected abnormalities outweigh the harms of false positive preoperative tests and, if there is a net benefit, how this benefit compares to the resource utilization required for testing.

Three professional medical associations nominated this topic for systematic review, citing the wide variation in clinical practice, the need for a guideline for routine preoperative testing, and the likelihood that a comparative effectiveness review on this subject would have broad clinical impact—particularly if such a review included the most commonly ordered tests in healthy patients, as well as those with comorbidities, undergoing a wide variety of high- and low-risk surgeries.

Since the UK's National Institute for Health and Clinical Excellence (NICE) published an evidence-based review and guideline titled “The Use of Routine Preoperative Tests for Elective Surgery” in 2003,^9^ there have been no other systematic reviews, including AHRQ reports, comprehensively covering this topic. A subsequent Health Technology Assessment conducted a limited systematic review in 2008 (published in 2012) of blood and pulmonary function tests in low- or medium-risk patients,10 but they included no studies comparing testing versus no testing. A recent Cochrane review focused on randomized controlled trials (RCTs) of routine preoperative testing for cataract surgery. It concluded that there is no increase in safety of cataract surgery with routine preoperative testing.11 The American College of Cardiology and the American Heart Association (ACC/AHA) published a guideline on perioperative cardiovascular evaluation in 2007,^12^ which in part covered routine preoperative tests prior to cardiovascular surgery and routine preoperative cardiovascular tests (e.g., transesophageal echocardiography) for noncardiovascular surgery, but their review was considerably narrower in scope than this review.

The ACC/AHA guidelines help ascertain cardiac risk in patients undergoing noncardiac surgery. A consistent theme is that routine cardiac testing is rarely indicated and that intervention rarely lowers the risk of a procedure unless the intervention was indicated irrespective of the patient's upcoming surgery. For example, the ACC/AHA guidelines state that ECG is not indicated for asymptomatic patients undergoing low risk surgery. The American College of Radiology published Appropriateness Criteria (last reviewed in 2011) for chest radiography, which, similar to the ACC/AHA guidelines, state that routine chest radiography in asymptomatic patients is usually not appropriate and exposes patient to unnecessary radiation.13 The ASA likewise published a practice advisory in 2012, which stated that preoperative testing should not be ordered routinely, but acknowledged insufficient evidence to identify explicit rules for ordering preoperative tests based on specific clinical characteristics.1

## Considerations for the Evaluation of Preoperative Testing

### Alternative Testing Strategies

There is no common terminology among anesthesiologists and surgeons regarding the alternative preoperative testing strategies. For this review, we use the terms routine, per protocol, and or ad hoc as defined here:

1. Routine preoperative testing, where the tests of interest are conducted in all patients undergoing a given procedure, regardless of medical history or other patient features. Common examples of this approach are coagulation studies for all patients undergoing tonsillectomy or routine hematocrit levels for all patients undergoing surgeries with any expected blood loss.
2. Per protocol preoperative testing, where the tests of interest are conducted in a predefined subset of patients undergoing a given procedure. Implicitly or explicitly, the patients chosen for testing are those who, as a group, are considered to be at above-average risk for procedure-related complications. Common criteria used are age, medical history, and anesthesia or surgical risk category. Specific examples include obtaining electrocardiograms (ECGs) in all patients 50 years or older or kidney function tests in patients who have diabetes or are taking certain medications.
3. Ad hoc (or elective) testing, where preoperative testing is done at the discretion of the clinician doing a preoperative evaluation, based on patient history and physical examination (H&P) findings. No tests are done routinely or based on any protocol. The reasons for obtaining (or foregoing) a test will vary widely across patients and across ordering clinicians.

A fourth alternative, not explicitly considered here, would be a policy proscribing any testing prior to surgery. While this approach may theoretically be an option, it is not a real-world alternative in high-income countries.

In practice (and in research studies) there may also be overlap or combinations of these alternatives. A protocol may require that some tests be performed in all patients (e.g., complete blood counts [CBC]) but other tests be performed per protocol. Of course, in almost all settings, clinicians will have the option to add ad hoc tests to a list of routine or per protocol tests.

### Preoperative Tests

There are many preoperative tests that can be ordered for a patient and will help determine fitness for surgery and anesthesia. Routine tests are those that may be of value to reduce the risk of procedural complications but are not directly related to the planned procedure. The specific tests under review here are listed in the Methods section and include hematologic, metabolic, and organ function blood tests, hemostasis tests, urinalysis, chest radiography (and related tests), ECG (and related tests), and pregnancy tests. These tests may be done alone (e.g., only a pregnancy test) or as a panel of tests. Since different tests evaluate different conditions with different levels of accuracy, they can be expected to predict different complications and to be of varying value for different patients undergoing different procedures.

### Patient and Procedure Heterogeneity

Patients undergoing surgery show considerable variation in demographic characteristics, underlying health and comorbidities, indications for surgery, specific surgery planned, type of anesthesia planned (e.g., general versus spinal anesthesia), and other factors. Differences among these factors may result in differences in the benefits of finding abnormalities (e.g., anemia) and in the potential harms of testing (e.g., delayed surgery or unnecessary colonoscopy). Therefore, it is important to look not only at the benefits and harms of preoperative testing in general, but also at specific patient and intervention (surgery-related) factors that might change the balance between the benefits and harms; namely the risk of the surgical procedure, type of anesthesia planned, indication for surgery, comorbidities, and other patient characteristics.

#### Surgical Procedures

The risk of procedural complications varies widely based on the type of surgery. It thus follows that the potential benefit of preoperative testing will vary based on the risk of complications related to the planned surgery. While there is not a widely used methodology for determining overall surgical risk, we provide an example of a simple categorization, used effectively by the 2003 NICE guideline,9 which grades surgeries by the complexity and likelihood of blood loss and complications (Table 1). Other surgical risk categorizations have been developed, but are generally less generalizable. For example, the American College of Cardiology/American Heart Association Task Force on Practice Guidelines ranked procedures as high, medium, and low based on cardiac risk.12 Although it has yet to be demonstrated, one could expect that some preoperative tests may be of greater value in reducing complications in higher- rather than lower risk surgeries.

Table 1 Surgical severity grades, from 2003 NICE guideline9

Grade | Procedure Examples
Grade 1 (minor) | Cataract excision Skin lesion excision Breast abscess drainage
Grade 2 (intermediate) | Inguinal hernia primary repair Varicose vein excision Tonsillectomy/adenoidectomy Knee arthroscopy
Grade 3 (major) | Total abdominal hysterectomy Lumbar discectomy
Grade 4 (major+) | Total joint replacement Lung surgery Colonic resection Radical neck dissection Neurosurgery Cardiac surgery

#### Patient Health Status

Similarly, one could expect that the risk of complications, and thus the potential value of preoperative testing, may be greater for patients with worse overall health status. The American Society of Anesthesiologists (ASA) physical status classification system was created to assess a patient's fitness for surgery. The six categories are listed in Table 2. ASA class is commonly assessed and reported, and it may be an important factor in determining which patients would most benefit from preoperative testing (i.e., which patients should be included in a testing protocol). However, it should be noted that there is no explicit definition for each of the status classes; thus the categorization of individual patients into different classes may vary widely from hospital to hospital and anesthesiologist to anesthesiologist.

Table 2 American Society of Anesthesiologists (ASA) physical status classification system14

Class | Definition
ASA Physical Status 1 | A normal healthy patient
ASA Physical Status 2 | A patient with mild systemic disease
ASA Physical Status 3 | A patient with severe systemic disease
ASA Physical Status 4 | A patient with severe systemic disease that is a constant threat to life
ASA Physical Status 5 | A moribund patient who is not expected to survive without the operation
ASA Physical Status 6 | A declared brain-dead patient whose organs are being removed for donor purposes

#### Patient Clinical Characteristics

Beyond ASA class, patients undergoing surgery have considerable variation in clinical characteristics. This variation may lead to substantial differences in how abnormal preoperative testing findings are handled, as well as their potential effect on surgery. For example, an abnormal ECG performed as part of a protocol in a patient with history of coronary artery disease may result in a different preoperative intervention or a different threshold for canceling surgery than in a patient with no cardiac history, risk factors, or symptoms.

#### Anesthesia Type

In general, preoperative testing is considered primarily for procedures that require a member of an anesthetic team (anesthesiologist, certified registered nurse anesthetist, or equivalent). The type of anesthesia used is determined by the complexity and invasiveness of the planned surgery, the patient's medical condition and history, and his or her preferences. Types of anesthesia include general anesthesia, monitored anesthesia care (MAC, also known as sedation anesthesia or local anesthesia with sedation), neuraxial anesthesia (spinal or epidural), or regional anesthesia, including peripheral nerve block (such as femoral or brachial plexus blocks) or intravenous regional anesthesia (Bier block). Preprocedure testing is generally of limited utility for procedures requiring only local anesthesia or only sedation (without anesthesia). Different anesthetic techniques carry different risks and rates of complications; thus, preoperative testing may be of different value for patients undergoing different types of anesthesia. However, as noted, the type of anesthesia will be confounded with the type of surgery and the patient's medical condition.

### Clinician- and Setting-Based Differences

Inefficiencies in the preoperative testing processes or failures in the handoff of test results between primary care physicians, surgeons, and anesthesiologists ultimately affect the clinical utility of preoperative testing. Different hospitals, surgeons, and anesthesiologists have different protocols for preoperative testing, including, but not limited to, ad hoc testing by the surgeon or anesthesiologist, referral to the patient's primary care physician for testing at his or her discretion, and dedicated clinics with standardized protocols based on a patient's health status and planned surgery. Further, the comparator intervention, ad hoc testing, is by definition variable, depending on the clinician ordering the test, to what degree testing is based on any H&P he or she performs, and each clinician's likelihood of ordering few or many tests, which in part will be based on the local culture. Subsequent to testing, there is an implementation issue, in that any changes to patient outcomes due to testing must be mediated through clinical decisions about how to act on abnormal tests. Again, individual clinicians, different specialties, and different surgical settings are likely to have different thresholds for when and how to respond to abnormal tests. Examples include decisions about whether to delay or cancel surgery or whether to administer blood components preoperatively. This variability in care practices raises questions about whether ad hoc testing results in under- and/or over-utilization of tests (balancing benefits and harms) compared with per protocol testing, as well as whether testing ordered and followed up by different disciplines or types of clinicians have equivalent clinical utility. Examples of potentially ineffective testing due to process failures include tests performed by primary care physicians that are not transmitted to or followed up by surgeons and tests done by anesthesiologists that are not transmitted to or followed up by primary care physicians. There remains a lack of knowledge as to whether patient outcomes differ based on differences in testing protocols.

### Timing of Testing

A final factor that needs to be considered is the timing of the tests. Hospitals or surgical centers may dictate that preoperative testing must be done within a limited period of time before surgery, such as 30 days or 6 months. Anecdotally, this results in changes in surgical practice, such as performing the second eye cataract surgery earlier than would otherwise be indicated so that preoperative testing does not have to be repeated. However, it is unknown whether there is adequate evidence to support any particular time threshold for preoperative tests.

## Assessing the Clinical Utility of Preoperative Testing

Preoperative testing can have a direct impact only on certain outcomes of interest, including emotional and cognitive changes in the patient conferred by testing and its results, any harms associated with the testing procedure (e.g., pain, hemorrhage, or bruising from a blood draw, exposure to ionizing radiation from imaging tests), and costs to the patient (in the form of time spent or copayments) or other types of resource utilization. For the most part, however, testing has indirect effects:

- Test results can influence treatment choices, such as managing the abnormal test result (e.g., by blood transfusion) or changing the surgical or anesthetic technique (e.g., changing from general to regional anesthesia), and through them, patient outcomes (e.g., a previously unknown test abnormality may confer an increased risk of surgical mortality; the surgery thus may be appropriately delayed or canceled)
- Testing can prolong time to the procedure for logistical reasons (either appropriately to allow correction of or further treatment due to the abnormal test result or unnecessarily if no further treatment or evaluation was truly needed)
- Abnormal test results may lead to cascade testing (either appropriately if the test result signals a real abnormality or unnecessarily if the test result was spurious or was not due to a clinically important abnormality)

Therefore, when assessing the clinical effects of testing, we need to assess the clinical utility of patient-management strategies that include the testing and its downstream indirect effects. At the systems level, the volume of testing has a direct impact on resource utilization and costs borne by patients and payers. Further, unnecessary testing can overload resources with limited bandwidth (e.g., imaging), representing at a minimum an increase in managing and scheduling overhead.

Comparative studies (comparing different preoperative testing strategies) can effectively analyze all outcomes of interest. The range of outcomes that can be meaningfully assessed by noncomparative (cohort) studies, though, is more limited. Complication rates, the most important patient-centered outcomes, can only be adequately assessed by comparative studies, since the underlying risk of complications will vary across cohorts of patients and types of surgery. The complication rate in a cohort study of routine testing is difficult to interpret without an estimate of the expected complication rate without routine testing. The only outcomes from cohort studies that can provide some information to address the Key Questions are those directly related to the testing, such as surgery cancelation or delay due to an abnormal test. However, this outcome is of somewhat limited value since it does not address whether the patient was benefited or harmed by the surgical cancelation or delay.

## Statement of Work

In 2011, nominators proposed questions related to routine preoperative testing to AHRQ to form the basis of a comparative effectiveness review. The topic went through a process of topic refinement with a panel of Key Informants (including domain experts in anesthesia, general and breast surgery, and cardiology; health care payers with an interest in preoperative testing; a patient advocate; and representatives from the three nominators) and local domain experts (including an epidemiologist, internist, anesthesiologist, ophthalmologist, radiologist, and a thoracic and general surgeon). As described further in the Methods section, we also convened a Technical Expert Panel (TEP) to finalize the protocol. These panels generally agreed that the primary questions of interest related to the effectiveness of performing routine preoperative testing on a broad range of patients scheduled for a broad range of procedures requiring anesthesia with a variety of tests. The target audience for this review includes surgeons, anesthesiologists, and other clinicians involved in perioperative care of surgical patients; policymakers, including clinical practice guideline developers and surgical clinic administrators involved in determining preoperative testing policies and protocols; healthcare payers; researchers with an interest in perioperative care; and, ultimately, patients undergoing surgical procedures. While there was some discussion of limiting the range of procedures to either exclude “high risk” elective surgeries (given the existence of guidance for these surgeries related to cardiac risk from the ACC/AHA 12) or to the most common surgeries in the U.S., it was ultimately agreed to keep a broad purview. Furthermore, since anesthesia is commonly used for some nonsurgical procedures (such as electroconvulsive therapy) and thus preoperative testing may be considered, it was agreed to include both surgical and nonsurgical procedures that require the presence of an anesthetist (i.e., excluding sedation alone). The stakeholder panels also reviewed various lists of potential tests to be considered. The most complete list considered was from the NICE evidence-based review and guideline.9 While some tests were considered for exclusion, ultimately it was agreed to include a broad range of tests, based primarily on the tests that have been examined in studies. The final list of included tests is in the Methods section. After a series of discussions about what research questions would provide solid evidence about the actual value of routine (or per protocol) preoperative testing to reduce perioperative complications, as opposed to evidence that would support the contention that testing could theoretically reduce these complications, it was agreed to limit the scope of the key questions. The decision to focus this review on direct evidence (evidence regarding actual changes in patient outcomes and management) was made in part due to time and resource constraints. The restrictions to the scope of the Key Questions are described further in the following section.

This Comparative Effectiveness Review analyzes the value of routine and per protocol preoperative testing in patients undergoing procedures requiring anesthesia or sedation. The review focuses on the direct evidence of the comparative value of routine preoperative testing versus not testing (or other protocols for testing). This evidence is derived primarily from studies that directly compare testing protocols. These are the only studies that can demonstrate whether uniformly testing an unselected population prior to surgery leads to better outcomes for those patients. We also include cohort studies that report rates of “process outcomes” (rates of surgery cancellation, changes to planned surgery or anesthesia, etc.) only for patients being tested since the rate of procedure delay and cancellation, etc., due to testing is, by definition, zero in patients who do not undergo testing. However, no implicit comparison can be made with patients who undergo ad hoc testing based on their H&P.

The review does not evaluate questions that, while important and related to the topic at hand, do not provide direct evidence of the comparative value of testing versus not testing. The review does not evaluate analyses that would require assumptions about what might have occurred without testing (e.g., studies that reported complications only in patients who underwent testing) or assumptions about how testing might improve outcomes based on different rates of complications among patients with abnormal and normal preoperative tests. Specifically,

1. We do not assess the benefits and harms of preoperative testing based on the incidence of: perioperative complications (such as major bleeding) in studies that report only on patients who underwent testing (i.e., noncomparative studies). Two examples of such an analysis would be 1) a study that found no perioperative cardiac events and thus concluded that a preoperative electrocardiogram (ECG) would not have been of value; and 2) a study that found potentially preventable episodes of clinically significant postoperative bleeding and thus concluded that a preoperative bleeding time test would have been of value. While these studies make conclusions regarding the possible value of testing, they do not provide evidence regarding the actual effect of routine preoperative tests since the complication rates absent routine testing is unknown.
2. We do not systematically review the prevalence rates of abnormal test results for different populations of patients undergoing surgery. Some studies have reported that, because a given percentage of patients have an abnormal preoperative test (such as a chest radiograph) and the surgical and anesthesia teams could alter their care based on these abnormalities, patients could benefit from the test. However, such studies again do not provide evidence that actually ordering the test would alter perioperative outcomes since the effect of acting on the abnormal test result on perioperative outcomes is unknown.
3. We do not systematically review the test performance (e.g., sensitivity and specificity) of any of the tests. To systematically review test performance would require a broader review of each test, beyond its use in routine preoperative testing, than would be required to answer the given key questions. Further, test performance without patient outcomes does not directly address the value of routine preoperative testing; the effect of acting on the (true or false) abnormal test result on perioperative outcomes is unknown.
4. We do not assesses test results (i.e., abnormal vs. normal test results) as predictors of outcomes. The goal of this review is to assess whether actually ordering routine preoperative tests alters care and patient outcomes. We are not evaluating the predictors of clinical outcomes, including abnormal test results; association studies do not provide data on how the test performs in different populations or the balance of benefits and harms. For example, we do not evaluate whether patients with abnormal ECGs are at higher risk of perioperative complications than patients with normal ECGs. Instead, we evaluate whether patients who had ECGs performed routinely had different outcomes than patients who did not.

These types of analyses are too indirect to the questions at hand and would not provide convincing evidence regarding the comparative effectiveness of routine or per protocol testing versus ad hoc or no testing. Also, since the impact of testing is mediated by management change, abnormal test results that are not or cannot be acted on will not prevent perioperative complications. This review is focused on addressing, as best possible, the direct, comparative evidence. However, in the Future Research section of the Discussion, we discuss how indirect evidence could be incorporated in decision modeling.

## Analytic Framework

To guide the development of the Key Questions for the evaluation of preoperative testing, we developed an analytic framework (Figure 1) that maps the specific linkages associating the populations of interest, the interventions, the outcomes of interest (including harms), and the potential modifying factors. Specifically, this analytic framework depicts the chain of logic that the evidence must support to link the interventions to improved health outcomes.

Figure 1 Analytic framework for routine preoperative testing

KQ = Key Question.

This figure depicts the key questions within the context of the PICO described in the previous section. In general, the figure illustrates how use of preoperative testing may result in clinical and resource-related outcomes or harms. Patients undergoing elective invasive procedures (or surgeries) may have routine, per protocol, ad hoc, or no preoperative testing, which could result in changes in perioperative management decisions, which can result in perioperative outcomes (e.g., delays, cancellation, or changes in complications), postoperative outcomes (e.g., complications), patient-centered outcomes (e.g., changes in satisfaction), changes in resource utilization (e.g., patient visits or length of stay), or alternatively, harms related to preoperative testing or associated with followup procedures. The associations between preoperative testing and both outcomes and harms can be affected by modifying factors including the type of surgical procedure (e.g., high risk), patient factors (e.g., their indication for surgery or comorbidities), and the structure of the testing (e.g., routine versus per protocol versus ad hoc, the ordering clinician, the timeframe of the testing). The two key questions are mapped across these various factors.

## Key Questions

Key Question 1: How do routine or per protocol preoperative testing strategies compare to no testing or alternative testing strategies with respect to outcomes—including perioperative clinical outcomes, quality of life or satisfaction, periprocedural patient management decisions, and resource utilization—among patients undergoing elective surgical procedures? How do outcomes vary by:

a. the risk of the surgical procedure, the type of anesthesia planned, the indication for surgery, comorbidities, or other patient characteristics
b. the structure of testing (e.g., routine for everyone vs. per protocol, whether testing is conducted in a specialized preoperative clinic) or by who orders the tests (e.g., surgeon vs. anesthesiologist vs. primary care physician)
c. the length of time prior to the procedure that the tests are conducted

Key Question 2: What are the harms of routine or per protocol preoperative testing strategies compared to no testing or to an alternative testing strategies? How do outcomes vary by:

a. the risk of the surgical procedure, the type of anesthesia planned, the indication for surgery, comorbidities, or other patient characteristics
b. the structure of testing (e.g., routine for everyone vs. per protocol, whether testing is conducted in a specialized preoperative clinic) or by who orders the tests (e.g., surgeon vs. anesthesiologist vs. primary care physician)