# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Rongwei (Rochelle) Fu, Ph.D.
  Scientific Resource Center for the AHRQ Effective Health Care Program
  Portland VA Research Foundation
  Department of Public Health and Preventive Medicine
  Oregon Health and Science University
  Portland, OR
- David I. Soybel, M.D.
  Penn State Hershey Surgical Specialties
  General Surgical & Surgical Oncology
  Hershey, PA
- Bobbie Jean Sweitzer, M.D.
  Department of Anesthesia & Critical Care
  University of Chicago
  Chicago, IL