# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Steven R. Brown, M.D., FAAFP
  American Academy of Family Physicians
  University of Arizona College of Medicine
  Phoenix, AZ
- Nestor F. Esnaola, M.D., M.P.H., M.B.A., FACS
  American Geriatrics Society, American College of Surgeons
  Medical University of South Carolina
  Charleston, SC
- Nick Fitterman, M.D., FACP, SFHM
  American College of Physicians
  North Shore Long Island Jewish Health System
  Westbury, NY
- Lee A. Fleisher, M.D.
  University of Pennsylvania Health System
  Philadelphia, PA
- Barbara Gold, M.D., M.S.
  American Society of Anesthesiology
  University of Minnesota
  Minneapolis, MN
- Bernice Hecker, M.D., M.H.A., FACC
  CMS Contractor Medical Director
  Noridian Healthcare Solutions
  Fargo, ND
- William Stuart Reynolds, M.D., M.P.H.
  Department of Urologic Surgery
  Female Pelvic Medicine and Reconstructive Surgery Center for Surgical Quality and Outcomes Research
  Vanderbilt University Medical Center
  Nashville, TN
- Pamela Thompson, M.S., MT(ASCP)
  Division of Laboratory Science and Standards, American Society of Clinical Pathology
  Centers for Disease Control and Prevention
  Atlanta, GA