# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Deepak L. Bhatt, M.D., M.P.H.
  Department of Cardiology
  VA Boston Healthcare System
  Harvard Medical School
  Boston University School of Medicine
  Boston, MA
- Steven R. Brown, M.D., FAAFP
  American Academy of Family Physicians
  University of Arizona College of Medicine
  Phoenix, AZ
- Nick Fitterman, M.D., FACP, SFHM
  American College of Physicians
  North Shore Long Island Jewish Health System
  Westbury, NY
- Barbara Gold, M.D., M.S.
  American Society of Anesthesiology
  University of Minnesota
  Minneapolis, MN
- Bernice Hecker, M.D., M.H.A., FACC
  CMS Contractor Medical Director
  Noridian Healthcare Solutions
  Fargo, ND
- Mark E. Mattingly, M.D., FCCP
  Hospitalist Program
  Medical Affairs, Blue Cross & Blue Shield of RI
  Providence, RI
- John B. Pollard, M.D.
  Department of Anesthesia
  VA Palo Alto Health Care System
  Palo Alto, CA
- Susan E. Pories, M.D., FACS
  Department of Surgery
  Mount Auburn Hospital
  Harvard Medical School
  Cambridge, MA
- Pamela Wescott, M.P.P.
  Patient Perspectives
  Informed Medical Decisions Foundation
  Boston, MA