# Risk of Bias

Table D-1 Randomized controlled trials: Risk of bias

Study Author Year PMID | Overall Risk of Bias | Elig Crit | Inapp Excl | Highly Select | Pt Charact | Outcomes | Blinding | Dropout | ITT | Multi | Discrep | Random'n | Alloc Conc | Spec Out
Cavallini 2004 15506597 | Low | Yes | Yes | No | No | Yes | nd | Yes | Yes | NA | Yes | Yes | Yes | No
Chung 2009 19151274 | Low | Yes | Yes | No | Yes | No | Yes | Yes | Yes | NA | Yes | Yes | nd | No
Falcone 2003 14689407 | Low | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | NA | Yes | Yes | No | No
Leonard 1975 1095116 | Medium | Yes | Yes | No | No | Yes | Yes | Yes | nd | NA | Yes | nd | nd | No
Lira 2001 11558245 | Low | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | NA | Yes | nd | nd | No
Schein 2000 10639549 | Medium | Yes | Yes | No | Yes | Yes | nd | Yes | Yes | No | Yes | nd | nd | No

Elig Crit: Eligibility criteria—Were eligibility criteria clear?

Inapp Excl: Inappropriate Exclusions—Did the study avoid inappropriate exclusions?

Highly Select: Highly Selective—Was this a highly selected, non-representative cohort of patients?

Pt Charact: Patient Characteristics—Adequate of description of patient characteristics?

Outcomes Def: Outcomes Defined—Were all the outcomes fully defined?

Blinding: Outcome Assessor Blinding—Blinded outcome assessment?

Dropout: Dropout—Dropout rate <20%?

ITT: Intention to Treat—Was there an intention to treat analysis?

Multi: Multicenter—If multicenter, was this accounted for in the analysis?

Discrep: Clearness of Reporting—Clear reporting with no discrepancies?

Random'n: Randomization—Was there an appropriate randomization technique?

Alloc Conc: Allocation Concealment—Was there allocation concealment?

Spec Out: Specific Outcome Downgrading—Should any specific outcome be further downgraded for quality issues specific to that outcome? If so, describe which and why in the comment box.

Abbreviations: nd=not documented

Table D-2 Nonrandomized comparative studies: Risk of bias

Study Author Year PMID | Overall Risk of Bias | Elig Crit | Inapp Excl | Highly Select | Pt Charact | Outcomes | Blinding | Dropout | Multi | Discrep | Nonexp Cohort | Adjust
Almanaseer 2005 15528897 | High | Yes | Yes | No | Yes | Yes | nd | Yes | NA | Yes | Yes | No
Finegan 2005 15983141 | High | Yes | Yes | No | No | No | Yes | Yes | NA | No | Yes | No
Larocque 1994 | High | Yes | Yes | No | Yes | No | No | Yes | NA | Yes | Yes | No
Mancuso 1999 10203622 | High | Yes | Unclear | No | Yes | Yes | nd | Unsure | NA | Yes | Yes | No
Meneghini 1998 9483592 | High | Yes | Yes | No | No | Yes | No | Yes | NA | Yes | Yes | No
Mignonsin 1996 8762245 | High | No | Unclear | No | Yes | Yes | No | Yes | NA | Yes | Yes | No
Wyatt 1989 2729769 | High | Yes | Yes | No | No | Yes | nd | Yes | NA | Yes | Yes | No
Zwack 1997 9051441 | High | No | Unclear | Unsure | No | Yes | nd | Yes | NA | Yes | Yes | No

Elig Crit: Eligibility criteria—Were eligibility criteria clear?

Inapp Excl: Inappropriate Exclusions—Did the study avoid inappropriate exclusions?

Highly Select: Highly Selective—Was this a highly selected, non-representative cohort of patients?

Pt Charact: Patient Characteristics—Adequate of description of patient characteristics?

Outcomes Def: Outcomes Defined—Were all the outcomes fully defined?

Blinding: Outcome Assessor Blinding—Blinded outcome assessment?

Dropout: Dropout—Dropout rate <20%?

Multi: Multicenter: If multicenter, was this accounted for in the analysis?

Discrep: Clearness of Reporting–Clear reporting with no discrepancies?

Nonexp Coh: Nonexposed Cohort Selection: Was the nonexposed cohort drawn from the same community as the exposed cohort?

Adjust: Adjustments–Was the analysis adjusted for baseline characteristics?

nd=not documented