# Summary Tables

Table C-1 Study characteristics

Table C-2 Comparative studies: Baseline characteristics

Table C-3 Noncomparative studies: Baseline characteristics

Table C-4 Noncomparative study: Tests by study arm

Table C-5 Perioperative complications of cataract surgery

Table C-6 Procedure cancellations

Table C-7 Perioperative complications of general or various surgeries

Table C-8 Return to the operating room

Table C-9 Unplanned hospital admission

Table C-10 Prolonged hospital admission

Table C-11 Length of hospital stay (continuous outcome)

Table C-12 Procedure or anesthesia delay

Table C-13 Perioperative complications of vascular surgeries

Table C-14 Perioperative complications of tonsillectomy

Table C-15 Change in surgical technique

Table C-16 Change in anesthetic management

Table C-17 Procedure cancellations

Table C-18 Procedure or anesthetic delay

Table C-19 Noncomparative studies: Change in anesthetic management

Table C-20 Noncomparative studies: Procedure cancellations

Table C-21 Noncomparative studies: Procedure or anesthesia delay

Table C-22 Noncomparative studies: Change in patient management

Table C-23 Noncomparative studies: Change in surgical technique

Table C-24 Noncomparative studies: Duration of surgical delay