# List of Rejected Articles

Author | Year | PMID | Rejection reason
Adams JG. | 1992 | 1524480 | Test not performed in all patients (only “ad hoc”)
Akin BV. | 1987 | 3565429 | Not anesthesia-involved surgery or procedure
Allison JG. | 1996 | 8712570 | No outcome of interest
Ammar AD. | 1996 | 8976360 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Archer C. | 1993 | 8269561 | Not primary study
Arieta CE. | 2004 | 15029333 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Asimakopoulos G. | 1998 | 9654879 | Not test of interest
Bach DS. | 1998 | 9792564 | Not test of interest
Barazzoni F. | 1999 | 10356863 | No comparison of interest
Barazzoni F. | 2002 | 12201191 | No outcome of interest
Barisione G. | 1997 | 9192933 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Basora M. | 2006 | 17105489 | Not test of interest
Best WR. | 2002 | 11893128 | Test not performed in all patients (only “ad hoc”)
Blery C. | 1986 | 2867356 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Bléry C. | 1987 | 3578950 | No comparison of interest
Boghosian SG. | 1987 | 3805556 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Boland BJ. | 1995 | 7900740 | Not anesthesia-involved surgery or procedure
Boothe P. | 1995 | 7614645 | Restricted to patients with 24 hour LOS
Brady AR. | 2000 | 10848851 | Test not performed in all patients (only “ad hoc”)
Bryson GL. | 2006 | 16527786 | Test not performed in all patients (only “ad hoc”)
Carliner NH. | 1985 | 4014040 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Catchlove BR. | 1979 | 537560 | Not primary study
Chalas E. | 1992 | 1550175 | Test not performed in all patients (only “ad hoc”)
Cherng YG. | 1998 | 10399512 | Only analyze test results as predictor of/association with outcomes
Christian KW. | 1988 | 3213942 | No comparison of interest
Clelland C. | 1996 | 8865786 | Not test of interest
Close HL. | 1994 | 7991252 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Conway JB. | 1992 | 1464132 | Evaluation of ad hoc referral to preoperative clinic
Cooper JD. | 2010 | 20672369 | Not primary study
Crapo RO. | 1986 | 3715720 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Crawford MW. | 2005 | 16326676 | Test not performed in all patients (only “ad hoc”)
De la Matta Martín M. | 2011 | 21608275 | No comparison of interest
de Vries TW. | 1992 | 1407139 | No comparison of interest
Deffarges C. | 1990 | 2240691 | Test not performed in all patients (only “ad hoc”)
Delahunt B. | 1980 | 6782527 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Dzankic S. | 2001 | 11473849 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Eisenberg JM. | 1982 | 7055424 | No outcome of interest
Eisert S. | 2006 | 17080336 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Epstein AM. | 1986 | 3960081 | Not anesthesia-involved surgery or procedure
Escolano F. | 1994 | 8016434 | No comparison of interest
Escolano F. | 1996 | 9005498 | No comparison of interest
Feely MA | 2013 | 23547574 | Not primary study
Fischer SP. | 1996 | 8694365 | No outcome of interest
Fischer SP. | 1999 | 10331340 | Not primary study
Fleisher LA. | 1999 | 10512254 | Test not performed in all patients (only “ad hoc”)
Fok CS | 2013 | 23219547 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Fourcade RO. | 1989 | 2624447 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
France FH. | 1997 | 9489121 | Not primary study
Gagner M. | 1990 | 2383834 | Test not performed in all patients (only “ad hoc”)
García-Miguel FJ. | 2002 | 11898449 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
García-Miguel FJ. | 2002 | 12025252 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Gauss A. | 2001 | 11135720 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Goldman L. | 1977 | 904659 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Hennrikus WL. | 2001 | 11521041 | No outcome of interest
Houry S. | 1995 | 7793487 | Analyses include history and physical examination also
Howells RC. | 1997 | 9419090 | Test not performed in all patients (only “ad hoc”)
Huang CJ. | 2006 | 16643221 | Not test of interest
Hubbell FA. | 1985 | 3965947 | Not anesthesia-involved surgery or procedure
Hux J. | 2003 | 14628523 | Test not performed in all patients (only “ad hoc”)
Ishaq M. | 1997 | 9510631 | Test not performed in all patients (only “ad hoc”)
Jacobsen J. | 1987 | 3826581 | Not primary study
Jakobsson A. | 1984 | 6143913 | Not primary study
Jeavons SJ. | 1987 | 2963612 | Test not performed in all patients (only “ad hoc”)
Jones MW. | 1988 | 3408144 | Not primary study
Kabakibi A. | 1998 | 9535391 | Test not performed in all patients (only “ad hoc”)
Kerr IH. | 1974 | 4621286 | Not primary study
Kertai MD. | 2003 | 12572926 | Test not performed in all patients (only “ad hoc”)
Kim SK. | 1987 | 3269245 | Test not performed in all patients (only “ad hoc”)
Koscielny J. | 2007 | 17694224 | Diagnostic test; Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.);Only analyze test results as predictor of/association with outcomes
Kozak EA. | 1994 | 8082343 | Not anesthesia-involved surgery or procedure
Kroenke K. | 1986 | 3772598 | Not anesthesia-involved surgery or procedure
Krupski WC. | 2000 | 10737150 | Test not performed in all patients (only “ad hoc”)
Lamers RJ. | 1989 | 2586653 | No comparison of interest
Landesberg G. | 1997 | 9357456 | Not test of interest
Lawrence VA. | 1989 | 2511275 | Not primary study
Leppo J | 1987 | 3805515 | Not test of interest
Levy PA. | 1979 | 10315061 | No outcome of interest
Lim EH. | 2003 | 14620724 | Test not performed in all patients (only “ad hoc”)
Liu LL. | 2002 | 12133011 | Test not performed in all patients (only “ad hoc”)
Macpherson DS. | 1990 | 2240920 | Test not performed in all patients (only “ad hoc”)
Macpherson DS. | 1993 | 8441296 | Not primary study
Mamode N. | 2001 | 11735198 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
McGirt MJ. | 2006 | 16723885 | Test not performed in all patients (only “ad hoc”)
McKee RF. | 1987 | 3631872 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Mendelson DS. | 1987 | 3659353 | Test not performed in all patients (only “ad hoc”)
Meyer RA. | 1970 | 5266022 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Michel C. | 1989 | 2717842 | No comparison of interest
Moorman JR. | 1985 | 3929661 | Not anesthesia-involved surgery or procedure
Morales-Orozco C. | 2005 | 15888267 | No comparison of interest
Morise AP. | 1987 | 3565461 | No data specific to routine tests, only to combined test and physical examination
Moyes LH | 2013 | 23484995 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Murdoch CJ. | 1999 | 10460569 | Test not performed in all patients (only “ad hoc”)
Muskett AD. | 1986 | 3774723 | Test not performed in all patients (only “ad hoc”)
Myers ER. | 1994 | 8127539 | Test not performed in all patients (only “ad hoc”)
Nascimento MA. | 2005 | 15905943 | No comparison of interest
Nze PU. | 2008 | 18686829 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Ogunseyinde AO. | 1988 | 2845755 | No outcome of interest
Ohrlander T. | 2012 | 22801403 | Not test of interest
Older P | 1993 | 8365279 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Older P. | 1999 | 10453862 | Not test of interest
Pal KM. | 1998 | 10323056 | Test not performed in all patients (only “ad hoc”)
Papaceit J. | 2003 | 14599421 | No comparison of interest
Parolari A. | 2012 | 22269725 | Test not performed in all patients (only “ad hoc”)
Patel RI. | 1992 | 1632540 | Test not performed in all patients (only “ad hoc”)
Perlíková I. | 1994 | 8052921 | Not test of interest
Poe RH. | 1988 | 3122567 | Only analyze test results as predictor of/association with outcomes
Poldermans D. | 1993 | 8491005 | Not test of interest
Poldermans D | 2006 | 16949487 | No outcomes of interest
Pollard JB. | 1996 | 8694327 | Test not performed in all patients (only “ad hoc”)
Prause G. | 1994 | 8179172 | No comparison of interest
Qaseem A. | 2006 | 16618955 | Not primary study
Rabkin SW. | 1979 | 111793 | Mix of elective and emergency surgery; no outcomes of interest
Rabkin SW. | 1983 | 6848157 | Test not performed in all patients (only “ad hoc”)
Rader ES. | 1978 | 76362 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Rajamanickam A. | 2007 | 18368871 | Not primary study
Ritz JP. | 1997 | 9574329 | No comparison of interest
Robbins JA. | 1979 | 529881 | Not primary study
Roux A. | 1993 | 8432567 | Emergency surgery (trauma)
Royal College of Radiologists | 1979 | 87976 | Test not performed in all patients (only “ad hoc”)
Rucker L. | 1983 | 6645012 | Not anesthesia-involved surgery or procedure
Rutten CL. | 1995 | 7777084 | No comparison of interest
Sagel SS. | 1974 | 4413189 | Not anesthesia-involved surgery or procedure
Samková A. | 2012 | 21967473 | Analysis only of abnormal test results (in outpatient hematology clinic)
Sanders DP. | 1989 | 2511563 | Test not performed in all patients (only “ad hoc”)
Sandler G. | 1979 | 466256 | Not anesthesia-involved surgery or procedure
Savina MD. | 1986 | 3720934 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Scheckenbach K. | 2008 | 17581692 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Schmidt JL. | 1990 | 2228707 | Not primary study
Schwaab M. | 2008 | 17963191 | No comparison of interest
Schwaab M. | 2009 | 19034824 | No comparison of interest
Seymour DG. | 1983 | 6869118 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Seymour DG. | 1982 | 7170281 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Shafritz R. | 1997 | 9293826 | Not test of interest
Smetana GW. | 2006 | 16618956 | Not primary study
Sommerville TE. | 1992 | 1738905 | Test not performed in all patients (only “ad hoc”)
Starsnic MA. | 1997 | 9195353 | Did not report outcome of interest by group (or excluding elective testing)
Steib A. | 1994 | 7826793 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Stevens RD. | 2004 | 15460545 | Not primary study
Suchman AL. | 1986 | 3723774 | Test not performed in all patients (only “ad hoc”)
Syed MA. | 1998 | 9732881 | Not anesthesia-involved surgery or procedure
Tait AR. | 1997 | 9327318 | Test not performed in all patients (only “ad hoc”)
Tallo FS. | 2007 | 17906760 | No comparison of interest
Thanh NX. | 2010 | 20054679 | Not clearly “routine”; No outcomes of interest
Thompson RE. | 1979 | 121382 | Not primary study
Tisi GM. | 1979 | 373529 | Not primary study
Tomita M. | 2010 | 21069496 | Test not performed in all patients (only “ad hoc”)
Troisi N. | 2010 | 20472385 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Turnbull JM. | 1987 | 3592875 | Test not performed in all patients (only “ad hoc”)
Twersky RS. | 1996 | 8694346 | Not primary study
Vogt AW. | 1997 | 9278827 | Test not performed in all patients (only “ad hoc”)
Wattsman TA. | 1997 | 8985077 | Test not performed in all patients (only “ad hoc”)
Weksler N. | 2003 | 12770652 | Study comparing surgery postponement due to high BP vs. none
Wiencek RG. | 1987 | 3605857 | No PDF could be retrieve
Williams GD. | 1999 | 10468251 | Non-comparative and no process outcome (eg, LOS, surgical delay/cancel, follow-up testing, etc.)
Wilson J. | 1999 | 10213716 | Not test of interest
Wilson ME. | 1980 | 7370563 | Survey of anesthesiologists, essentially
Wilson RF. | 1979 | 435059 | Not anesthesia-involved surgery or procedure
Wood RA. | 1981 | 7254966 | Test not performed in all patients (only “ad hoc”)
Yipintsoi T. | 1989 | 2723562 | Too unclear a linkage between ECG results and subsequent management