# Literature Search Strategy

July 22, 2013

Five databases searched:

- Ovid MEDLINE(R) 1946 to July Week 3 2013
- EBM Reviews - Cochrane Database of Systematic Reviews 2005 to July 2013
- EBM Reviews - Cochrane Central Register of Controlled Trials to July 2013
- EBM Reviews - Health Technology Assessment to 2^nd^ Quarter 2013
- Ovid Healthstar - 1966 to July 2013

# | Searches | <<description>> | Results
1 | exp “Ambulatory Surgical Procedures”/ | | 21168
2 | exp “Surgical Procedures Elective”/ | | 16102
3 | exp “Preoperative Care”/ | | 105812
4 | ambulatory surg*.af. | | 23281
5 | elective surg*.af. | | 15691
6 | (preop or pre-op or pre-operative or pre operative or preoperative or “pre operative”).af. | | 334692
7 | or/1-6 | <<pre-op or surgery>> | 389716
8 | “Diagnostic Tests Routine”/ | | 13032
9 | ((diagnostic or laboratory) adj10 (test or tests or testing)).mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 151480
10 | exp “Sensitivity & Specificity”/ | | 705830
11 | “Predictive Value of Tests”/ | | 245895
12 | exp Mass Screening/ | | 215864
13 | (sensitivit* or specificit* or predictive value* or accuracy or likelihood ratio* or screening or false negative*).mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 2551208
14 | or/8-13 | <<tests, general>> | 2674572
15 | (comment or editorial or letter or news).pt. (exclusions) | <<exclusions>> | 2167401
16 | Electrocardiography.af. | | 284718
17 | (ecg or electrocardiogra*).mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 334122
18 | 16 or 17 | <<ECG>> | 334135
19 | Radiography/ | | 38507
20 | ((chest or thoracic) and (xray* or x-ray* or radiograph* or roentgenography)).af. | | 168282
21 | exp Radiography Thoracic/ | | 52842
22 | 19 or 20 or 21 | <<CXR>> | 211507
23 | exp Hemoglobins/ | | 146648
24 | (hemoglobin* or haemoglobin*).mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 226734
25 | exp Blood Cell Count/ | | 171734
26 | blood count.mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 7872
27 | white blood cell count.mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 9979
28 | leukocyte count.mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 74872
29 | platelet count.mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 40843
30 | 23 or 24 or 25 or 26 or 27 or 28 or 29 | <<blood counts>> | 415342
31 | exp Hemostasis/ or exp Hemostasis, Surgical/ | | 149861
32 | exp Hematologic Tests/ | | 299343
33 | (h?emostasis or h?ematologic test*).mp. | | 62604
34 | exp Blood Coagulation Tests/ | | 48188
35 | exp Blood Coagulation/ | | 65371
36 | blood coagulation/ | | 45934
37 | blood coagulation test.af. | | 48
38 | blood examination.af. | | 1063
39 | exp blood clotting test/ | | 0
40 | exp Partial Thromboplastin Time/ | | 8076
41 | exp International Normalized Ratio/ | | 6118
42 | (partial thromboplastin time or PTT).mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 16258
43 | (international normali?ed ratio or INR).mp. [mp=ti, ab, ot, nm, hw, kf, ps, rs, ui, tx, kw, ct, sh] | | 13053
44 | prothrombin time.mp. or exp Prothrombin Time/ | | 20444
45 | bleeding time.mp. or exp Bleeding Time/ | | 7413
46 | whole blood coagulation time.mp. or exp Whole Blood Coagulation Time/ | | 1831
47 | or/31-46 | <<hemostasis>> | 455996
48 | exp Biochemistry/ | | 500169
49 | biochemistry/ | | 17835
50 | blood chemistry.af. | | 4410
51 | exp Blood Chemical Analysis/ | | 162574
52 | exp Glucose Tolerance Test/ | | 41299
53 | (glucose tolerance or glucose test*).mp. | | 63039
54 | exp Diagnostic Techniques, Urological/ | | 163541
55 | diagnostic techniques urological.af. | | 887
56 | exp Urinalysis/ | | 7200
57 | (urine analysis or urinalysis or dipstick).mp. | | 19061
58 | exp Kidney Function Tests/ | | 91577
59 | kidney function test*/ | | 0
60 | ((kidney function or renal function) adj10 test*).mp. | | 33772
61 | exp Electrolytes/ | | 568493
62 | electrolyt*.mp. | | 111412
63 | creatinine.mp. or exp Creatinine/ | | 147554
64 | blood urea nitrogen.mp. or exp blood urea nitrogen/ | | 20558
65 | urea nitrogen blood level.af. | | 91
66 | or/48-65 | <<laboratory tests>> | 1562962
67 | blood glucose.mp. or exp blood glucose/ | | 207294
68 | blood sugar.mp. | | 12086
69 | glucose test*.mp. | | 2139
70 | glucose blood level.af. | | 1148
71 | or/67-70 | <<blood glucose>> | 212625
72 | exp pregnancy tests/ | | 4810
73 | pregnancy test*.mp. | | 6490
74 | exp chronic gonadotropin, beta subunit, human/ or beta hcg.mp. | | 4232
75 | or/72-74 | <<pregnancy test>> | 10542
76 | exp hemoglobinopathies/ | | 53186
77 | h?emoglobinopath*.mp. | | 8204
78 | exp Anemia, sickle cell/ or sickle cell.mp. | | 30193
79 | or/76-78 | <<sickle cell test>> | 57996
80 | exp respiratory function tests/ | | 323769
81 | lung function test.af. | | 976
82 | exp airway resistance/ | | 18628
83 | exp respiratory airflow/ | | 62793
84 | exp lung volume measurements/ | | 48566
85 | lung volume/ | | 0
86 | exp vital capacity/ | | 34096
87 | (vital capacity or VC).mp. | | 41126
88 | exp forced expiratory flow rates/ | | 16550
89 | exp forced expiratory volume/ | | 37389
90 | forced expiratory volume/ | | 37389
91 | ((pulmonary function or respiratory function or lung function) adj10 test*).mp. | | 75895
92 | (forced expiratory volume or fev).mp. | | 54666
93 | (peak expiratory flow rate or PEF).mp. or exp peak expiratory flow rate/ | | 16902
94 | forced respiratory function.af. | | 1
95 | exp blood gas analysis/ or blood gas*.mp. | | 67174
96 | or/80-95 | <<pulmonary tests>> | 363601
97 | 18 or 22 or 30 or 47 or 66 or 71 or 75 or 79 or 96 | <<tests, specific>> | 3102325
98 | (and/7,14,97) not 15 | <<pre-op & tests, general & tests, specific not exclusions>> | 7985
99 | limit 98 to yr=“1890 - 1999” | | 2622
100 | remove duplicates from 99 | | 1344
101 | limit 98 to yr=“2000 - 2013” | | 5363
102 | remove duplicates from 101 | | 2916
103 | (preop$ and test$).ti | <<terms added after peer review>> | 372
104 | 103 not (98 or 15) | | 262
105 | 100 or 102 | <<FINAL YIELD, deduplicated>> | 4581
| Ovid MEDLINE(R) | | (4346)
| EBM Reviews - Cochrane Database of Systematic Reviews | | (192)
| EBM Reviews - Cochrane Central Register of Controlled Trials | | (12)
| EBM Reviews - Health Technology Assessment | | (6)
| Ovid Healthstar | | (25)