# Sample Abstraction Forms

To see the Sample Abstraction Forms, please select the link below. This link will take you to a PDF version of the forms.

Sample Abstraction Forms