# Acknowledgments

We would like to thank David Jacobs, Ph.D., for his contribution to conceptualization and methodology of meta-analysis; Alisha Baines and Dianne Smith for programming support; the librarians Jim Beattie, M.L.I.S., Lisa McGuire, M.L.I.S., Judy Stanke, M.A., and Delbert Reed, Ph.D., for their contributions to the literature search; and Marilyn Eells for editing and formatting the report.

## Technical Expert Panel

Michael Barry, M.D., Massachusetts General Hospital, Boston, Massachusetts

D. Andrew Loblaw, M.D., Toronto Sunnybrook Regional Cancer Centre, Toronto, Ontario, Canada

Ian M. Thompson, M.D., University of Texas Health Science Center, San Antonio, Texas

## Peer Reviewers

Richard M. Hoffman, M.D., University of New Mexico Health Sciences Center, Albuquerque, New Mexico

John Wei, M.D., University of Michigan Health System, Ann Arbor, Michigan

## EPC Program Directors

Timothy J. Wilt, M.D., M.P.H., Minneapolis VA Center for Chronic Disease Outcomes Research, Minneapolis, Minnesota

Robert L. Kane, M.D., University of Minnesota, Minneapolis, Minnesota

## AHRQ Contacts

- Beth A. Collins Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- William Lawrence, M.D., M.S.
- Task Order Officer
- Evidence-based Practice Center Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD