# List of Excluded Studies

For Key Questions 1, 2, and 4: Excluded studies are available from the American Urological Association Guideline for the Management of Clinically Localized Prostate Cancer Database. (In press.)

There were 13,888 citations retrieved and reviewed. Of these, 1,764 were selected for winnowing; 759 accepted for further review, and 592 articles, judged potentially eligible, underwent an extraction process. The main reasons (and number of rejected articles) for rejection to narrow articles from 1,764 to 759 were: no outcomes data (435) and T3/T2 contamination (401). Upon further review of the 592 potentially eligible articles, 156 were rejected. Reasons for rejection (and number of rejected articles) included: no outcomes data (31); not local disease (38); T1–T2 patients <50 (7); known duplicate publications (10); other (60).

## Question 1. Quality of Life

### PCOS

1 Hoffman RM, Gilliland FD, Penson DF, Stone SN, Hunt WC, Potosky AL. Cross-sectional and longitudinal comparisons of health-related quality of life between patients with prostate carcinoma and matched controls. Cancer. 2004;101(9):2011-9. Previously published data. [pmid: 15452835].
2 Legler J, Potosky AL, Gilliland FD, et al. Validation Study of Retrospective Recall of Disease-Targeted Function: Results From the Prostate Cancer Outcomes Study. Medical Care. 2000;38(8):847-57. Validation study. [pmid: 10929996].
3 Penson DF, Feng Z, Kuniyuki A, et al. General Quality of Life 2 Years Following Treatment for Prostate Cancer: What Influences Outcomes? Results From the Prostate Cancer Outcomes Study. J Clin Oncol. 2003;21:1147-54. Not localized prostate cancer. [pmid: 12637483].
4 Potosky AL, Harlan LC, Stanford JL, et al. Prostate Cancer Practice Patterns and Quality of Life: the Prostate Cancer Outcomes Study. Journal of the National Cancer Institute. 1999;91(20):1719-24. No outcomes data. [pmid: 10528021].
5 Potosky AL, Knopf K, Clegg LX, et al. Quality-of-Life Outcomes After Primary Androgen Deprivation Therapy: Results >From the Prostate Cancer Outcomes Study. J Clin Oncol. 2001;19:3750-57. Not localized prostate cancer. [pmid: 11533098].
6 Potosky AL, Legler J, Albertsen PC, et al. Health outcomes after prostatectomy or radiotherapy for prostate cancer: results from the Prostate Cancer Outcomes Study. Journal of the National Cancer Institute. 2000;92(19):1582-92. Previously published data updated. [pmid: 11018094].
7 Potosky AL, Reeve BB, Clegg LX, et al. Quality of life following localized prostate cancer treated initially with androgen deprivation therapy or no therapy. Journal of the National Cancer Institute. 2002;94(6):430-7. Previously published data updated. [pmid: 11904315].

### Non-PCOS

1 Abdalla I, Basu A, Hellman S. An evidence-based analysis of the management of localized prostate cancer. Cancer Journal. 2002;8(1):40-6. Review article.
2 Abouassaly R, Lane BR, Lakin MM, Klein EA, Gill IS. Ejaculatory urine incontinence after radical prostatectomy. Urology. Dec. 2006;68(6):1248-52. Less than 100 patients per study arm. [pmid: 17141827].
3 Agarwal PK, Oefelein MG. Testosterone replacement therapy after primary treatment for prostate cancer. Journal of Urology. 2005;173(2):533-6. Less than 100 patients per study arm. [pmid: 15643240].
4 Ahmad MM. Psychometric evaluation of the Cognitive Appraisal of Health Scale with patients with prostate cancer. Journal of Advanced Nursing. 2005;49(1):78-86. Not comparative treatments. [pmid: 15610384].
5 Ahmad MM, Musil CM, Zauszniewski JA, Resnick MI. Prostate cancer: appraisal, coping, and health status. Journal of Gerontological Nursing. 2005;31(10):34-43. Not comparative treatments. [pmid: 16262089].
6 Ahmed S, Davies J. Managing the complications of prostate cryosurgery. BJU International. 2005;95(4):480-1. No QOL outcomes. [pmid: 15705063].
7 Al-Abany M, Helgason AR, Adolfsson J, Steineck G. Reliability of assessment of urgency and other symptoms indicating anal sphincter, large bowel or urinary dysfunction. Scandinavian Journal of Urology & Nephrology. 2006;40(5):397-408. Not comparative treatments. [pmid: 17060087].
8 Alberts SR, Novotny PJ, Sloan JA, Danella J, Bostwick DG, Sebo TJ, et al. Flutamide in men with prostatic intraepithelial neoplasia: a randomized, placebo-controlled chemoprevention trial. Am J Ther. Jul–Aug. 2006;13(4):291-7. Less than 100 patients per study arm. [pmid: 16858161].
9 Albertsen PC. Clinical and physical determinants for toxicity of 125-I seed prostate brachytherapy. Journal of Urology. 2005;174(5):1969-70. No QOL outcomes.
10 Alexianu M, Weiss GH. Radical prostatectomy versus brachytherapy for early-stage prostate cancer. Journal of Endourology. 2000;14(4):325-8. No QOL outcomes. [pmid: 10910147].
11 Alibhai SM, Naglie G, Nam R, Trachtenberg J, Krahn MD. Do older men benefit from curative therapy of localized prostate cancer?. Journal of Clinical Oncology. 2003;21(17):3318-27. No QOL outcomes. [pmid: 12947068].
12 Allen ZA, Merrick GS, Butler WM, Wallner KE, Kurko B, Anderson RL, et al. Detailed urethral dosimetry in the evaluation of prostate brachytherapy-related urinary morbidity. International Journal of Radiation Oncology, Biology, Physics. 2005;62(4):981-7. No QOL outcomes.
13 Anast JW, Sadetsky N, Pasta DJ, Bassett WW, Latini D, DuChane J, et al. The impact of obesity on health related quality of life before and after radical prostatectomy (data from CaPSURE). Journal of Urology. 2005;173(4):1132-8. Not comparative treatments. [pmid: 15758721].
14 Anastasiadis AG, Sachdev R, Salomon L, Ghafar MA, Stisser BC, Shabsigh R, et al. Comparison of health-related quality of life and prostate-associated symptoms after primary and salvage cryotherapy for prostate cancer. Journal of Cancer Research & Clinical Oncology. 2003;129(12):676-82. Not RCT. [pmid: 14569465].
15 Anger JT, Maliski SL, Krupski TL, Kwan L, Gore JL, Fink A, et al. Outcomes in men denied access to a California public assistance program for prostate cancer. Public Health Rep. Mar–Apr. 2007;122(2):217-23. Not comparative treatments. [pmid: 17357364].
16 Anonymous. Researchers study quality of life after prostate cancer. ONS News 2000;15(8):13. Not prospective or longitudinal survey study or RCT
17 Anonymous. Patient comfort an important consideration for treating men with prostate cancer. Urologic Nursing 2002;22(4):285. Not prospective or longitudinal survey study or RCT
18 Anonymous. Bush vs. Kerry: who is healthier? Both candidates are active, so their cardiovascular systems seem to be in tip-top shape. But they've had health problems typical of men their age. Harvard Health Letter 2004;30(1):6–7. Not localized prostate cancer
19 Arredondo SA, Downs TM, Lubeck DP, Pasta DJ, Silva SJ, Wallace KL, et al. Watchful waiting and health related quality of life for patients with localized prostate cancer: data from CaPSURE. Journal of Urology. 2004;172(5 Pt 1):1830-4. CaPSURE data. [pmid: 15540732].
20 Arredondo SA, Elkin EP, Marr PL, Latini DM, DuChane J, Litwin MS, et al. Impact of comorbidity on health-related quality of life in men undergoing radical prostatectomy: data from CaPSURE. Urology. 2006;67(3):559-65. CaPSURE data. [pmid: 16527580].
21 Arredondo SA, Latini DM, Sadetsky N, Kawakami J, Pasta DJ, DuChane J, et al. Quality of life for men receiving a second treatment for prostate cancer. Journal of Urology. Jan. 2007;177(1):273-8. discussion 8–9. Not comparative treatments. [pmid: 17162062].
22 Ashayeri E, Omogbehin A, Sridhar R, Shankar RA. Strontium 89 in the treatment of pain due to diffuse osseous metastases: a university hospital experience. Journal of the National Medical Association. 2002;94(8):706-11. Not localized prostate cancer. [pmid: 12152927].
23 Augustin H, Pummer K, Daghofer F, Habermann H, Primus G, Hubmer G. Patient self-reporting questionnaire on urological morbidity and bother after radical retropubic prostatectomy. European Urology. 2002;42(2):112-17. Not comparative treatments. [pmid: 12160580].
24 Auvinen A, Vornanen T, Tammela TL, Ala-Opas M, Leppilahti M, Salminen P, et al. A randomized trial of the choice of treatment in prostate cancer: design and baseline characteristics. BJU International. 2001;88(7):708-15. No QOL outcomes. [pmid: 11890241].
25 Bacon CG, Giovannucci E, Testa M, Glass TA, Kawachi I. The association of treatment-related symptoms with quality-of-life outcomes for localized prostate carcinoma patients. Cancer. 2002;94(3):862-71. Not comparative treatments. [pmid: 11857323].
26 Bacon CG, Giovannucci E, Testa M, Kawachi I. The impact of cancer treatment on quality of life outcomes for patients with localized prostate cancer. Journal of Urology. 2001;166(5):1804-10. Not prospective or longitudinal survey study. [pmid: 11586228].
27 Bailey DE, Mishel MH, Belyea M, Stewart JL, Mohler J. Uncertainty intervention for watchful waiting in prostate cancer. Cancer Nursing. 2004;27(5):339-46. Not comparative treatments. [pmid: 15525860].
28 Ball AJ, Gambill B, Fabrizio MD, Davis JW, Given RW, Lynch DF, et al. Prospective longitudinal comparative study of early health-related quality-of-life outcomes in patients undergoing surgical treatment for localized prostate cancer: a short-term evaluation of five approaches from a single institution. Journal of Endourology. Oct. 2006;20(10):723-31. Less than 1 year duration or follow-up. [pmid: 17094746].
29 Bang H, Jung SH, George SL. Sample size calculation for simulation-based multiple-testing procedures. Journal of Biopharmaceutical Statistics. 2005;15(6):957-67. Not localized prostate cancer. [pmid: 16279354].
30 Barqawi A, O'Donnell C, Kumar R, Koul H, Crawford ED. Correlation between LUTS (AUA-SS) and erectile dysfunction (SHIM) in an age-matched racially diverse male population: data from the Prostate Cancer Awareness Week (PCAW). International Journal of Impotence Research. 2005;17(4):370-4. Not comparative treatments. [pmid: 15889121].
31 Barreto F, Dall'Oglio M, Srougi M. Recurrent vesicourethal stenosis after radical prostatectomy: how to treat it?. International Braz J Urol. 2005;31(6):552-4. Less than 100 patients per study arm. [pmid: 16386124].
32 Basu A, Meltzer D. Value of information on preference heterogeneity and individualized care. Medical Decision Making. Mar–Apr. 2007;27(2):112-27. Not comparative treatments. [pmid: 17409362].
33 Batista-Miranda JE, Sevilla-Cecilia C, Torrubia R, Musquera M, Huguet-Perez J, Ponce de Leon X, et al. Quality of life in prostate cancer patients and controls: psychometric validation of the FACTP-4 in Spanish, and relation to urinary symptoms. Archivos Espanoles de Urologia. 2003;56(4):447-54. Not comparative treatments. [pmid: 12830620].
34 Befort CA, Zelefsky MJ, Scardino PT, Borrayo E, Giesler RB, Kattan MW. A measure of health-related quality of life among patients with localized prostate cancer: results from ongoing scale development. Clinical Prostate Cancer. 2005;4(2):100-8. Validation study. [pmid: 16197610].
35 Ben-Tovim DI, Dougherty ML, Stapleton AM, Pinnock CB. Coping with prostate cancer: a quantitative analysis using a new instrument, the centre for clinical excellence in urological research coping with cancer instrument. Urology. 2002;59(3):383-8. Not prospective or longitudinal survey study or RCT. [pmid: 11880075].
36 Berglund G, Petersson LM, Eriksson KC, Wallenius I, Roshanai A, Nordin KM, et al. “Between Men”: a psychosocial rehabilitation programme for men with prostate cancer. Acta Oncologica. 2007;46(1):83-9. Not comparative treatments. [pmid: 17438709].
37 Berry W, Friedland D, Fleagle J, Jackson D, Ilegbodu D, Boehm KA, et al. A phase II study of weekly paclitaxel/estramustine/carboplatin in hormone-refractory prostate cancer. Clin Genitourin Cancer. Sep. 2006;5(2):131-7. Not comparative treatments. [pmid: 17026801].
38 Bertaccini A, Ceccarelli R, Urbinati M, Galassi P, Vitullo G, De Stefano R, et al. BSP-PC (Bononian Satisfaction Profile—Prostate Cancer): development and validation of a “disease-specific” questionnaire for the evaluation of health-related quality of life in patients with prostate cancer. Archivio Italiano di Urologia, Andrologia. 2003;75(4):187-94. Less than 100 patients per study arm.
39 Bestmann B, Loetters C, Diemer T, Weidner W, Kuchler T, Rohde V. Prostate-specific symptoms of prostate cancer in a German general population. Prostate Cancer & Prostatic Diseases. 2007;10(1):52-9. Not comparative treatments. [pmid: 17102801].
40 Bestmann B, Rohde V, Siebmann JU, Galalae R, Weidner W, Kuchler T. Validation of the German prostate-specific module. World Journal of Urology. Feb. 2006;24(1):94-100. Not prospective or longitudinal survey study or RCT. [pmid: 16421733].
41 Bettuzzi S, Brausi M, Rizzi F, Castagnetti G, Peracchia G, Corti A. Chemoprevention of human prostate cancer by oral administration of green tea catechins in volunteers with high-grade prostate intraepithelial neoplasia: a preliminary report from a one-year proof-of-principle study. Cancer Research. 2006;66(2):1234-40. Not localized prostate cancer. [pmid: 16424063].
42 Bex A, Otto T, Lummen G, Rubben H. Phase II study of repeated single 24-hour infusion of low-dose 5-fluorouracil for palliation in symptomatic hormone-refractory prostate cancer. Urologia Internationalis. 2002;69(4):273-7. Not localized prostate cancer. [pmid: 12444282].
43 Bianco FJ Jr, Riedel ER, Begg CB, Kattan MW, Scardino PT. Variations among high volume surgeons in the rate of complications after radical prostatectomy: further evidence that technique matters.[see comment]. Journal of Urology. 2005;173(6):2099-103. No QOL outcomes. [pmid: 15879851].
44 Bidoli E, Talamini R, Bosetti C, Negri E, Maruzzi D, Montella M, et al. Macronutrients, fatty acids, cholesterol and prostate cancer risk. Annals of Oncology. 2005;16(1):152-7. No QOL outcomes. [pmid: 15598953].
45 Bisson JI, Chubb HL, Bennett S, Mason M, Jones D, Kynaston H. The prevalence and predictors of psychological distress in patients with early localized prostate cancer. BJU International. 2002;90(1):56-61. Not comparative treatments. [pmid: 12081771].
46 Black PC, Basen-Engquist K, Wang X, Swartz RJ, Eddings T, Matin SF, et al. A randomized prospective trial evaluating testosterone, haemoglobin kinetics and quality of life, during and after 12 months of androgen deprivation after prostatectomy: results from the Postoperative Adjuvant Androgen Deprivation trial. BJU International. Jul. 2007;100(1):63-9. Not localized prostate cancer. [pmid: 17552954].
47 Blank TO, Bellizzi KM. After prostate cancer: predictors of well-being among long-term prostate cancer survivors. Cancer. 2006;106(10):2128-35. Not localized prostate cancer. [pmid: 16607648].
48 Blatt HJ, Abel LJ, Stipetich RL, Galbreath RW, Lief JH, Butler WM, et al. Utilization of a self-administered questionnaire to assess rectal function following prostate brachytherapy. Urologic Nursing. 2001;21(5):356-9. Not comparative treatments. [pmid: 11998302].
49 Bloom JR, Stewart SL, Oakley-Girvans I, Banks PJ, Chang S. Family history, perceived risk, and prostate cancer screening among African American men. Cancer Epidemiology, Biomarkers & Prevention. Nov. 2006;15(11):2167-73. Not comparative treatments.
50 Boberg EW, Gustafson DH, Hawkins RP, Offord KP, Koch C, Wen KY, et al. Assessing the unmet information, support and care delivery needs of men with prostate cancer. Patient Education & Counseling. 2003;49(3):233-42. Not comparative treatments. [pmid: 12642195].
51 Boccardo F, Rubagotti A, Conti G, Potenzoni D, Manganelli A, Del Monaco D. Exploratory study of drug plasma levels during bicalutamide 150 mg therapy co-administered with tamoxifen or anastrozole for prophylaxis of gynecomastia and breast pain in men with prostate cancer. Cancer Chemotherapy & Pharmacology. 2005;56(4):415-20. No QOL outcomes. [pmid: 15838655].
52 Bode RK, Lai JS, Dineen K, Heinemann AW, Shevrin D, Von Roenn J, et al. Expansion of a physical function item bank and development of an abbreviated form for clinical research. Journal of Applied Measurement. 2006;7(1):1-15. Not localized prostate cancer. [pmid: 16385148].
53 Boehmer U, Babayan RK. Facing erectile dysfunction due to prostate cancer treatment: perspectives of men and their partners. Cancer Investigation. 2004;22(6):840-8. Less than 100 patients per study arm. [pmid: 15641481].
54 Bokhour BG, Clark JA, Inui TS, Silliman RA, Talcott JA. Sexuality after treatment for early prostate cancer: exploring the meanings of “erectile dysfunction”.[see comment]. Journal of General Internal Medicine. 2001;16(10):649-55. No QOL outcomes. [pmid: 11679031].
55 Bondy SJ, Iscoe NA, Rothwell DM, Gort EH, Fleshner NE, Paszat LF, et al. Trends in hormonal management of prostate cancer: a population-based study in Ontario. Medical Care. 2001;39(4):384-96. No QOL outcomes. [pmid: 11329525].
56 Borchers H, Kirschner-Hermanns R, Brehmer B, Tietze L, Reineke T, Pinkawa M, et al. Permanent 125I-seed brachytherapy or radical prostatectomy: a prospective comparison considering oncological and quality of life results. BJU International. 2004;94(6):805-11. Less than 100 patients per study arm. [pmid: 15476513].
57 Bradley EB, Bissonette EA, Theodorescu D. Determinants of long-term quality of life and voiding function of patients treated with radical prostatectomy or permanent brachytherapy for prostate cancer. BJU International. 2004;94(7):1003-9. Not localized prostate cancer. [pmid: 15541117].
58 Brandeis J, Pashos CL, Henning JM, Litwin MS. A nationwide charge comparison of the principal treatments for early stage prostate carcinoma. Cancer. 2000;89(8):1792-9. No QOL outcomes. [pmid: 11042575].
59 Brandeis JM, Litwin MS, Burnison CM, Reiter RE. Quality of life outcomes after brachytherapy for early stage prostate cancer. Journal of Urology. 2000;163(3):851-7. Not prospective or longitudinal survey study. [pmid: 10687991].
60 Brar R, Maliski SL, Kwan L, Krupski TL, Litwin MS. Changes in quality of life among low-income men treated for prostate cancer. Urology. 2005;66(2):344-9. Not localized prostate cancer. [pmid: 16040094].
61 Brasso K, Friis S, Juel K, Jorgensen T, Iversen P. The need for hospital care of patients with clinically localized prostate cancer managed by noncurative intent: a population based registry study. Journal of Urology. 2000;163(4):1150-4. No QOL outcomes. [pmid: 10737485].
62 Brehmer B, Kirschner-Hermanns R, Donner A, Reineke T, Knuchel-Clarke R, Jakse G. Efficacy of unilateral nerve sparing in radical perineal prostatectomy. Urologia Internationalis. 2005;74(4):308-14. Not comparative treatments. [pmid: 15897694].
63 Brindle LA, Oliver SE, Dedman D, Donovan JL, Neal DE, Hamdy FC, et al. Measuring the psychosocial impact of population-based prostate-specific antigen testing for prostate cancer in the UK. BJU International. Oct. 2006;98(4):777-82. Not comparative treatments. [pmid: 16978272].
64 Brown CT, O'Flynn E, Van Der Meulen J, Newman S, Mundy AR, Emberton M. The fear of prostate cancer in men with lower urinary tract symptoms: should symptomatic men be screened?. BJU International. 2003;91(1):30-2. Not localized prostate cancer. [pmid: 12614245].
65 Bruchovsky N, Klotz LH, Sadar M, Crook JM, Hoffart D, Godwin L, et al. Intermittent androgen suppression for prostate cancer: Canadian Prospective Trial and related observations. Molecular Urology. 2000;4(3):191-9. discussion 201. No QOL outcomes. [pmid: 11062374].
66 Bruner DW, Hanlon A, Mazzoni S, Raysor S, Konski A, Hanks G, et al. Predictors of preferences and utilities in men treated with 3D-CRT for prostate cancer. International Journal of Radiation Oncology, Biology, Physics. 2004;58(1):34-42. Not comparative treatments.
67 Buhler KR, Santucci RA, Royai RA, Whitney SC, Vessella RL, Lange PH, et al. Intermittent androgen suppression in the LuCaP 23.12 prostate cancer xenograft model. Prostate. 2000;43(1):63-70. Not human study. [pmid: 10725867].
68 Burns SM, Mahalik JR. Physical health, self-reliance, and emotional control as moderators of the relationship between locus of control and mental health among men treated for prostate cancer. J Behav Med. Dec. 2006;29(6):561-72. Not comparative treatments. [pmid: 16988886].
69 Burns-Cox N, Basketter V, Higgins B, Holmes S. Prospective randomised trial comparing diethylstilboestrol and flutamide in the treatment of hormone relapsed prostate cancer. International Journal of Urology. 2002;9(8):431-4. Not localized prostate cancer. [pmid: 12225339].
70 Buron C, Le Vu B, Cosset JM, Pommier P, Peiffert D, Delannes M, et al. Brachytherapy versus prostatectomy in localized prostate cancer: results of a French multicenter prospective medico-economic study. International Journal of Radiation Oncology, Biology, Physics. Mar 1. 2007;67(3):812-22. Not localized prostate cancer.
71 Butler WM, Merrick GS, Dorsey AT, Lief JH, Galbreath RW. Modern prostate brachytherapy. Medical Dosimetry. 2000;25(3):149-53. Review article. [pmid: 11025262].
72 Caffo O, Fellin G, Bolner A, Coccarelli F, Divan C, Frisinghelli M, et al. Prospective evaluation of quality of life after interstitial brachytherapy for localized prostate cancer. International Journal of Radiation Oncology, Biology, Physics. Sep 1. 2006;66(1):31-7. Not comparative treatments.
73 Calvert NW, Morgan AB, Catto JW, Hamdy FC, Akehurst RL, Mouncey P, et al. Effectiveness and cost-effectiveness of prognostic markers in prostate cancer. British Journal of Cancer. 2003;88(1):31-5. No QOL outcomes. [pmid: 12556955].
74 Cambio AJ, Ellison LM, Chamie K, deVere White RW, Evans CP. Cost-benefit and outcome analysis: effect of prostate biopsy undergrading. Urology. Jun. 2007;69(6):1152-6. Not comparative treatments. [pmid: 17572205].
75 Campbell LC, Keefe FJ, McKee DC, Edwards CL, Herman SH, Johnson LE, et al. Prostate cancer in African Americans: relationship of patient and partner self-efficacy to quality of life. Journal of Pain & Symptom Management. 2004;28(5):433-44. Not localized prostate cancer. [pmid: 15504620].
76 Campbell LC, Keefe FJ, Scipio C, McKee DC, Edwards CL, Herman SH, et al. Facilitating research participation and improving quality of life for African American prostate cancer survivors and their intimate partners. A pilot study of telephone-based coping skills training. Cancer. Jan 15. 2007;109(2 Suppl):414-24. Not comparative treatments. [pmid: 17173280].
77 Canada AL, Neese LE, Sui D, Schover LR. Pilot intervention to enhance sexual rehabilitation for couples after treatment for localized prostate carcinoma. Cancer. 2005;104(12):2689-700. No QOL outcomes. [pmid: 16294343].
78 Carlson LE, Speca M, Patel KD, Goodey E. Mindfulness-based stress reduction in relation to quality of life, mood, symptoms of stress, and immune parameters in breast and prostate cancer outpatients. Psychosomatic Medicine. 2003;65(4):571-81. Less than 100 patients per study arm. [pmid: 12883107].
79 Carlson LE, Speca M, Patel KD, Goodey E. Mindfulness-based stress reduction in relation to quality of life, mood, symptoms of stress and levels of cortisol, dehydroepiandrosterone sulfate (DHEAS) and melatonin in breast and prostate cancer outpatients. Psychoneuroendocrinology. 2004;29(4):448-74. Less than 100 patients per study arm. [pmid: 14749092].
80 Carmack Taylor CL, de Moor C, Basen-Engquist K, Smith MA, Dunn AL, Badr H, et al. Moderator analyses of participants in the Active for Life after cancer trial: implications for physical activity group intervention studies. Ann Behav Med. Feb. 2007;33(1):99-104. Not comparative treatments. [pmid: 17291175].
81 Carmack Taylor CL, Demoor C, Smith MA, Dunn AL, Basen-Engquist K, Nielsen I, et al. Active for Life After Cancer: a randomized trial examining a lifestyle physical activity program for prostate cancer patients. Psycho-Oncology. Oct. 2006;15(10):847-62. Less than 100 patients per study arm. [pmid: 16447306].
82 Carmack Taylor CL, Smith MA, de Moor C, Dunn AL, Pettaway C, Sellin R, et al. Quality of life intervention for prostate cancer patients: design and baseline characteristics of the active for life after cancer trial. Controlled Clinical Trials. 2004;25(3):265-85. No QOL outcomes. [pmid: 15157729].
83 Cathala N, Brillat F, Mombet A, Lobel E, Prapotnich D, Alexandre L, et al. Patient followup after radical prostatectomy by Internet medical file. Journal of Urology. 2003;170(6 Pt 1):2284-7. Not comparative treatments. [pmid: 14634397].
84 Cereceda LE, Flechon A, Droz JP. Management of vertebral metastases in prostate cancer: a retrospective analysis in 119 patients. Clinical Prostate Cancer. 2003;2(1):34-40. Not localized prostate cancer. [pmid: 15046682].
85 Cesaretti JA, Stone NN, Stock RG. Urinary symptom flare following I-125 prostate brachytherapy. International Journal of Radiation Oncology, Biology, Physics. 2003;56(4):1085-92. Not comparative treatments.
86 Chander S, Choo R, Danjoux C, Morton G, Pearse A, Deboer G, et al. Effect of androgen suppression on hemoglobin in prostate cancer patients undergoing salvage radiotherapy plus 2-year buserelin acetate for rising PSA after surgery. International Journal of Radiation Oncology, Biology, Physics. 2005;62(3):719-24. Less than 100 patients per study arm.
87 Chapple A, Ziebland S, Shepperd S, Miller R, Herxheimer A, McPherson A. Why men with prostate cancer want wider access to prostate specific antigen testing: qualitative study.[see comment]. BMJ. 2002;325(7367):737. Not comparative treatments. [pmid: 12364299].
88 Chaussy C, Thuroff S. Results and side effects of high-intensity focused ultrasound in localized prostate cancer. Journal of Endourology. 2001;15(4):437-40. discussion 47–8. No QOL outcomes. [pmid: 11394458].
89 Chaussy C, Thuroff S. The status of high-intensity focused ultrasound in the treatment of localized prostate cancer and the impact of a combined resection. Current Urology Reports. 2003;4(3):248-52. No QOL outcomes. [pmid: 12756090].
90 Cheli CD, Levine RL, Cambetas DR, Kolker JD, Roberts SB. Age-related reference ranges for complexed prostate-specific antigen and complexed/total prostate-specific antigen ratio: results from East Texas Medical Center Cancer Institute screening campaign. Urology. 2002;60(4 Suppl 1):53-9. Not comparative treatments. [pmid: 12384164].
91 Chiu BC, Anderson JR, Corbin D. Predictors of prostate cancer screening among health fair participants. Public Health. 2005;119(8):686-93. Not comparative treatments. [pmid: 15949522].
92 Choo R, Do V, Herschorn S, DeBoer G, Danjoux C, Morton G, et al. Urodynamic changes at 18 months post-therapy in patients treated with external beam radiotherapy for prostate carcinoma. International Journal of Radiation Oncology, Biology, Physics. 2002;53(2):290-6. Less than 100 patients per study arm.
93 Chrouser KL, Leibovich BC, Sweat SD, Larson DW, Davis BJ, Tran NV, et al. Urinary fistulas following external radiation or permanent brachytherapy for the treatment of prostate cancer. Journal of Urology. 2005;173(6):1953-7. No QOL outcomes. [pmid: 15879789].
94 Clark JA, Bokhour BG, Inui TS, Silliman RA, Talcott JA. Measuring patients' perceptions of the outcomes of treatment for early prostate cancer. Medical Care. 2003;41(8):923-36. Not localized prostate cancer. [pmid: 12886172].
95 Clark JA, Inui TS, Silliman RA, Bokhour BG, Krasnow SH, Robinson RA, et al. Patients' perceptions of quality of life after treatment for early prostate cancer. Journal of Clinical Oncology. 2003;21(20):3777-84. Not localized prostate cancer. [pmid: 14551296].
96 Clark JA, Talcott JA. Symptom indexes to assess outcomes of treatment for early prostate cancer. Medical Care. 2001;39(10):1118-30. Validation study. [pmid: 11567174].
97 Clark JA, Talcott JA. Confidence and uncertainty long after initial treatment for early prostate cancer: survivors' views of cancer control and the treatment decisions they made. Journal of Clinical Oncology. Sep 20. 2006;24(27):4457-63. Not comparative treatments. [pmid: 16983114].
98 Cliff AM, MacDonagh RP. Psychosocial morbidity in prostate cancer: I. Design of a new questionnaire. BJU International. 2000;86(7):829-33. Not comparative treatments. [pmid: 11069409].
99 Cohen JH, Schoenbach VJ, Kaufman JS, Talcott JA, Schenck AP, Peacock S, et al. Racial differences in clinical progression among Medicare recipients after treatment for localized prostate cancer (United States). Cancer Causes Control. Aug. 2006;17(6):803-11. No QOL outcomes. [pmid: 16783608].
100 Conde FA, Sarna L, Oka RK, Vredevoe DL, Rettig MB, Aronson WJ. Age, body mass index, and serum prostate-specific antigen correlate with bone loss in men with prostate cancer not receiving androgen deprivation therapy. Urology. 2004;64(2):335-40. No QOL outcomes. [pmid: 15302490].
101 Cooperberg MR, Koppie TM, Lubeck DP, Ye J, Grossfeld GD, Mehta SS, et al. How potent is potent? Evaluation of sexual function and bother in men who report potency after treatment for prostate cancer: data from CaPSURE. Urology. 2003;61(1):190-6. CaPSURE data. [pmid: 12559294].
102 Cooperberg MR, Lubeck DP, Meng MV, Mehta SS, Carroll PR. The changing face of low-risk prostate cancer: trends in clinical presentation and primary management. Journal of Clinical Oncology. 2004;22(11):2141-9. CaPSURE data. [pmid: 15169800].
103 Cormier L, Guillemin F, Valeri A, Fournier G, Cussenot O, Mangin P, et al. Impact of prostate cancer screening on health-related quality of life in at-risk families. Urology. 2002;59(6):901-6. Not comparative treatments. [pmid: 12031378].
104 Courneya KS, Segal RJ, Reid RD, Jones LW, Malone SC, Venner PM, et al. Three independent factors predicted adherence in a randomized controlled trial of resistance exercise training among prostate cancer survivors. Journal of Clinical Epidemiology. 2004;57(6):571-9. Not comparative treatments. [pmid: 15246125].
105 Crawford ED. Use of algorithms as determinants for individual patient decision making: national comprehensive cancer network versus artificial neural networks. Urology. 2003;62(6 Suppl 1):13-9. Not comparative treatments. [pmid: 14706504].
106 Crowe H, Costello AJ. Prostate cancer: perspectives on quality of life and impact of treatment on patients and their partners. Urologic Nursing. 2003;23(4):279-85. Not localized prostate cancer. [pmid: 14552074].
107 Dacal K, Sereika SM, Greenspan SL. Quality of life in prostate cancer patients taking androgen deprivation therapy. Journal of the American Geriatrics Society. 2006;54(1):85-90. Not localized prostate cancer. [pmid: 16420202].
108 Dahm P, Silverstein AD, Weizer AZ, Young MD, Vieweg J, Albala DM, et al. A longitudinal assessment of bowel related symptoms and fecal incontinence following radical perineal prostatectomy. Journal of Urology. 2003;169(6):2220-4. Not comparative treatments. [pmid: 12771754].
109 Dahn JR, Penedo FJ, Gonzalez JS, Esquiabro M, Antoni MH, Roos BA, et al. Sexual functioning and quality of life after prostate cancer treatment: considering sexual desire. Urology. 2004;63(2):273-7. Not localized prostate cancer. [pmid: 14972470].
110 Dahn JR, Penedo FJ, Molton I, Lopez L, Schneiderman N, Antoni MH. Physical activity and sexual functioning after radiotherapy for prostate cancer: beneficial effects for patients undergoing external beam radiotherapy. Urology. 2005;65(5):953-8. Not comparative treatments. [pmid: 15882730].
111 Dale W, Hemmerich J, Meltzer D. Extending the validity of the Memorial Anxiety Scale for Prostate Cancer (MAX-PC) at the time of prostate biopsy in a racially-mixed population. Psycho-Oncology. May. 2007;16(5):493-8. Not comparative treatments. [pmid: 17080494].
112 Dalkin BL, Christopher BA, Shawler D. Health related quality of life outcomes after radical prostatectomy: attention to study design and the patient-based importance of single-surgeon studies. Urologic Oncology. 2006;24(1):28-32. Not comparative treatments. [pmid: 16414489].
113 Dalkin BL, Wessells H, Cui H. A national survey of urinary and health related quality of life outcomes in men with an artificial urinary sphincter for post-radical prostatectomy incontinence. Journal of Urology. 2003;169(1):237-9. Not comparative treatments. [pmid: 12478144].
114 D'Amico A, Cormack R, Kumar S, Tempany CM. Real-time magnetic resonance imaging-guided brachytherapy in the treatment of selected patients with clinically localized prostate cancer. Journal of Endourology. 2000;14(4):367-70. Not comparative treatments. [pmid: 10910153].
115 Daubenmier JJ, Weidner G, Marlin R, Crutchfield L, Dunn-Emke S, Chi C, et al. Lifestyle and health-related quality of life of men with prostate cancer managed with active surveillance. Urology. 2006;67(1):125-30. Not comparative treatments. [pmid: 16413347].
116 Davis JW, Kuban DA, Lynch DF, Schellhammer PF. Quality of life after treatment for localized prostate cancer: differences based on treatment modality.[see comment]. Journal of Urology. 2001;166(3):947-52. Not prospective or longitudinal survey study. [pmid: 11490252].
117 Davison BJ, Goldenberg SL. Decisional regret and quality of life after participating in medical decision-making for early-stage prostate cancer. BJU International. 2003;91(1):14-7. Less than 100 patients per study arm. [pmid: 12614242].
118 Davison BJ, Parker PA, Goldenberg SL. Patients' preferences for communicating a prostate cancer diagnosis and participating in medical decision-making. BJU International. 2004;93(1):47-51. Less than 100 patients per study arm. [pmid: 14678366].
119 Deimling GT, Bowman KF, Sterns S, Wagner LJ, Kahana B. Cancer-related health worries and psychological distress among older adult, long-term cancer survivors. Psycho-Oncology. Apr. 2006;15(4):306-20. Not comparative treatments. [pmid: 16041841].
120 Deimling GT, Sterns S, Bowman KF, Kahana B. The health of older-adult, long-term cancer survivors. Cancer Nursing. 2005;28(6):415-24. Not comparative treatments. [pmid: 16330962].
121 Deinsberger R, Regatschnig R, Kaiser B, Bankl HC. Spinal leptomeningeal metastases from prostate cancer. J Neurooncol. Feb. 2006;76(3):293-7. Not comparative treatments. [pmid: 16151594].
122 Deinsberger R, Regatschnig R, Kaiser B, Bankl HC. Spinal leptomeningeal metastases from prostate cancer. Acta Neurochir (Wien). Apr. 2006;148(4):467-71. Not comparative treatments. [pmid: 16322903].
123 Deliveliotis C, Liakouras C, Delis A, Skolarikos A, Varkarakis J, Protogerou V. Prostate operations: long-term effects on sexual and urinary function and quality of life. Comparison with an age-matched control population. Urological Research. 2004;32(4):283-9. Not comparative treatments. [pmid: 15057494].
124 Demark-Wahnefried W, Clipp EC, McBride C, Lobach DF, Lipkus I, Peterson B, et al. Design of FRESH START: a randomized trial of exercise and diet among cancer survivors. Medicine & Science in Sports & Exercise. 2003;35(3):415-24. Not comparative treatments. [pmid: 12618570].
125 Demark-Wahnefried W, Clipp EC, Morey MC, Pieper CF, Sloane R, Snyder DC, et al. Lifestyle intervention development study to improve physical function in older adults with cancer: outcomes from Project LEAD. Journal of Clinical Oncology. Jul 20. 2006;24(21):3465-73. Not comparative treatments. [pmid: 16849763].
126 Demark-Wahnefried W, Morey MC, Clipp EC, Pieper CF, Snyder DC, Sloane R, et al. Leading the Way in Exercise and Diet (Project LEAD): intervening to improve function among older breast and prostate cancer survivors. Controlled Clinical Trials. 2003;24(2):206-23. Not comparative treatments. [pmid: 12689742].
127 Demark-Wahnefried W, Peterson B, McBride C, Lipkus I, Clipp E. Current health behaviors and readiness to pursue life-style changes among men and women diagnosed with early stage prostate and breast carcinomas. Cancer. 2000;88(3):674-84. Not comparative treatments. [pmid: 10649263].
128 Denis L. Europa uomo. BJU International. Jun. 2007;99(6):1329-30. Not comparative treatments. [pmid: 17419704].
129 Denis LJ. Europa Uomo: The European Prostate Cancer Coalition. Archivio Italiano di Urologia, Andrologia. Dec. 2006;78(4):157-60. Not comparative treatments.
130 Derby CA, Mohr BA, Goldstein I, Feldman HA, Johannes CB, McKinlay JB. Modifiable risk factors and erectile dysfunction: can lifestyle changes modify risk?. Urology. 2000;56(2):302-6. Not localized prostate cancer. [pmid: 10925098].
131 Descazeaud A, Zerbib M, Hofer MD, Chaskalovic J, Debre B, Peyromaure M. Evolution of health-related quality of life two to seven years after retropubic radical prostatectomy: evaluation by UCLA prostate cancer index. World Journal of Urology. 2005;23(4):257-62. Not comparative treatments. [pmid: 16136358].
132 Diefenbach MA, Hamrick N, Uzzo R, Pollack A, Horwitz E, Greenberg R, et al. Clinical, demographic and psychosocial correlates of complementary and alternative medicine use by men diagnosed with localized prostate cancer. Journal of Urology. 2003;170(1):166-9. Not comparative treatments. [pmid: 12796672].
133 Djozic J. The nerve sparing radical prostatectomy—a step to better quality of life-surgical aspects. Acta Chirurgica Iugoslavica. 2005;52(4):63-7. Not comparative treatments. [pmid: 16673598].
134 Do V, Choo R, Deboer G, Herschorn S, Danjoux C, Chen CH, et al. Urodynamic findings 3 months after radiotherapy in patients treated with conformal external beam radiotherapy for prostate carcinoma.[see comment]. BJU International. 2002;90(1):62-7. Not comparative treatments. [pmid: 12081772].
135 Docherty A, Brothwell CPD, Symons M. The impact of inadequate knowledge on patient and spouse experience of prostate cancer. Cancer Nursing. Jan–Feb. 2007;30(1):58-63. Less than 100 patients per study arm. [pmid: 17235222].
136 Donnelly BJ, Saliken JC, Ernst DS, Ali-Ridha N, Brasher PM, Robinson JW, et al. Prospective trial of cryosurgical ablation of the prostate: five-year results. Urology. 2002;60(4):645-9. Not comparative treatments. [pmid: 12385926].
137 Downs TM, Sadetsky N, Pasta DJ, Grossfeld GD, Kane CJ, Mehta SS, et al. Health related quality of life patterns in patients treated with interstitial prostate brachytherapy for localized prostate cancer—data from CaPSURE.[see comment]. Journal of Urology. 2003;170(5):1822-7. CaPSURE data. [pmid: 14532784].
138 Dunsmuir WD, McFarlane JP, Tan A, Dowling C, Downie J, Kourambas J, et al. Gyrus bipolar electrovaporization vs transurethral resection of the prostate: a randomized prospective single-blind trial with 1 y follow-up. Prostate Cancer & Prostatic Diseases. 2003;6(2):182-6. Not localized prostate cancer. [pmid: 12806380].
139 Durham J, Low M, McLeod D. Screening for prostate cancer: a survey of New Zealand general practitioners.[see comment]. New Zealand Medical Journal. 2003;116(1176):U476. Not comparative treatments. [pmid: 12835804].
140 Eastham JA, Kelly WK, Grossfeld GD, Small EJ. Cancer and Leukemia Group B. Cancer and Leukemia Group B (CALGB) 90203: a randomized phase 3 study of radical prostatectomy alone versus estramustine and docetaxel before radical prostatectomy for patients with high-risk localized disease. Urology. 2003;62(Suppl 1):55-62. No QOL outcomes. [pmid: 14747042].
141 Egawa S, Shimura S, Irie A, Kitano M, Nishiguchi I, Kuwao S, et al. Toxicity and health-related quality of life during and after high dose rate brachytherapy followed by external beam radiotherapy for prostate cancer. Japanese Journal of Clinical Oncology. 2001;31(11):541-7. Less than 100 patients per study arm. [pmid: 11773262].
142 Eggener SE, Stern JA, Jain PM, Oram S, Ai J, Cai X, et al. Enhancement of intermittent androgen ablation by “off-cycle” maintenance with finasteride in LNCaP prostate cancer xenograft model. Prostate. 2006;66(5):495-502. Not human study. [pmid: 16372330].
143 Elkin EB, Cowen ME, Cahill D, Steffel M, Kattan MW. Preference assessment method affects decision-analytic recommendations: a prostate cancer treatment example.[see comment]. Medical Decision Making. 2004;24(5):504-10. No QOL outcomes. [pmid: 15358999].
144 Eller LS, Lev EL, Gejerman G, Colella J, Esposito M, Lanteri V, et al. Prospective study of quality of life of patients receiving treatment for prostate cancer. Nursing Research. 2006;55(2 Suppl):S28-36. Less than 1 year duration or follow-up. [pmid: 16601630].
145 Ellerby JH, McKenzie J, McKay S, Gariepy GJ, Kaufert JM. Bioethics for clinicians: 18. Aboriginal cultures.[see comment]. CMAJ Canadian Medical Association Journal. 2000;163(7):845-50. Not localized prostate cancer. [pmid: 11033715].
146 Elstein AS, Chapman GB, Chmiel JS, Knight SJ, Chan C, Nadler RB, et al. Agreement between prostate cancer patients and their clinicians about utilities and attribute importance. Health Expectations. 2004;7(2):115-25. No QOL outcomes. [pmid: 15117386].
147 Elstein AS, Chapman GB, Knight SJ. Patients' values and clinical substituted judgments: the case of localized prostate cancer. Health Psychology. 2005;24(4 Suppl):S85-92. No QOL outcomes. [pmid: 16045424].
148 Enger SM, Van den Eeden SK, Sternfeld B, Loo RK, Quesenberry CP Jr, Rowell S, et al. California Men's Health Study (CMHS): a multiethnic cohort in a managed care setting. BMC Public Health. 2006;6:172. Not comparative treatments. [pmid: 16813653].
149 Ernst DS, Tannock IF, Winquist EW, Venner PM, Reyno L, Moore MJ, et al. Randomized, double-blind, controlled trial of mitoxantrone/prednisone and clodronate versus mitoxantrone/prednisone and placebo in patients with hormone-refractory prostate cancer and pain. Journal of Clinical Oncology. 2003;21(17):3335-42. Not localized prostate cancer. [pmid: 12947070].
150 Eskicorapci SY, Karabulut E, Turkeri L, Baltaci S, Cal C, Toktas G, et al. Validation of 2001 Partin tables in Turkey: a multicenter study. European Urology. 2005;47(2):185-9. No QOL outcomes. [pmid: 15661412].
151 Eton DT, Lai JS, Cella D, Reeve BB, Talcott JA, Clark JA, et al. Data pooling and analysis to build a preliminary item bank: an example using bowel function in prostate cancer. Evaluation & the Health Professions. 2005;28(2):142-59. No QOL outcomes. [pmid: 15851770].
152 Eton DT, Lepore SJ, Helgeson VS. Early quality of life in patients with localized prostate carcinoma: an examination of treatment-related, demographic, and psychosocial factors. Cancer. 2001;92(6):1451-9. Less than 1 year duration or follow-up. [pmid: 11745222].
153 Eton DT, Lepore SJ, Helgeson VS. Psychological distress in spouses of men treated for early-stage prostate carcinoma. Cancer. 2005;103(11):2412-8. Not comparative treatments. [pmid: 15858824].
154 Evans BR, Peterson BL, Demark-Wahnefried W. No difference in response rate to a mailed survey among prostate cancer survivors using conditional versus unconditional incentives. Cancer Epidemiology, Biomarkers & Prevention. 2004;13(2):277-8. No QOL outcomes.
155 Faithfull S, Corner J, Meyer L, Huddart R, Dearnaley D. Evaluation of nurse-led follow up for patients undergoing pelvic radiotherapy. British Journal of Cancer. 2001;85(12):1853-64. Not comparative treatments. [pmid: 11747326].
156 Falsaperla M, Morgia G, Tartarone A, Ardito R, Romano G. Support ellagic acid therapy in patients with hormone refractory prostate cancer (HRPC) on standard chemotherapy using vinorelbine and estramustine phosphate. European Urology. 2005;47(4):449-54. discussion 54–5. Not localized prostate cancer. [pmid: 15774240].
157 Fearing A, Bell D, Newton M, Lambert S. Prostate screening health beliefs and practices of African American men. ABNF Journal. 2000;11(6):141-4. Not comparative treatments. [pmid: 11760286].
158 Feigenberg SJ, Lee WR, Desilvio ML, Winter K, Pisansky TM, Bruner DW, et al. Health-related quality of life in men receiving prostate brachytherapy on RTOG 98-05. International Journal of Radiation Oncology, Biology, Physics. 2005;62(4):956-64. Not comparative treatments.
159 Feneley MR, Brewster S. Opportunities and outcomes in early prostate cancer: a commentary on policy, patient perspectives, trials and strategies. BJU International. 2003;91(3):177-8. Review article. [pmid: 12580998].
160 Ferrero JM, Chamorey E, Oudard S, Dides S, Lesbats G, Cavaglione G, et al. Phase II trial evaluating a docetaxel-capecitabine combination as treatment for hormone-refractory prostate cancer. Cancer. Aug 15. 2006;107(4):738-45. Not comparative treatments. [pmid: 16826591].
161 Ficarra V, Novara G, Galfano A, Stringari C, Baldassarre R, Cavalleri S, et al. Twelve-month self-reported quality of life after retropubic radical prostatectomy: a prospective study with Rand 36-Item Health Survey (Short Form-36). BJU International. 2006;97(2):274-8. Not comparative treatments. [pmid: 16430628].
162 Ficarra V, Righetti R, D'Amico A, Pilloni S, Balzarro M, Schiavone D, et al. General state of health and psychological well-being in patients after surgery for urological malignant neoplasms. Urologia Internationalis. 2000;65(3):130-4. Less than 100 patients per study arm. [pmid: 11054029].
163 Fillion L, Gelinas C, Simard S, Savard J, Gagnon P. Validation evidence for the French Canadian adaptation of the Multidimensional Fatigue Inventory as a measure of cancer-related fatigue. Cancer Nursing. 2003;26(2):143-54. Validation study. [pmid: 12660563].
164 Filocamo MT, Li Marzi V, Del Popolo G, Cecconi F, Villari D, Marzocco M, et al. Pharmacologic treatment in postprostatectomy stress urinary incontinence. European Urology. Jun. 2007;51(6):1559-64. Less than 100 patients per study arm. [pmid: 16942833].
165 Finne P, Stenman UH, Maattanen L, Makinen T, Tammela TL, Martikainen P, et al. The Finnish trial of prostate cancer screening: where are we now?. BJU International. 2003;92(Suppl 2):22-6. Not comparative treatments. [pmid: 14983949].
166 Finney G, Haynes AM, Cross P, Brenner P, Boyn A, Stricker P. Cross-sectional analysis of sexual function after prostate brachytherapy. Urology. 2005;66(2):377-81. Not comparative treatments. [pmid: 16098365].
167 Fisher M. The endothelin-1 antagonist, atrasentan, improves time to progression and quality of life in hormone-refractory prostate cancer. Clinical Prostate Cancer. 2002;1(2):79-80. Not localized prostate cancer. [pmid: 15046697].
168 Fleshner N, Dranitsaris G, Finelli A, Tsihlias J, Bell D, Gleave M, et al. Surgical wait times for patients with urological cancers: a survey of Canadian surgeons. Canadian Journal of Urology. Jun. 2006;13(Suppl 3):3-13. Not comparative treatments. [pmid: 16818006].
169 Fossa SD, Slee PH, Brausi M, Horenblas S, Hall RR, Hetherington JW, et al. Flutamide versus prednisone in patients with prostate cancer symptomatically progressing after androgen-ablative therapy: a phase III study of the European organization for research and treatment of cancer genitourinary group. Journal of Clinical Oncology. 2001;19(1):62-71. Not localized prostate cancer. [pmid: 11134196].
170 Fowler FJ Jr, McNaughton Collins M, Walker Corkery E, Elliott DB, Barry MJ. The impact of androgen deprivation on quality of life after radical prostatectomy for prostate carcinoma.[see comment]. Cancer. 2002;95(2):287-95. Not prospective or longitudinal survey study. [pmid: 12124828].
171 Fowler JE Jr, Viadur Study G. Patient-reported experience with the Viadur 12-month leuprolide implant for prostate cancer. Urology. 2001;58(3):430-4. Not comparative treatments. [pmid: 11549494].
172 Frank SJ, Pisters LL, Davis J, Lee AK, Bassett R, Kuban DA. An assessment of quality of life following radical prostatectomy, high dose external beam radiation therapy and brachytherapy iodine implantation as monotherapies for localized prostate cancer. Journal of Urology. Jun. 2007;177(6):2151-6. discussion 6. Not prospective or longitudinal survey study or RCT. [pmid: 17509305].
173 Fransson P. Recall of pretreatment symptoms among men treated with radiotherapy for prostate cancer. Acta Oncologica. 2005;44(4):355-61. Not comparative treatments. [pmid: 16120544].
174 Fransson P, Tavelin B, Widmark A. Reliability and responsiveness of a prostate cancer questionnaire for radiotherapy-induced side effects. Supportive Care in Cancer. 2001;9(3):187-98. Less than 100 patients per study arm. [pmid: 11401103].
175 Freedland SJ, Haffner MC, Landis PK, Saigal CS, Carter HB. Obesity does not adversely affect health-related quality-of-life outcomes after anatomic retropubic radical prostatectomy. Urology. 2005;65(6):1131-6. Not comparative treatments. [pmid: 15913722].
176 Froehner M, Koch R, Litz R, Oehlschlaeger S, Wirth MP. Which conditions contributing to the Charlson score predict survival after radical prostatectomy?. Journal of Urology. 2004;171(2 Pt 1):697-9. No QOL outcomes. [pmid: 14713789].
177 Froehner M, Litz R, Manseck A, Hakenberg OW, Leike S, Albrecht DM, et al. Relationship of comorbidity, age and perioperative complications in patients undergoing radical prostatectomy. Urologia Internationalis. 2001;67(4):283-8. No QOL outcomes. [pmid: 11741129].
178 Gacci M, Livi L, Paiar F, Detti B, Litwin MS, Bartoletti R, et al. Quality of life after radical treatment of prostate cancer: validation of the Italian version of the University of California-Los Angeles Prostate Cancer Index. Urology. 2005;66(2):338-43. Not localized prostate cancer. [pmid: 16098363].
179 Galalae RM, Loch T, Riemer B, Rzehak P, Kuchler T, Kimmig B, et al. Health-related quality of life measurement in long-term survivors and outcome following radical radiotherapy for localized prostate cancer. Strahlentherapie und Onkologie. 2004;180(9):582-9. Not comparative treatments. [pmid: 15378189].
180 Galbraith ME, Arechiga A, Ramirez J, Pedro LW. Prostate cancer survivors' and partners' selfreports of health-related quality of life, treatment symptoms, and marital satisfaction 2.5–5.5 years after treatment. Oncology Nursing Forum 2005;Online. 32(2):E30–41. Previously published data
181 Gall TL. The role of religious coping in adjustment to prostate cancer. Cancer Nursing. 2004;27(6):454-61. Not comparative treatments. [pmid: 15632786].
182 Gall TL. Relationship with God and the quality of life of prostate cancer survivors. Quality of Life Research. 2004;13(8):1357-68. Not comparative treatments. [pmid: 15503831].
183 Gaston KE, Kouba E, Moore DT, Pruthi RS. The use of erythropoietin in patients undergoing radical prostatectomy: effects on hematocrit, transfusion rates and quality of life. Urologia Internationalis. 2006;77(3):211-5. Less than 100 patients per study arm. [pmid: 17033207].
184 Gattellari M, Ward JE. Will men attribute fault to their GP for adverse effects arising from controversial screening tests? An Australian study using scenarios about PSA screening. Journal of Medical Screening. 2004;11(4):165-9. Not comparative treatments. [pmid: 15563771].
185 Geinitz H, Zimmermann FB, Thamm R, Erber C, Muller T, Keller M, et al. Late rectal symptoms and quality of life after conformal radiation therapy for prostate cancer. Radiotherapy & Oncology. Jun. 2006;79(3):341-7. Not comparative treatments. [pmid: 16733072].
186 Ghavamian R, Zincke H. Technique for nerve dissection. Seminars in Urologic Oncology. 2000;18(1):43-5. Not comparative treatments. [pmid: 10719930].
187 Giard N, Lichtenstein P, Yashin AI. A multistate model for the genetic analysis of the ageing process. Statistics in Medicine. 2002;21(17):2511-26. Not comparative treatments. [pmid: 12205696].
188 Giesler RB, Given B, Given CW, Rawl S, Monahan P, Burns D, et al. Improving the quality of life of patients with prostate carcinoma: a randomized trial testing the efficacy of a nurse-driven intervention. Cancer. 2005;104(4):752-62. Not comparative treatments. [pmid: 15986401].
189 Giesler RB, Miles BJ, Cowen ME, Kattan MW. Assessing quality of life in men with clinically localized prostate cancer: development of a new instrument for use in multiple settings. Quality of Life Research. 2000;9(6):645-65. Validation study. [pmid: 11236855].
190 Gilling PJ, Kennett KM, Fraundorfer MR. Holmium laser resection v transurethral resection of the prostate: results of a randomized trial with 2 years of follow-up. Journal of Endourology. 2000;14(9):757-60. Not localized prostate cancer. [pmid: 11110572].
191 Given B, Given C, Azzouz F, Stommel M. Physical functioning of elderly cancer patients prior to diagnosis and following initial treatment. Nursing Research. 2001;50(4):222-32. Not localized prostate cancer. [pmid: 11480531].
192 Goeman L, Salomon L, La De Taille A, Vordos D, Hoznek A, Yiou R, et al. Long-term functional and oncological results after retroperitoneal laparoscopic prostatectomy according to a prospective evaluation of 550 patients. World Journal of Urology. Aug. 2006;24(3):281-8. Not comparative treatments. [pmid: 16508788].
193 Gohagan JK, Prorok PC, Hayes RB, Kramer BS, Prostate LCaOCSTPT. The Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial of the National Cancer Institute: history, organization, and status. Controlled Clinical Trials 2000;21(6 Suppl):251S–72S. Not comparative treatments
194 Gomella LG, Albertsen PC, Benson MC, Forman JD, Soloway MS. The use of video-based patient education for shared decision-making in the treatment of prostate cancer. Seminars in Urologic Oncology. 2000;18(3):182-7. No QOL outcomes. [pmid: 10975489].
195 Gomha MA, Boone TB. Artificial urinary sphincter for post-prostatectomy incontinence in men who had prior radiotherapy: a risk and outcome analysis.[see comment]. Journal of Urology. 2002;167(2 Pt 1):591-6. No QOL outcomes. [pmid: 11792924].
196 Gore JL, Krupski T, Kwan L, Fink A, Litwin MS. Mental health of low income uninsured men with prostate cancer. Journal of Urology. 2005;173(4):1323-6. Not comparative treatments. [pmid: 15758790].
197 Gore JL, Krupski T, Kwan L, Maliski S, Litwin MS. Partnership status influences quality of life in low-income, uninsured men with prostate cancer. Cancer. 2005;104(1):191-8. Not comparative treatments. [pmid: 15912494].
198 Gore JL, Penson DF, Litwin MS. Discussing quality-of-life issues with a patient newly diagnosed with prostate cancer. Nat Clin Pract Urol. Aug. 2006;3(8):449-52. Not comparative treatments. [pmid: 16902521].
199 Gotay CC. Quality of life research in Hawaii's cancer survivors. Hawaii Medical Journal. 2001;60(7):189. Not localized prostate cancer. [pmid: 11496533].
200 Gotay CC, Holup JL, Pagano I. Ethnic differences in quality of life among early breast and prostate cancer survivors.[see comment]. Psycho-Oncology. 2002;11(2):103-13. Not localized prostate cancer. [pmid: 11921326].
201 Gralla O, Haas F, Knoll N, Hadzidiakos D, Tullmann M, Romer A, et al. Fast-track surgery in laparoscopic radical prostatectomy: basic principles. World Journal of Urology. Apr. 2007;25(2):185-91. Less than 100 patients per study arm. [pmid: 17171563].
202 Gralnek D, Wessells H, Cui H, Dalkin BL. Differences in sexual function and quality of life after nerve sparing and nonnerve sparing radical retropubic prostatectomy. Journal of Urology. 2000;163(4):1166-9. discussion 9–70. Not prospective or longitudinal survey study. [pmid: 10737488].
203 Gray RE, Wassersug RJ, Sinding C, Barbara AM, Trosztmer C, Fleshner N. The experiences of men receiving androgen deprivation treatment for prostate cancer: a qualitative study. Canadian Journal of Urology. 2005;12(4):2755-63. Less than 100 patients per study arm. [pmid: 16197599].
204 Green HJ, Pakenham KI, Headley BC, Gardiner RA. Coping and health-related quality of life in men with prostate cancer randomly assigned to hormonal medication or close monitoring. Psycho-Oncology. 2002;11(5):401-14. Not localized prostate cancer. [pmid: 12228873].
205 Green HJ, Pakenham KI, Headley BC, Yaxley J, Nicol DL, Mactaggart PN, et al. Quality of life compared during pharmacological treatments and clinical monitoring for non-localized prostate cancer: a randomized controlled trial.[see comment]. BJU International. 2004;93(7):975-9. Less than 100 patients per study arm. [pmid: 15142146].
206 Greene KL, Cowan JE, Cooperberg MR, Meng MV, DuChane J, Carroll PR, et al. Who is the average patient presenting with prostate cancer?. Urology. 2005;66(5 Suppl):76-82. CaPSURE data. [pmid: 16194711].
207 Grein U, Meyer WW. Local recurrent cancer after radical prostatectomy and incontinence. Is the artificial urinary sphincter a useful therapeutic option?. Urologia Internationalis. 2001;66(1):9-12. Not comparative treatments. [pmid: 11150943].
208 Gudbergsson SB, Fossa SD, Borgeraas E, Dahl AA. A comparative study of living conditions in cancer patients who have returned to work after curative treatment. Supportive Care in Cancer. Oct. 2006;14(10):1020-9. Not comparative treatments. [pmid: 16572315].
209 Guirguis-Blake J. Screening for prostate cancer. Am Fam Physician. Feb 1. 2007;75(3):336-7. Not comparative treatments. [pmid: 17304863].
210 Gwede CK, Pow-Sang J, Seigne J, Heysek R, Helal M, Shade K, et al. Treatment decision-making strategies and influences in patients with localized prostate carcinoma. Cancer. 2005;104(7):1381-90. No QOL outcomes. [pmid: 16080181].
211 Hack TF, Pickles T, Bultz BD, Ruether JD, Degner LF. Impact of providing audiotapes of primary treatment consultations to men with prostate cancer: a multi-site, randomized, controlled trial. Psycho-Oncology. Jun. 2007;16(6):543-52. Not comparative treatments. [pmid: 16991107].
212 Hallberg O. Adverse health indicators correlating with sparsely populated areas in Sweden. Eur J Cancer Prev. Feb. 2007;16(1):71-6. Not comparative treatments. [pmid: 17220707].
213 Hammadeh MY, Madaan S, Hines J, Philp T. 5-year outcome of a prospective randomized trial to compare transurethral electrovaporization of the prostate and standard transurethral resection. Urology. 2003;61(6):1166-71. Not localized prostate cancer. [pmid: 12809891].
214 Hamrick N, Diefenbach MA. Religion and spirituality among patients with localized prostate cancer. Palliat Support Care. Dec. 2006;4(4):345-55. Not comparative treatments. [pmid: 17133894].
215 Hara I, Kawabata G, Miyake H, Nakamura I, Hara S, Okada H, et al. Comparison of quality of life following laparoscopic and open prostatectomy for prostate cancer. Journal of Urology. 2003;169(6):2045-8. Not localized prostate cancer. [pmid: 12771715].
216 Harden J, Schafenacker A, Northouse L, Mood D, Smith D, Pienta K, et al. Couples' experiences with prostate cancer: focus group research. Oncology Nursing Forum 2002;Online. 29(4):701–9. Less than 100 patients per study arm
217 Harden JK, Northouse LL, Mood DW. Qualitative analysis of couples' experience with prostate cancer by age cohort. Cancer Nursing. Sep–Oct. 2006;29(5):367-77. Not comparative treatments. [pmid: 17006110].
218 Harrod HL. A piece of my mind. An essay on desire. JAMA. 2003;289(7):813-4. Review article. [pmid: 12588245].
219 Hashine K, Azuma K, Koizumi T, Sumiyoshi Y. Health-related quality of life and treatment outcomes for men with prostate cancer treated by combined external-beam radiotherapy and hormone therapy. International Journal of Clinical Oncology. 2005;10(1):45-50. Not comparative treatments. [pmid: 15729601].
220 Hedestig O, Sandman PO, Tomic R, Widmark A. Living after radical prostatectomy for localized prostate cancer: a qualitative analysis of patient narratives. Acta Oncologica. 2005;44(7):679-86. Less than 100 patients per study arm. [pmid: 16227157].
221 Hedestig O, Sandman PO, Tomic R, Widmark A. Living after external beam radiotherapy of localized prostate cancer: a qualitative analysis of patient narratives. Cancer Nursing. 2005;28(4):310-7. Less than 100 patients per study arm. [pmid: 16046895].
222 Hedestig O, Sandman PO, Widmark A. Living with untreated localized prostate cancer: a qualitative analysis of patient narratives.[see comment]. Cancer Nursing. 2003;26(1):55-60. Less than 100 patients per study arm. [pmid: 12556713].
223 Heidenreich A, Sommer F, Ohlmann CH, Schrader AJ, Olbert P, Goecke J, et al. Prospective randomized Phase II trial of pegylated doxorubicin in the management of symptomatic hormone-refractory prostate carcinoma. Cancer. 2004;101(5):948-56. Not localized prostate cancer. [pmid: 15329902].
224 Helgeson VS, Lepore SJ, Eton DT. Moderators of the benefits of psychoeducational interventions for men with prostate cancer. Health Psychology. May. 2006;25(3):348-54. Not comparative treatments. [pmid: 16719606].
225 Hellerstedt B, Pienta KJ, Redman BG, Esper P, Dunn R, Fardig J, et al. Phase II trial of oral cyclophosphamide, prednisone, and diethylstilbestrol for androgen-independent prostate carcinoma. Cancer. 2003;98(8):1603-10. Not localized prostate cancer. [pmid: 14534875].
226 Henderson A, Andreyev HJN, Stephens R, Dearnaley D. Patient and physician reporting of symptoms and health-related quality of life in trials of treatment for early prostate cancer: considerations for future studies. Clin Oncol (R Coll Radiol). Dec. 2006;18(10):735-43. Review article. [pmid: 17168208].
227 Hervouet S, Savard J, Simard S, Ivers H, Laverdiere J, Vigneault E, et al. Psychological functioning associated with prostate cancer: cross-sectional comparison of patients treated with radiotherapy, brachytherapy, or surgery. Journal of Pain & Symptom Management. 2005;30(5):474-84. Not localized prostate cancer. [pmid: 16310621].
228 Hildenbrand B, Sauer B, Kalis O, Stoll C, Freudenberg MA, Niedermann G, et al. Immunotherapy of patients with hormone-refractory prostate carcinoma pre-treated with interferon-gamma and vaccinated with autologous PSA-peptide loaded dendritic cells—a pilot study. Prostate. Apr 1. 2007;67(5):500-8. Not localized prostate cancer. [pmid: 17262804].
229 Hindley RG, Mostafid AH, Brierly RD, Harrison NW, Thomas PJ, Fletcher MS. The 2-year symptomatic and urodynamic results of a prospective randomized trial of interstitial radiofrequency therapy vs transurethral resection of the prostate. BJU International. 2001;88(3):217-20. Not localized prostate cancer. [pmid: 11488732].
230 Hoffman RM, Gilliland FD, Penson DF, Stone SN, Hunt WC, Potosky AL. Cross-sectional and longitudinal comparisons of health-related quality of life between patients with prostate carcinoma and matched controls. Cancer. 2004;101(9):2011-9. Previously published data. [pmid: 15452835].
231 Hollenbeck BK, Dunn RL, Wei JT, McLaughlin PW, Han M, Sanda MG. Neoadjuvant hormonal therapy and older age are associated with adverse sexual health-related quality-of-life outcome after prostate brachytherapy. Urology. 2002;59(4):480-4. Not comparative treatments. [pmid: 11927294].
232 Hollenbeck BK, Dunn RL, Wei JT, Montie JE, Sanda MG. Determinants of long-term sexual health outcome after radical prostatectomy measured by a validated instrument. Journal of Urology. 2003;169(4):1453-7. Not comparative treatments. [pmid: 12629382].
233 Hollenbeck BK, Wei JT, Sanda MG, Dunn RL, Sandler HM. Neoadjuvant hormonal therapy impairs sexual outcome among younger men who undergo external beam radiotherapy for localized prostate cancer. Urology. 2004;63(5):946-50. Not comparative treatments. [pmid: 15134986].
234 Holmes-Rovner M, Stableford S, Fagerlin A, Wei JT, Dunn RL, Ohene-Frempong J, et al. Evidence-based patient choice: a prostate cancer decision aid in plain language. BMC Medical Informatics & Decision Making. 2005;5(1):16. No QOL outcomes. [pmid: 15963238].
235 Hon NHY, Brathwaite D, Hussain Z, Ghiblawi S, Brace H, Hayne D, et al. A prospective, randomized trial comparing conventional transurethral prostate resection with PlasmaKinetic vaporization of the prostate: physiological changes, early complications and long-term followup. Journal of Urology. Jul. 2006;176(1):205-9. Less than 100 patients per study arm. [pmid: 16753403].
236 Hong JH, Jeon SS, Lee HM, Choi YH, Kim S, Choi HY. The Functional Assessment of Cancer Therapy-Prostate (FACT-P) scales in men with prostate cancer: reliability and validity of the Korean version. J Korean Med Sci. Apr. 2006;21(2):295-9. Not comparative treatments. [pmid: 16614517].
237 Hoyle DW. Confronting prostate cancer: a personal reflection. N C Med J. Mar–Apr. 2006;67(2):128-9. Not prospective or longitudinal survey study or RCT. [pmid: 16752716].
238 Hsu EI, Hong EK, Lepor H. Influence of body weight and prostate volume on intraoperative, perioperative, and postoperative outcomes after radical retropubic prostatectomy. Urology. 2003;61(3):601-6. Not comparative treatments. [pmid: 12639655].
239 Hu JC, Elkin EP, Krupski TL, Gore J, Litwin MS. The effect of postprostatectomy external beam radiotherapy on quality of life: results from the Cancer of the Prostate Strategic Urologic Research Endeavor. Cancer. Jul 15. 2006;107(2):281-8. CaPSURE data. [pmid: 16779794].
240 Hu JC, Elkin EP, Pasta DJ, Lubeck DP, Kattan MW, Carroll PR, et al. Predicting quality of life after radical prostatectomy: results from CaPSURE.[see comment]. Journal of Urology. 2004;171(2 Pt 1):703-7. discussion 7–8. CaPSURE data. [pmid: 14713791].
241 Hu JC, Kwan L, Saigal CS, Litwin MS. Regret in men treated for localized prostate cancer. Journal of Urology. 2003;169(6):2279-83. Not comparative treatments. [pmid: 12771770].
242 Hughes Halbert C, Weathers B, Delmoor E. Developing an academic-community partnership for research in prostate cancer. Journal of Cancer Education. 2006;21(2):99-103. No QOL outcomes. [pmid: 17020523].
243 Hunt-Shanks TT, Blanchard CM, Baker F, Hann D, Roberts CS, McDonald J, et al. Exercise use as complementary therapy among breast and prostate cancer survivors receiving active treatment: examination of exercise intention. Integrative Cancer Therapies. Jun. 2006;5(2):109-16. Not comparative treatments. [pmid: 16685075].
244 Hurwitz MD, Cormack R, Tempany CM, Kumar S, D'Amico AV. Three-dimensional real-time magnetic resonance-guided interstitial prostate brachytherapy optimizes radiation dose distribution resulting in a favorable acute side effect profile in patients with clinically localized prostate cancer. Techniques in Urology. 2000;6(2):89-94. Not comparative treatments. [pmid: 10798806].
245 Ishihara M, Suzuki H, Akakura K, Komiya A, Imamoto T, Tobe T, et al. Baseline health-related quality of life in the management of prostate cancer. International Journal of Urology. Jul. 2006;13(7):920-5. Not comparative treatments. [pmid: 16882056].
246 Jacobsen NEB, Moore KN, Estey E, Voaklander D. Open versus laparoscopic radical prostatectomy: a prospective comparison of postoperative urinary incontinence rates. Journal of Urology. Feb. 2007;177(2):615-9. Not prospective or longitudinal survey study or RCT. [pmid: 17222646].
247 Jakobsson L. Indwelling catheter treatment and health-related quality of life in men with prostate cancer in comparison with men with benign prostatic hyperplasia. Scandinavian Journal of Caring Sciences. 2002;16(3):264-71. Not comparative treatments. [pmid: 12191038].
248 Jakobsson L, Hallberg IR, Loven L. Experiences of micturition problems, indwelling catheter treatment and sexual life consequences in men with prostate cancer. Journal of Advanced Nursing. 2000;31(1):59-67. Not comparative treatments. [pmid: 10632794].
249 Jakobsson L, Loven L, Hallberg IR. Micturition problems in relation to quality of life in men with prostate cancer or benign prostatic hyperplasia: comparison with men from the general population. Cancer Nursing. 2004;27(3):218-29. Not comparative treatments. [pmid: 15238809].
250 Janda M, Gerstner N, Obermair A, Fuerst A, Wachter S, Dieckmann K, et al. Quality of life changes during conformal radiation therapy for prostate carcinoma. Cancer. 2000;89(6):1322-8. Not localized prostate cancer. [pmid: 11002229].
251 Jarow JP. Puboprostatic ligament sparing radical retropubic prostatectomy. Seminars in Urologic Oncology. 2000;18(1):28-32. Not comparative treatments. [pmid: 10719927].
252 Jayadevappa R, Bloom BS, Fomberstein SC, Wein AJ, Malkowicz SB. Health related quality of life and direct medical care cost in newly diagnosed younger men with prostate cancer. Journal of Urology. 2005;174(3):1059-64. discussion 64. Less than 100 patients per study arm. [pmid: 16094058].
253 Jayadevappa R, Chhatre S, Whittington R, Bloom BS, Wein AJ, Malkowicz SB. Health-related quality of life and satisfaction with care among older men treated for prostate cancer with either radical prostatectomy or external beam radiation therapy. BJU International. 2006;97(5):955-62. Not localized prostate cancer. [pmid: 16643477].
254 Jayadevappa R, Johnson JC, Chhatre S, Wein AJ, Malkowicz SB. Ethnic variation in return to baseline values of patient-reported outcomes in older prostate cancer patients. Cancer. Jun 1. 2007;109(11):2229-38. Not comparative treatments. [pmid: 17443664].
255 Jenkins R, Schover LR, Fouladi RT, Warneke C, Neese L, Klein EA, et al. Sexuality and health-related quality of life after prostate cancer in African-American and white men treated for localized disease. Journal of Sex & Marital Therapy. 2004;30(2):79-93. Not comparative treatments. [pmid: 14742098].
256 Jenkins VA, Bloomfield DJ, Shilling VM, Edginton TL. Does neoadjuvant hormone therapy for early prostate cancer affect cognition? Results from a pilot study.[see comment]. BJU International. 2005;96(1):48-53. Less than 100 patients per study arm. [pmid: 15963119].
257 Jepson R, Clegg A, Forbes C, Lewis R, Sowden A, Kleijnen J. The determinants of screening uptake and interventions for increasing uptake: a systematic review. Health Technology Assessment (Winchester, England). 2000;4(14):i-vii. Review article.
258 Jo Y, Hiratsuka J, Fujii T, Takenaka A, Fujisawa M. High-dose-rate iridium-192 afterloading therapy combined with external beam radiotherapy for T1c–T3bN0M0 prostate cancer. Urology. 2004;64(3):556-60. Not localized prostate cancer. [pmid: 15351592].
259 Jo Y, Junichi H, Tomohiro F, Yoshinari I, Masato F. Radical prostatectomy versus high-dose rate brachytherapy for prostate cancer: effects on health-related quality of life. BJU International. 2005;96(1):43-7. Not localized prostate cancer. [pmid: 15963118].
260 Johannsen M, Gneveckow U, Eckelt L, Feussner A, Waldofner N, Scholz R, et al. Clinical hyperthermia of prostate cancer using magnetic nanoparticles: presentation of a new interstitial technique. International Journal of Hyperthermia. 2005;21(7):637-47. No QOL outcomes. [pmid: 16304715].
261 Johannsen M, Gneveckow U, Taymoorian K, Thiesen B, Waldofner N, Scholz R, et al. Morbidity and quality of life during thermotherapy using magnetic nanoparticles in locally recurrent prostate cancer: results of a prospective phase I trial. International Journal of Hyperthermia. May. 2007;23(3):315-23. Less than 100 patients per study arm. [pmid: 17523023].
262 Johnstone PA, Gray C, Powell CR. Quality of life in T1–3N0 prostate cancer patients treated with radiation therapy with minimum 10-year follow-up. International Journal of Radiation Oncology, Biology, Physics. 2000;46(4):833-8. Not localized prostate cancer.
263 Joly F, Alibhai SMH, Galica J, Park A, Yi QL, Wagner L, et al. Impact of androgen deprivation therapy on physical and cognitive function, as well as quality of life of patients with nonmetastatic prostate cancer. Journal of Urology. Dec. 2006;176(6 Pt 1):2443-7. Less than 100 patients per study arm. [pmid: 17085125].
264 Joseph HJ, Thibault GP, Ruttle-King J. Perceived stress and quality of life among prostate cancer survivors. Mil Med. May. 2006;171(5):425-9. Not comparative treatments. [pmid: 16761894].
265 Jurczok A, Zacharias M, Wagner S, Hamza A, Fornara P. Prospective non-randomized evaluation of four mediators of the systemic response after extraperitoneal laparoscopic and open retropubic radical prostatectomy. BJU International. Jun. 2007;99(6):1461-6. Not localized prostate cancer. [pmid: 17537217].
266 Kaasa S, Brenne E, Lund JA, Fayers P, Falkmer U, Holmberg M, et al. Prospective randomised multicenter trial on single fraction radiotherapy (8 Gy × 1) versus multiple fractions (3 Gy × 10) in the treatment of painful bone metastases. Radiotherapy & Oncology. Jun. 2006;79(3):278-84. Not localized prostate cancer. [pmid: 16793154].
267 Kaiho Y, Nakagawa H, Ikeda Y, Namiki S, Numahata K, Satoh M, et al. Intraoperative electrophysiological confirmation of urinary continence after radical prostatectomy. Journal of Urology. 2005;173(4):1139-42. Not comparative treatments. [pmid: 15758722].
268 Kakehi Y, Kamoto T, Ogawa O, Arai Y, Litwin MS, Suzukamo Y, et al. Development of Japanese version of the UCLA Prostate Cancer Index: a pilot validation study. International Journal of Clinical Oncology. 2002;7(5):306-11. Validation study. [pmid: 12402065].
269 Kakehi Y, Takegami M, Suzukamo Y, Namiki S, Arai Y, Kamoto T, et al. Health related quality of life in Japanese men with localized prostate cancer treated with current multiple modalities assessed by a newly developed Japanese version of the Expanded Prostate Cancer Index Composite. Journal of Urology. May. 2007;177(5):1856-61. Less than 100 patients per study arm. [pmid: 17437836].
270 Kalkner KM, Acosta S, Thorsson O, Frederiksen H, Nilsson A, Gustavsson B, et al. Octreotide scintigraphy and Chromogranin A do not predict clinical response in patients with octreotide acetate-treated hormone-refractory prostate cancer. Prostate Cancer & Prostatic Diseases. 2006;9(1):92-8. Not localized prostate cancer. [pmid: 16231013].
271 Kang SH, Kim JW, Bae JH, Park HS, Moon DG, Yoon DK, et al. Targeted-cryosurgical ablation of the prostate with androgen deprivation therapy: quality of life in high-risk prostate cancer patients. Asian J Androl. Sep. 2006;8(5):629-36. Less than 100 patients per study arm. [pmid: 16847531].
272 Kao GD, Devine P. Use of complementary health practices by prostate carcinoma patients undergoing radiation therapy. Cancer. 2000;88(3):615-9. Less than 100 patients per study arm. [pmid: 10649255].
273 Kao J, Turian J, Meyers A, Hamilton RJ, Smith B, Vijayakumar S, et al. Sparing of the penile bulb and proximal penile structures with intensity-modulated radiation therapy for prostate cancer. British Journal of Radiology. 2004;77(914):129-36. Less than 100 patients per study arm. [pmid: 15010385].
274 Ka'opua LSL, Gotay CC, Boehm PS. Spiritually based resources in adaptation to long-term prostate cancer survival: perspectives of elderly wives. Health Soc Work. Feb. 2007;32(1):29-39. Less than 100 patients per study arm. [pmid: 17432739].
275 Karakiewicz PI, Kattan MW, Tanguay S, Elhilali MM, Bazinet M, Scardino PT, et al. Cross-cultural validation of the UCLA prostate cancer index. Urology. 2003;61(2):302-7. Validation study. [pmid: 12597935].
276 Karakiewicz PI, Tanguay S, Kattan MW, Elhilali MM, Aprikian AG. Erectile and urinary dysfunction after radical prostatectomy for prostate cancer in Quebec: a population-based study of 2415 men. European Urology. 2004;46(2):188-94. Not comparative treatments. [pmid: 15245812].
277 Kasimis B, Wilding G, Kreis W, Feuerman M, Chang V, Hwang S, et al. Survival of patients who had salvage castration after failure on bicalutamide monotherapy for stage (D2) prostate cancer.[see comment]. Cancer Investigation. 2000;18(7):602-8. Not localized prostate cancer. [pmid: 11036467].
278 Kattan MW, Fearn PA, Miles BJ. Time trade-off utility modified to accommodate degenerative and life-threatening conditions. Proceedings / AMIA Annual Symposium 2001:304–8. Not comparative treatments
279 Katz D, Koppie TM, Wu D, Meng MV, Grossfeld GD, Sadesky N, et al. Sociodemographic characteristics and health related quality of life in men attending prostate cancer support groups. Journal of Urology. 2002;168(5):2092-6. Not comparative treatments. [pmid: 12394716].
280 Katz G, Rodriguez R. Use of a modified American Urological Association Symptom Score for the evaluation of the quality of life of patients with prostate cancer. Urology. 2001;57(1):112-6. Validation study. [pmid: 11164154].
281 Katz G, Rodriguez R. Changes in continence and health-related quality of life after curative treatment and watchful waiting of prostate cancer. Urology. Jun. 2007;69(6):1157-60. Less than 100 patients per study arm. [pmid: 17572206].
282 Kaul S, Savera A, Badani K, Fumo M, Bhandari A, Menon M. Functional outcomes and oncological efficacy of Vattikuti Institute prostatectomy with Veil of Aphrodite nerve-sparing: an analysis of 154 consecutive patients. BJU International. 2006;97(3):467-72. Not comparative treatments. [pmid: 16469009].
283 Key TJ, Allen N, Appleby P, Overvad K, Tjonneland A, Miller A, et al. Fruits and vegetables and prostate cancer: no association among 1104 cases in a prospective study of 130544 men in the European Prospective Investigation into Cancer and Nutrition (EPIC). International Journal of Cancer. 2004;109(1):119-24. Not comparative treatments. [pmid: 14735477].
284 Kim SP, Knight SJ, Tomori C, Colella KM, Schoor RA, Shih L, et al. Health literacy and shared decision making for prostate cancer patients with low socioeconomic status. Cancer Investigation. 2001;19(7):684-91. Not comparative treatments. [pmid: 11577809].
285 Kim Y, Roscoe JA, Morrow GR. The effects of information and negative affect on severity of side effects from radiation therapy for prostate cancer. Supportive Care in Cancer. 2002;10(5):416-21. Not comparative treatments. [pmid: 12136225].
286 Kinsinger DP, Penedo FJ, Antoni MH, Dahn JR, Lechner S, Schneiderman N. Psychosocial and sociodemographic correlates of benefit-finding in men treated for localized prostate cancer. Psycho-Oncology. Nov. 2006;15(11):954-61. Not comparative treatments. [pmid: 16523528].
287 Kirby R. Case study: management of lymph node-positive disease detected at radical prostatectomy. Prostate Cancer & Prostatic Diseases. 2005;8(3):287-9. Less than 100 patients per study arm. [pmid: 15940288].
288 Kirschner-Hermanns R, Jakse G. Quality of life following radical prostatectomy. Frontiers of Radiation Therapy & Oncology. 2002;36:99-105. Not comparative treatments. [pmid: 11842760].
289 Klabunde CN, Reeve BB, Harlan LC, Davis WW, Potosky AL. Do patients consistently report comorbid conditions over time?: results from the prostate cancer outcomes study. Medical Care. 2005;43(4):391-400. No QOL outcomes. [pmid: 15778642].
290 Knight SJ, Latini DM, Hart SL, Sadetsky N, Kane CJ, DuChane J, et al. Education predicts quality of life among men with prostate cancer cared for in the Department of Veterans Affairs: a longitudinal quality of life analysis from CaPSURE. Cancer. May 1. 2007;109(9):1769-76. CaPSURE data. [pmid: 17380491].
291 Knight SJ, Siston AK, Chmiel JS, Slimack N, Elstein AS, Chapman GB, et al. Ethnic variation in localized prostate cancer: a pilot study of preferences, optimism, and quality of life among black and white veterans. Clinical Prostate Cancer. 2004;3(1):31-7. No QOL outcomes. [pmid: 15279688].
292 Ko CM, Malcarne VL, Varni JW, Roesch SC, Banthia R, Greenbergs HL, et al. Problem-solving and distress in prostate cancer patients and their spousal caregivers. Supportive Care in Cancer. 2005;13(6):367-74. Not comparative treatments. [pmid: 15657688].
293 Kobayashi T, Nishizawa K, Mitsumori K. Individual variation of hormonal recovery after cessation of luteinizing hormone-releasing hormone agonist therapy in men receiving long-term medical castration therapy for prostate cancer. Scandinavian Journal of Urology & Nephrology. 2006;40(3):198-203. No QOL outcomes. [pmid: 16809259].
294 Kolodziej M, Neubauer MA, Rousey SR, Pluenneke RE, Perrine G, Mull S, et al. Phase II trial of docetaxel/capecitabine in hormone-refractory prostate cancer. Clin Genitourin Cancer. Sep. 2006;5(2):155-61. Not comparative treatments. [pmid: 17026805].
295 Konski A, Watkins-Bruner D, Feigenberg S, Hanlon A, Kulkarni S, Beck JR, et al. Using decision analysis to determine the cost-effectiveness of intensity-modulated radiation therapy in the treatment of intermediate risk prostate cancer. International Journal of Radiation Oncology, Biology, Physics. Oct 1. 2006;66(2):408-15. Not comparative treatments.
296 Korfage IJ, de Koning HJ, Habbema JDF, Schroder FH, Essink-Bot ML. Side-effects of treatment for localized prostate cancer: are they valued differently by patients and healthy controls?. BJU International. Apr. 2007;99(4):801-6. Less than 100 patients per study arm. [pmid: 17233804].
297 Korfage IJ, de Koning HJ, Roobol M, Schroder FH, Essink-Bot ML. Prostate cancer diagnosis: the impact on patients' mental health. European Journal of Cancer. 2006;42(2):165-70. Not comparative treatments. [pmid: 16326098].
298 Korfage IJ, Essink-Bot ML, Borsboom GJ, Madalinska JB, Kirkels WJ, Habbema JD, et al. Five-year follow-up of health-related quality of life after primary treatment of localized prostate cancer. International Journal of Cancer. 2005;116(2):291-6. Not localized prostate cancer. [pmid: 15800919].
299 Korfage IJ, Essink-Bot ML, Madalinska JB, Kirkels WJ, Litwin MS, de Koning HJ. Measuring disease specific quality of life in localized prostate cancer: the Dutch experience. Quality of Life Research. 2003;12(4):459-64. Validation study. [pmid: 12797718].
300 Korfage IJ, Hak T, de Koning HJ, Essink-Bot ML. Patients' perceptions of the side-effects of prostate cancer treatment—a qualitative interview study. Soc Sci Med. Aug. 2006;63(4):911-9. Less than 100 patients per study arm. [pmid: 16798130].
301 Kornblith AB, Herndon JE 2nd, Zuckerman E, Godley PA, Savarese D, Vogelzang NJ, et al. The impact of docetaxel, estramustine, and low dose hydrocortisone on the quality of life of men with hormone refractory prostate cancer and their partners: a feasibility study. Annals of Oncology. 2001;12(5):633-41. Not localized prostate cancer. [pmid: 11432621].
302 Koroukian SM, Murray P, Madigan E. Comorbidity, disability, and geriatric syndromes in elderly cancer patients receiving home health care. Journal of Clinical Oncology. 2006;24(15):2304-10. Not localized prostate cancer. [pmid: 16710028].
303 Kouba E, Hubbard JS, Moore D, Wallen EM, Pruthi RS. A prospective evaluation of the short-term impact and recovery of health-related quality of life in men undergoing radical prostatectomy. BJU International. Jan. 2007;99(1):72-6. Not comparative treatments. [pmid: 17227494].
304 Krahn M, Ritvo P, Irvine J, Tomlinson G, Bezjak A, Trachtenberg J, et al. Construction of the Patient-Oriented Prostate Utility Scale (PORPUS): a multiattribute health state classification system for prostate cancer. Journal of Clinical Epidemiology. 2000;53(9):920-30. Design study. [pmid: 11004418].
305 Krahn M, Ritvo P, Irvine J, Tomlinson G, Bremner KE, Bezjak A, et al. Patient and community preferences for outcomes in prostate cancer: implications for clinical policy. Medical Care. 2003;41(1):153-64. Not localized prostate cancer. [pmid: 12544552].
306 Kronenwetter C, Weidner G, Pettengill E, Marlin R, Crutchfield L, McCormac P, et al. A qualitative analysis of interviews of men with early stage prostate cancer: the Prostate Cancer Lifestyle Trial. Cancer Nursing. 2005;28(2):99-107. Less than 100 patients per study arm. [pmid: 15815179].
307 Krupski T, Bissonette EA, Petroni GR, Theodorescu D. The impact of prostate volume following neoadjuvant androgen deprivation on quality of life and voiding symptoms in patients undergoing permanent prostate brachytherapy. European Urology. 2003;43(5):467-72. Not localized prostate cancer. [pmid: 12705988].
308 Krupski T, Petroni GR, Bissonette EA, Theodorescu D. Quality-of-life comparison of radical prostatectomy and interstitial brachytherapy in the treatment of clinically localized prostate cancer. Urology. 2000;55(5):736-42. Not localized prostate cancer. [pmid: 10792092].
309 Krupski TL, Bergman J, Kwan L, Litwin MS. Quality of prostate carcinoma care in a statewide public assistance program. Cancer. 2005;104(5):985-92. Quality of care study. [pmid: 16047332].
310 Krupski TL, Fink A, Kwan L, Maliski S, Connor SE, Clerkin B, et al. Health-related quality-of-life in low-income, uninsured men with prostate cancer. Journal of Health Care for the Poor & Underserved. 2005;16(2):375-90. Not localized prostate cancer. [pmid: 15937399].
311 Krupski TL, Kwan L, Fink A, Sonn GA, Maliski S, Litwin MS. Spirituality influences health related quality of life in men with prostate cancer. Psycho-Oncology. Feb. 2006;15(2):121-31. Not comparative treatments. [pmid: 15880458].
312 Krupski TL, Saigal CS, Litwin MS. Variation in continence and potency by definition.[see comment]. Journal of Urology. 2003;170(4 Pt 1):1291-4. Validation study. [pmid: 14501744].
313 Kubler HR, Tseng TY, Sun L, Vieweg J, Harris MJ, Dahm P. Impact of nerve sparing technique on patient self-assessed outcomes after radical perineal prostatectomy. Journal of Urology. Aug. 2007;178(2):488-92. discussion 92. Not comparative treatments. [pmid: 17561133].
314 Kumar V, Toussi H, Marr C, Hough C, Javle P. The benefits of radical prostatectomy beyond cancer control in symptomatic men with prostate cancer. BJU International. 2004;93(4):507-9. Less than 100 patients per study arm. [pmid: 15008719].
315 Kupelian PA, Willoughby TR. Short-course, intensity-modulated radiotherapy for localized prostate cancer. Cancer Journal. 2001;7(5):421-6. Not comparative treatments.
316 Kuriyama M, Takahashi Y, Sahashi M, Ono Y, Tanaka T, Shimizu H, et al. Prospective and randomized comparison of combined androgen blockade versus combination with oral UFT as an initial treatment for prostate cancer. Japanese Journal of Clinical Oncology. 2001;31(1):18-24. Not localized prostate cancer. [pmid: 11256836].
317 Kwiatkowski M, Huber A, Moschopulos M, Lehmann K, Wernli M, Hafeli A, et al. Prostate cancer screening: results of a prospective trial in Canton Aargau, Switzerland. Swiss Medical Weekly. 2004;134(3940):580-5. Not comparative treatments. [pmid: 15592949].
318 Lambert S, Fearing A, Bell D, Newton M. A comparative study of prostate screening health beliefs and practices between African American and Caucasian men. ABNF Journal. 2002;13(3):61-3. Not comparative treatments. [pmid: 12108142].
319 Larson G, Pappas N, Hassoun B. Prostate cancer treatment with ultrasound-guided transperineal brachytherapy: analysis of the treatment results of our first 150 patients. Journal - Oklahoma State Medical Association. 2000;93(8):391-6. Not comparative treatments. [pmid: 10979616].
320 Latini DM, Chan JM, Cowan JE, Arredondo SA, Kane CJ, Penson DF, et al. Health-related quality of life for men with prostate cancer and diabetes: a longitudinal analysis from CaPSURE. Urology. Dec. 2006;68(6):1242-7. CaPSURE data. [pmid: 17141841].
321 Lebeau T, Perrotte P, Valiquette L, Benard F, McCormack M, Saad F, et al. Validation of prostate cancer index and SF-12 short forms. Canadian Journal of Urology. 2005;12(6):2873-9. Validation study. [pmid: 16401372].
322 Lee D. Clinical trials of atrasentan in hormone-refractory prostate cancer. Clinical Prostate Cancer. 2003;2(2):84-6. Not localized prostate cancer. [pmid: 15040868].
323 Lee JJ, Lieberman R, Sloan JA, Piantadosi S, Lippman SM. Design considerations for efficient prostate cancer chemoprevention trials. Urology. 2001;57(4 Suppl 1):205-12. Not comparative treatments. [pmid: 11295629].
324 Lee WR, McQuellon RP, Harris-Henderson K, Case LD, McCullough DL. A preliminary analysis of health-related quality of life in the first year after permanent source interstitial brachytherapy (PIB) for clinically localized prostate cancer. International Journal of Radiation Oncology, Biology, Physics. 2000;46(1):77-81. Not comparative treatments.
325 Lee WR, McQuellon RP, McCullough DL. A prospective analysis of patient-reported quality of life after prostate brachytherapy. Seminars in Urologic Oncology. 2000;18(2):147-51. Not comparative treatments. [pmid: 10875457].
326 Legler J, Potosky AL, Gilliland FD, Eley JW, Stanford JL. Validation study of retrospective recall of disease-targeted function: results from the prostate cancer outcomes study. Medical Care. 2000;38(8):847-57. Validation study. [pmid: 10929996].
327 Legler JM, Davis WW, Potosky AL, Hoffman RM. Latent variable modelling of recovery trajectories: sexual function following radical prostatectomy. Statistics in Medicine. 2004;23(18):2875-93. Not comparative treatments. [pmid: 15344192].
328 Lehrer S, Cesaretti J, Stone NN, Stock RG. Urinary symptom flare after brachytherapy for prostate cancer is associated with erectile dysfunction and more urinary symptoms before implantation. BJU International. Nov. 2006;98(5):979-81. Not comparative treatments. [pmid: 17034599].
329 Leibovici D, Lee AK, Cheung RM, Spiess PE, Kuban DA, Rosser CJ, et al. Symptomatic local recurrence of prostate carcinoma after radiation therapy. Cancer. 2005;103(10):2060-6. Not comparative treatments. [pmid: 15822114].
330 Leitzmann MF. Is there a link between macronutrient intake and prostate cancer?. Nature Clinical Practice Oncology. 2005;2(4):184-5. Review article.
331 Lepore SJ, Helgeson VS, Eton DT, Schulz R. Improving quality of life in men with prostate cancer: a randomized controlled trial of group education interventions. Health Psychology. 2003;22(5):443-52. Not comparative treatments. [pmid: 14570527].
332 Lertakyamanee J, Ruksamanee EO, Tantiwong A, Boonsuk K, Nilpradab I, Vorakijpokatorn P, et al. The risk and effectiveness of transurethral resection of prostate. Journal of the Medical Association of Thailand. 2002;85(12):1288-95. Not comparative treatments. [pmid: 12678166].
333 Lev EL, Eller LS, Gejerman G, Lane P, Owen SV, White M, et al. Quality of life of men treated with brachytherapies for prostate cancer. Health & Quality of Life Outcomes. 2004;2:28. Less than 100 patients per study arm. [pmid: 15198803].
334 Lev EL, Eller LS, Kolassa J, Gejerman G, Colella J, Lane P, et al. Exploratory factor analysis: strategies used by patients to promote health. World Journal of Urology. Mar. 2007;25(1):87-93. No QOL outcomes. [pmid: 17066263].
335 Lewinshtein DJ, Perrotte P, Lebeau T, Ramirez A, Benayoun S, Karakiewicz PI. Normal urinary and sexual function in men without evidence of prostate cancer from Montreal, Canada. BJU International. Jun. 2006;97(6):1273-7. Not localized prostate cancer. [pmid: 16686725].
336 Lieberman R. Prostate cancer chemoprevention: Strategies for designing efficient clinical trials. Urology. 2001;57(4 Suppl 1):224-9. Not comparative treatments. [pmid: 11295633].
337 Liepe K, Kotzerke J. A comparative study of 188Re-HEDP, 186Re-HEDP, 153Sm-EDTMP and 89Sr in the treatment of painful skeletal metastases. Nucl Med Commun. Aug. 2007;28(8):623-30. Not localized prostate cancer. [pmid: 17625384].
338 Liepe K, Runge R, Kotzerke J. Systemic radionuclide therapy in pain palliation. American Journal of Hospice & Palliative Care. 2005;22(6):457-64. Not localized prostate cancer. [pmid: 16323716].
339 Little DJ, Kuban DA, Levy LB, Zagars GK, Pollack A. Quality-of-life questionnaire results 2 and 3 years after radiotherapy for prostate cancer in a randomized dose-escalation study. Urology. 2003;62(4):707-13. Not localized prostate cancer. [pmid: 14550448].
340 Litwin MS, Gore JL, Kwan L, Brandeis JM, Lee SP, Withers HR, et al. Quality of life after surgery, external beam irradiation, or brachytherapy for early-stage prostate cancer. Cancer. Jun 1. 2007;109(11):2239-47. Less than 100 patients per study arm. [pmid: 17455209].
341 Litwin MS, Greenfield S, Elkin EP, Lubeck DP, Broering JM, Kaplan SH. Assessment of prognosis with the total illness burden index for prostate cancer: aiding clinicians in treatment choice. Cancer. May 1. 2007;109(9):1777-83. CaPSURE data. [pmid: 17354226].
342 Litwin MS, Lubeck DP, Spitalny GM, Henning JM, Carroll PR. Mental health in men treated for early stage prostate carcinoma: a posttreatment, longitudinal quality of life analysis from the Cancer of the Prostate Strategic Urologic Research Endeavor. Cancer. 2002;95(1):54-60. CaPSURE data. [pmid: 12115317].
343 Litwin MS, Lubeck DP, Stoddard ML, Pasta DJ, Flanders SC, Henning JM. Quality of life before death for men with prostate cancer: results from the CaPSURE database. Journal of Urology. 2001;165(3):871-5. CaPSURE data. [pmid: 11176489].
344 Litwin MS, Melmed GY, Nakazon T. Life after radical prostatectomy: a longitudinal study.[see comment]. Journal of Urology. 2001;166(2):587-92. Not comparative treatments. [pmid: 11458073].
345 Litwin MS, Pasta DJ, Yu J, Stoddard ML, Flanders SC. Urinary function and bother after radical prostatectomy or radiation for prostate cancer: a longitudinal, multivariate quality of life analysis from the Cancer of the Prostate Strategic Urologic Research Endeavor. Journal of Urology. 2000;164(6):1973-7. CaPSURE data. [pmid: 11061894].
346 Litwin MS, Sadetsky N, Pasta DJ, Lubeck DP. Bowel function and bother after treatment for early stage prostate cancer: a longitudinal quality of life analysis from CaPSURE. Journal of Urology. 2004;172(2):515-9. CaPSURE data. [pmid: 15247718].
347 Livingston P, White V, Hayman J, Hill D. How acceptable is a referral and telephone-based outcall programme for men diagnosed with cancer? A feasibility study. Eur J Cancer Care (Engl). Dec. 2006;15(5):467-75. Not comparative treatments. [pmid: 17177905].
348 Livsey JE, Routledge J, Burns M, Swindell R, Davidson SE, Cowan RA, et al. Scoring of treatment-related late effects in prostate cancer. Radiotherapy & Oncology. 2002;65(2):109-21. Not comparative treatments. [pmid: 12443807].
349 Lock M, Loblaw DA, Choo R, Imrie K. Disseminated intravascular coagulation and PC-SPES: a case report and literature review. Canadian Journal of Urology. 2001;8(4):1326-9. Review article. [pmid: 11564276].
350 Lowe FC. Goals for benign prostatic hyperplasia therapy. Urology. 2002;59(2 Suppl 1):1-2. Not localized prostate cancer. [pmid: 11832306].
351 Lubeck DP, Kim H, Grossfeld G, Ray P, Penson DF, Flanders SC, et al. Health related quality of life differences between black and white men with prostate cancer: data from the cancer of the prostate strategic urologic research endeavor.[see comment]. Journal of Urology. 2001;166(6):2281-5. CaPSURE data. [pmid: 11696752].
352 Lubeck DP, Litwin MS, Henning JM, Mathias SD, Bloor L, Carroll PR. An instrument to measure patient satisfaction with healthcare in an observational database: results of a validation study using data from CaPSURE. American Journal of Managed Care. 2000;6(1):70-6. CaPSURE data. [pmid: 11009748].
353 Ma G, Troxel AB, Heitjan DF. An index of local sensitivity to nonignorable drop-out in longitudinal modelling. Statistics in Medicine. 2005;24(14):2129-50. Review article. [pmid: 15909292].
354 Madalinska JB, Essink-Bot ML, de Koning HJ, Kirkels WJ, van der Maas PJ, Schroder FH. Health-related quality-of-life effects of radical prostatectomy and primary radiotherapy for screen-detected or clinically diagnosed localized prostate cancer.[see comment]. Journal of Clinical Oncology. 2001;19(6):1619-28. Not localized prostate cancer. [pmid: 11250990].
355 Madalinska JB, Essink-Bot ML, de Koning HJ, Kirkels WJ, van der Maas PJ, Schroder FH. Health-related quality of life in patients with screen-detected versus clinically diagnosed prostate cancer preceding primary treatment. Prostate. 2001;46(2):87-97. Not comparative treatments. [pmid: 11170136].
356 Maier S, Reich E, Martin R, Bachem M, Altug V, Hautmann RE, et al. Tributyrin induces differentiation, growth arrest and apoptosis in androgen-sensitive and androgen-resistant human prostate cancer cell lines. International Journal of Cancer. 2000;88(2):245-51. Not localized prostate cancer. [pmid: 11004676].
357 Malcarne VL, Banthia R, Varni JW, Sadler GR, Greenbergs HL, Ko CM. Problem-solving skills and emotional distress in spouses of men with prostate cancer. Journal of Cancer Education. 2002;17(3):150-4. Not comparative treatments. [pmid: 12243220].
358 Malik A, Mukhtar H. Prostate cancer prevention through pomegranate fruit. Cell Cycle. 2006;5(4):371-3. Not comparative treatments. [pmid: 16479165].
359 Maliski SL, Kwan L, Krupski T, Fink A, Orecklin JR, Litwin MS. Confidence in the ability to communicate with physicians among low-income patients with prostate cancer. Urology. 2004;64(2):329-34. Not comparative treatments. [pmid: 15302489].
360 Maliski SL, Kwan L, Orecklin JR, Saigal CS, Litwin MS. Predictors of fatigue after treatment for prostate cancer. Urology. 2005;65(1):101-8. No QOL outcomes. [pmid: 15667873].
361 Mangar SA, Sydes MR, Tucker HL, Coffey J, Sohaib SA, Gianolini S, et al. Evaluating the relationship between erectile dysfunction and dose received by the penile bulb: using data from a randomised controlled trial of conformal radiotherapy in prostate cancer (MRC RT01, ISRCTN47772397). Radiotherapy & Oncology. Sep. 2006;80(3):355-62. No QOL outcomes. [pmid: 16949694].
362 Mark HF, Samy M, Santoro K, Mark S, Feldman D. Fluorescent in situ hybridization study of c-myc oncogene copy number in prostate cancer. Experimental & Molecular Pathology. 2000;68(1):65-9. Not localized prostate cancer. [pmid: 10640455].
363 Marley J. Can quality-of-life measures help in the care of urology patients?. Professional Nurse. 2002;18(4):229-31. Review article.
364 Massey P. Intravenous nutrient therapy eliminated androgen deprivation therapy-induced hot flashes in two men with prostate cancer. J Soc Integr Oncol. 2006;4(4):153-6. Not comparative treatments. [pmid: 17022923].
365 Matsuura N, Kamae I, Nakamura H, Maruo T. Utility and treatment decisions: 15 clinical cases in Japan. Journal of Evaluation in Clinical Practice. 2001;7(4):419-30. Less than 100 patients per study arm. [pmid: 11737533].
366 Maung K. Zoledronic acid is effective in the treatment of prostate cancer patients with bone metastases. Clinical Prostate Cancer. 2002;1(1):12-3. Not localized prostate cancer. [pmid: 15046707].
367 McBride CM, Clipp E, Peterson BL, Lipkus IM, Demark-Wahnefried W. Psychological impact of diagnosis and risk reduction among cancer survivors. Psycho-Oncology. 2000;9(5):418-27. Not localized prostate cancer. [pmid: 11038480].
368 McElveen TL, Waterman FM, Kim H, Dicker AP. Factors predicting for urinary incontinence after prostate brachytherapy. International Journal of Radiation Oncology, Biology, Physics. 2004;59(5):1395-404. Not comparative treatments.
369 McGovern PM, Gross CR, Krueger RA, Engelhard DA, Cordes JE, Church TR. False-positive cancer screens and health-related quality of life. Cancer Nursing. 2004;27(5):347-52. Not comparative treatments. [pmid: 15525861].
370 McLaughlin PW, Troyer S, Berri S, Narayana V, Meirowitz A, Roberson PL, et al. Functional anatomy of the prostate: implications for treatment planning. International Journal of Radiation Oncology, Biology, Physics. 2005;63(2):479-91. No QOL outcomes.
371 McPherson CP, Swenson KK, Kjellberg J. Quality of life in patients with prostate cancer. Seminars in Oncology Nursing. 2001;17(2):138-46. Review article. [pmid: 11383245].
372 Mehta SS, Lubeck DP, Pasta DJ, Litwin MS. Fear of cancer recurrence in patients undergoing definitive treatment for prostate cancer: results from CaPSURE. Journal of Urology. 2003;170(5):1931-3. CaPSURE data. [pmid: 14532810].
373 Meng MV, Elkin EP, Harlan SR, Mehta SS, Lubeck DP, Carroll PR. Predictors of treatment after initial surveillance in men with prostate cancer: results from CaPSURE. Journal of Urology. 2003;170(6 Pt 1):2279-83. CaPSURE data. [pmid: 14634396].
374 Merrick GS, Butler WM. Rectal function following permanent prostate brachytherapy. West Virginia Medical Journal. 2004;100(1):18-20. Not comparative treatments. [pmid: 15119492].
375 Merrick GS, Butler WM, Dorsey AT, Galbreath RW, Blatt H, Lief JH. Rectal function following prostate brachytherapy. International Journal of Radiation Oncology, Biology, Physics. 2000;48(3):667-74. Not comparative treatments.
376 Merrick GS, Butler WM, Galbreath RW, Stipetich RL, Abel LJ, Lief JH. Erectile function after permanent prostate brachytherapy. International Journal of Radiation Oncology, Biology, Physics. 2002;52(4):893-902. Not comparative treatments.
377 Merrick GS, Butler WM, Wallner K, Galbreath RW, Anderson RL, Kurko BS, et al. Permanent prostate brachytherapy-induced morbidity in patients with grade II and III obesity. Urology. 2002;60(1):104-8. Not comparative treatments. [pmid: 12100933].
378 Merrick GS, Butler WM, Wallner KE, Allen Z, Galbreath RW, Lief JH. Brachytherapy-related dysuria. BJU International. 2005;95(4):597-602. Not comparative treatments. [pmid: 15705087].
379 Merrick GS, Butler WM, Wallner KE, Galbreath RW, Allen ZA, Gutman S, et al. Long-term rectal function after permanent prostate brachytherapy.[see comment]. Cancer Journal. Mar–Apr. 2007;13(2):95-104. Not comparative treatments.
380 Merrick GS, Butler WM, Wallner KE, Galbreath RW, Anderson RL, Kurko BS, et al. Erectile function after prostate brachytherapy. International Journal of Radiation Oncology, Biology, Physics. 2005;62(2):437-47. Not comparative treatments.
381 Merrick GS, Butler WM, Wallner KE, Galbreath RW, Kurko B, Cleavinger S. Rectal function following brachytherapy with or without supplemental external beam radiation: results of two prospective randomized trials. Brachytherapy. 2003;2(3):147-57. No QOL outcomes. [pmid: 15062137].
382 Merrick GS, Butler WM, Wallner KE, Galbreath RW, Lief JH. Long-term urinary quality of life after permanent prostate brachytherapy. International Journal of Radiation Oncology, Biology, Physics. 2003;56(2):454-61. Not comparative treatments.
383 Merrick GS, Butler WM, Wallner KE, Galbreath RW, Murray B, Zeroski D, et al. Dysuria after permanent prostate brachytherapy. International Journal of Radiation Oncology, Biology, Physics. 2003;55(4):979-85. Not comparative treatments.
384 Merrick GS, Butler WM, Wallner KE, Hines AL, Allen Z. Late rectal function after prostate brachytherapy. International Journal of Radiation Oncology, Biology, Physics. 2003;57(1):42-8. Not comparative treatments.
385 Merrick GS, Butler WM, Wallner KE, Lief JH, Anderson RL, Smeiles BJ, et al. The importance of radiation doses to the penile bulb vs. crura in the development of postbrachytherapy erectile dysfunction. International Journal of Radiation Oncology, Biology, Physics. 2002;54(4):1055-62. Less than 100 patients per study arm.
386 Merrick GS, Butler WM, Wallner KE, Murray BC, Allen Z, Galbreath RW. Influence of hormonal therapy on late rectal function after permanent prostate brachytherapy with or without supplemental external beam radiotherapy. International Journal of Radiation Oncology, Biology, Physics. 2004;58(1):68-74. No QOL outcomes.
387 Merrill RM. Demographics and health-related factors of men receiving prostate-specific antigen screening in Utah. Preventive Medicine. 2001;33(6):646-52. Not comparative treatments. [pmid: 11716662].
388 Merrill RM, Perego UA, Heiner SW. Age, lifestyle, health risk indicators, and prostate-specific antigen scores in men participating in the world senior games. Urologic Oncology. 2002;7(3):105-9. Not localized prostate cancer. [pmid: 12474543].
389 Meyer JP, Gillatt DA, Lockyer R, Macdonagh R. The effect of erectile dysfunction on the quality of life of men after radical prostatectomy. BJU International. 2003;92(9):929-31. Not comparative treatments. [pmid: 14632849].
390 Michalski JM, Winter K, Purdy JA, Wilder R, Perez CA, Roach M, et al. Trade-off to low-grade toxicity with conformal radiation therapy for prostate cancer on Radiation Therapy Oncology Group 9406. Seminars in Radiation Oncology. 2002;12(1 Suppl 1):75-80. Not comparative treatments. [pmid: 11917289].
391 Michalski JM, Winter K, Purdy JA, Wilder RB, Perez CA, Roach M, et al. Preliminary evaluation of low-grade toxicity with conformal radiation therapy for prostate cancer on RTOG 9406 dose levels I and II. International Journal of Radiation Oncology, Biology, Physics. 2003;56(1):192-8. Not comparative treatments.
392 Miften MM, Beavis AW, Marks LB. Influence of dose calculation model on treatment plan evaluation in conformal radiotherapy: a three-case study. Medical Dosimetry. 2002;27(1):51-7. Less than 100 patients per study arm. [pmid: 12019966].
393 Miller DC, Litwin MS, Sanda MG, Montie JE, Dunn RL, Resh J, et al. Use of quality indicators to evaluate the care of patients with localized prostate carcinoma. Cancer. 2003;97(6):1428-35. No QOL outcomes. [pmid: 12627506].
394 Miller DC, Sanda MG, Dunn RL, Montie JE, Pimentel H, Sandler HM, et al. Long-term outcomes among localized prostate cancer survivors: health-related quality-of-life changes after radical prostatectomy, external radiation, and brachytherapy. Journal of Clinical Oncology. 2005;23(12):2772-80. Not localized prostate cancer. [pmid: 15837992].
395 Miller DC, Wei JT, Dunn RL, Montie JE, Pimentel H, Sandler HM, et al. Use of medications or devices for erectile dysfunction among long-term prostate cancer treatment survivors: potential influence of sexual motivation and/or indifference. Urology. Jul. 2006;68(1):166-71. No QOL outcomes. [pmid: 16844457].
396 Miller NL, Bissonette EA, Bahnson R, Wilson J, Theodorescu D. Impact of a novel neoadjuvant and adjuvant hormone-deprivation approach on quality of life, voiding function, and sexual function after prostate brachytherapy. Cancer. 2003;97(5):1203-10. Not prospective or longitudinal survey study. [pmid: 12599226].
397 Mohile SG, Bylow K, Dale W, Dignam J, Martin K, Petrylak DP, et al. A pilot study of the vulnerable elders survey-13 compared with the comprehensive geriatric assessment for identifying disability in older patients with prostate cancer who receive androgen ablation. Cancer. Feb 15. 2007;109(4):802-10. Less than 100 patients per study arm. [pmid: 17219443].
398 Moinpour CM, Lovato LC, Thompson IM Jr, Ware JE Jr, Ganz PA, Patrick DL, et al. Profile of men randomized to the prostate cancer prevention trial: baseline health-related quality of life, urinary and sexual functioning, and health behaviors. Journal of Clinical Oncology. 2000;18(9):1942-53. Not comparative treatments. [pmid: 10784636].
399 Mols F, van de Poll-Franse LV, Vingerhoets AJJM, Hendrikx A, Aaronson NK, Houterman S, et al. Long-term quality of life among Dutch prostate cancer survivors: results of a population-based study. Cancer. Nov 1. 2006;107(9):2186-96. Not localized prostate cancer. [pmid: 17013914].
400 Monahan PO, Champion V, Rawl S, Giesler RB, Given B, Given CW, et al. What contributes more strongly to predicting QOL during 1-year recovery from treatment for clinically localized prostate cancer: 4-weeks-post-treatment depressive symptoms or type of treatment?. Quality of Life Research. Apr. 2007;16(3):399-411. Not localized prostate cancer. [pmid: 17091363].
401 Monga U, Kerrigan AJ, Thornby J, Monga TN, Zimmermann KP. Longitudinal study of quality of life in patients with localized prostate cancer undergoing radiotherapy. Journal of Rehabilitation Research & Development. 2005;42(3):391-9. Less than 100 patients per study arm. [pmid: 16187251].
402 Montgomery JS, Gayed BA, Hollenbeck BK, Daignault S, Sanda MG, Montie JE, et al. Obesity adversely affects health related quality of life before and after radical retropubic prostatectomy. Journal of Urology. Jul. 2006;176(1):257-61. discussion 61–2. Not comparative treatments. [pmid: 16753415].
403 Movsas B, Scott C, Watkins-Bruner D. Pretreatment factors significantly influence quality of life in cancer patients: a Radiation Therapy Oncology Group (RTOG) analysis. International Journal of Radiation Oncology, Biology, Physics. Jul 1. 2006;65(3):830-5. Less than 100 patients per study arm.
404 Muanza TM, Albert PS, Smith S, Godette D, Crouse NS, Cooley-Zgela T, et al. Comparing measures of acute bowel toxicity in patients with prostate cancer treated with external beam radiation therapy. International Journal of Radiation Oncology, Biology, Physics. 2005;62(5):1316-21. Not comparative treatments.
405 Mulhall JP, Morgentaler A. Penile rehabilitation should become the norm for radical prostatectomy patients. J Sex Med. May. 2007;4(3):538-43. Review article. [pmid: 17498093].
406 Mulholland TL, Huynh PN, Huang RR, Wong C, Diokno AC, Peters KM. Urinary incontinence after radical retropubic prostatectomy is not related to patient body mass index. Prostate Cancer & Prostatic Diseases. 2006;9(2):153-9. Not comparative treatments. [pmid: 16505832].
407 Namiki S, Ishidoya S, Saito S, Satoh M, Tochigi T, Ioritani N, et al. Natural history of voiding function after radical retropubic prostatectomy. Urology. Jul. 2006;68(1):142-7. Not comparative treatments. [pmid: 16777193].
408 Namiki S, Ishidoya S, Tochigi T, Kawamura S, Kuwahara M, Terai A, et al. Health-related quality of life after intensity modulated radiation therapy for localized prostate cancer: comparison with conventional and conformal radiotherapy. Japanese Journal of Clinical Oncology. Apr. 2006;36(4):224-30. Less than 100 patients per study arm. [pmid: 16537689].
409 Namiki S, Kuwahara M, Ioritani N, Akito T, Arai Y. An evaluation of urinary function after radical prostatectomy in Japanese men: concordance with definitions of urinary continence. BJU International. 2005;95(4):530-3. Not comparative treatments. [pmid: 15705074].
410 Namiki S, Saito S, Nakagawa H, Sanada T, Yamada A, Arai Y. Impact of unilateral sural nerve graft on recovery of potency and continence following radical prostatectomy: 3-year longitudinal study. Journal of Urology. Jul. 2007;178(1):212-6. discussion 6. Less than 100 patients per study arm. [pmid: 17499797].
411 Namiki S, Saito S, Satoh M, Ishidoya S, Kawamura S, Tochigi T, et al. Quality of life after radical prostatectomy in Japanese men: 2 year longitudinal study. Japanese Journal of Clinical Oncology. 2005;35(9):551-8. Not comparative treatments. [pmid: 16141296].
412 Namiki S, Saito S, Tochigi T, Ioritani N, Terai A, Arai Y. Impact of salvage therapy for biochemical recurrence on health-related quality of life following radical prostatectomy. International Journal of Urology. Mar. 2007;14(3):186-91. Not comparative treatments. [pmid: 17430252].
413 Namiki S, Saito S, Tochigi T, Kuwahara M, Ioritani N, Yoshimura K, et al. Impact of hormonal therapy prior to radical prostatectomy on the recovery of quality of life. International Journal of Urology. 2005;12(2):173-81. Not localized prostate cancer. [pmid: 15733112].
414 Namiki S, Satoh T, Baba S, Ishiyama H, Hayakawa K, Saito S, et al. Quality of life after brachytherapy or radical prostatectomy for localized prostate cancer: a prospective longitudinal study. Urology. Dec. 2006;68(6):1230-6. Less than 100 patients per study arm. [pmid: 17141839].
415 Namiki S, Takegami M, Kakehi Y, Suzukamo Y, Fukuhara S, Arai Y. Analysis linking UCLA PCI with Expanded Prostate Cancer Index Composite: an evaluation of health related quality of life in Japanese men with localized prostate cancer. Journal of Urology. Aug. 2007;178(2):473-7. discussion 7. Less than 100 patients per study arm. [pmid: 17561164].
416 Namiki S, Tochigi T, Kuwahara M, Ioritani N, Terai A, Numata I, et al. Health related quality of life in Japanese men after radical prostatectomy or radiation therapy for localized prostate cancer. International Journal of Urology. 2004;11(8):619-27. Not localized prostate cancer. [pmid: 15285752].
417 Namiki S, Tochigi T, Kuwahara M, Ioritani N, Yoshimura K, Terai A, et al. Recovery of health related quality of life after radical prostatectomy in japanese men: a longitudinal study. International Journal of Urology. 2004;11(9):742-9. Not comparative treatments. [pmid: 15379938].
418 Namiki S, Tochigi T, Kuwahara M, Ohnuma T, Ioritani N, Soma F, et al. Health-related quality of life after radical prostatectomy in Japanese men with localized prostate cancer. International Journal of Urology. 2003;10(12):643-50. Not comparative treatments. [pmid: 14633067].
419 Naoe M, Ogawa Y, Shichijo T, Fuji K, Fukagai T, Yoshida H. Pilot evaluation of selective serotonin reuptake inhibitor antidepressants in hot flash patients under androgen-deprivation therapy for prostate cancer. Prostate Cancer & Prostatic Diseases. 2006;9(3):275-8. Less than 100 patients per study arm. [pmid: 16786037].
420 Natsume O, Kondo H, Cho M, Fujimoto K, Ozono S, Hirao Y. The impact of radical prostatectomy on patient well-being: a prospective urodynamic study focused on detrusor function. Hinyokika Kiyo - Acta Urologica Japonica. 2004;50(1):1-6. Not comparative treatments. [pmid: 15032007].
421 Naughton CK, Miller DC, Yan Y. Impact of transrectal ultrasound guided prostate biopsy on quality of life: a prospective randomized trial comparing 6 versus 12 cores. Journal of Urology. 2001;165(1):100-3. Not comparative treatments. [pmid: 11125374].
422 Newton F, Burney S, Frydenberg M, Millar J, Ng K. Assessing mood and general health-related quality of life among men treated in Australia for localized prostate cancer. International Journal of Urology 2007 Apr Apr;14(4):311–6. Less than 100 patients per study arm
423 Newton FJ, Burney S, Millar JL, Frydenberg M, Ng KT. Disease-specific quality of life among patients with localized prostate cancer: an Australian perspective. BJU International. Jun. 2006;97(6):1179-83. Less than 100 patients per study arm. [pmid: 16686708].
424 Nishimura K, Yamaguchi Y, Yamanaka M, Ichikawa Y, Nagano S. Climacteric-like disorders in prostate cancer patients treated with LHRH agonists. Archives of Andrology. 2005;51(1):41-8. Not comparative treatments. [pmid: 15764416].
425 Nishiyama T, Kanazawa S, Watanabe R, Terunuma M, Takahashi K. Influence of hot flashes on quality of life in patients with prostate cancer treated with androgen deprivation therapy. International Journal of Urology. 2004;11(9):735-41. Not comparative treatments. [pmid: 15379937].
426 Noguchi M, Itoh K, Yao A, Mine T, Yamada A, Obata Y, et al. Immunological evaluation of individualized peptide vaccination with a low dose of estramustine for HLA-A24+ HRPC patients. Prostate. 2005;63(1):1-12. Not localized prostate cancer. [pmid: 15378520].
427 Noguchi M, Shimada A, Yahara J, Suekane S, Noda S. Early catheter removal 3 days after radical retropubic prostatectomy. International Journal of Urology. 2004;11(11):983-8. Not comparative treatments. [pmid: 15509202].
428 Norderhaug IN, Sandberg S, Fossa SD, Forland F, Malde K, Kvinnsland S, et al. Health technology assessment and implications for clinical practice: the case of prostate cancer screening.[see comment][erratum appears in Scand J Clin Lab Invest. 2004;64(8):757]. Scandinavian Journal of Clinical & Laboratory Investigation. 2003;63(5):331-8. Not comparative treatments. [pmid: 14599155].
429 North West Uro-Oncology G. A preliminary report on a patient-preference study to compare treatment options in early prostate cancer. BJU International 2002;90(3):253–6. No QOL outcomes
430 Northouse LL, Rosset T, Phillips L, Mood D, Schafenacker A, Kershaw T. Research with families facing cancer: the challenges of accrual and retention. Res Nurs Health. Jun. 2006;29(3):199-211. Not comparative treatments. [pmid: 16676337].
431 O'Connell B, Baker L, Munro I. The nature and impact of incontinence in men who have undergone prostate surgery and implications for nursing practice. Contemp Nurse. Feb. 2007;24(1):65-78. Not comparative treatments. [pmid: 17348784].
432 Oefelein MG. Health related quality of life using serum testosterone as the trigger to re-dose long acting depot luteinizing hormone-releasing hormone agonists in patients with prostate cancer. Journal of Urology. 2003;169(1):251-5. Not localized prostate cancer. [pmid: 12478147].
433 Ohyama C, Tsuchiya N, Habuchi T, Sato K, Satoh S, Shimoda N, et al. Rectosigmoidal bladder utilizing intussuscepted ileal segment: a surgical technique for urinary diversion and experiences in 30 patients.[see comment]. International Journal of Urology. 2004;11(6):379-85. Not localized prostate cancer. [pmid: 15157206].
434 Olmi P. Limits to the radiation therapy due to age. Tumori. 2002;88(1 Suppl 1):S95-7. Review article. [pmid: 11989940].
435 Olver I, Keefe D, Myers M. Phase II study of prolonged ambulatory infusion carboplatin and oral etoposide for patients progressing through hormonal therapy for prostate cancer. Internal Medicine Journal. 2005;35(7):405-8. Less than 100 patients per study arm. [pmid: 15958110].
436 Onik G. The male lumpectomy: rationale for a cancer targeted approach for prostate cryoablation. A review. Technology in Cancer Research & Treatment. 2004;3(4):365-70. Review article. [pmid: 15270587].
437 Onik G, Narayan P, Vaughan D, Dineen M, Brunelle R. Focal “nerve-sparing” cryosurgery for treatment of primary prostate cancer: a new approach to preserving potency. Urology. 2002;60(1):109-14. Less than 100 patients per study arm. [pmid: 12100934].
438 Ozasa K, Nakao M, Watanabe Y, Hayashi K, Miki T, Mikami K, et al. Association of serum phytoestrogen concentration and dietary habits in a sample set of the JACC Study. Journal of Epidemiology. 2005;15(Suppl 2):S196-202. Not localized prostate cancer. [pmid: 16127234].
439 Pagano S, Gotay CC. Modeling quality of life in cancer patients as a unidimensional construct. Hawaii Medical Journal. 2006;65(3):76-80. Not localized prostate cancer. [pmid: 16724449].
440 Passik SD, Kirsh KL. A pilot examination of the impact of cancer patients' fatigue on their spousal caregivers. Palliat Support Care. Dec. 2005;3(4):273-9. Not localized prostate cancer. [pmid: 17039982].
441 Patel VR, Thaly R, Shah K. Robotic radical prostatectomy: outcomes of 500 cases. BJU International. May. 2007;99(5):1109-12. Not comparative treatments. [pmid: 17437441].
442 Patel VR, Tully AS, Holmes R, Lindsay J. Robotic radical prostatectomy in the community setting—the learning curve and beyond: initial 200 cases. Journal of Urology. 2005;174(1):269-72. Not comparative treatments. [pmid: 15947662].
443 Patterson RE, Neuhouser ML, Hedderson MM, Schwartz SM, Standish LJ, Bowen DJ. Changes in diet, physical activity, and supplement use among adults diagnosed with cancer. Journal of the American Dietetic Association. 2003;103(3):323-8. Not localized prostate cancer. [pmid: 12616253].
444 Patterson RE, Neuhouser ML, Hedderson MM, Schwartz SM, Standish LJ, Bowen DJ, et al. Types of alternative medicine used by patients with breast, colon, or prostate cancer: predictors, motives, and costs. Journal of Alternative & Complementary Medicine. 2002;8(4):477-85. Not localized prostate cancer. [pmid: 12230908].
445 Pearce A, Choo R, Danjoux C, Morton G, Loblaw DA, Szumacher E, et al. Effect of combined treatment with salvage radiotherapy plus androgen suppression on quality of life in patients with recurrent prostate cancer after radical prostatectomy. International Journal of Radiation Oncology, Biology, Physics. 2006;65(1):78-83. Not comparative treatments.
446 Pelucchi C, Galeone C, Talamini R, Negri E, Parpinel M, Franceschi S, et al. Dietary folate and risk of prostate cancer in Italy.[see comment]. Cancer Epidemiology, Biomarkers & Prevention. 2005;14(4):944-8. Not comparative treatments.
447 Penedo FJ, Dahn JR, Molton I, Gonzalez JS, Kinsinger D, Roos BA, et al. Cognitive-behavioral stress management improves stress-management skills and quality of life in men recovering from treatment of prostate carcinoma. Cancer. 2004;100(1):192-200. Not comparative treatments. [pmid: 14692040].
448 Penedo FJ, Dahn JR, Shen BJ, Schneiderman N, Antoni MH. Ethnicity and determinants of quality of life after prostate cancer treatment. Urology. 2006;67(5):1022-7. No QOL outcomes. [pmid: 16698362].
449 Penedo FJ, Molton I, Dahn JR, Shen BJ, Kinsinger D, Traeger L, et al. A randomized clinical trial of group-based cognitive-behavioral stress management in localized prostate cancer: development of stress management skills improves quality of life and benefit finding. Ann Behav Med. Jun. 2006;31(3):261-70. Less than 100 patients per study arm. [pmid: 16700640].
450 Penson DF, Feng Z, Kuniyuki A, McClerran D, Albertsen PC, Deapen D, et al. General quality of life 2 years following treatment for prostate cancer: what influences outcomes? Results from the prostate cancer outcomes study.[see comment]. Journal of Clinical Oncology. 2003;21(6):1147-54. Not localized prostate cancer. [pmid: 12637483].
451 Penson DF, Latini DM, Lubeck DP, Wallace K, Henning JM, Lue T. Is quality of life different for men with erectile dysfunction and prostate cancer compared to men with erectile dysfunction due to other causes? Results from the ExCEED data base.[see comment]. Journal of Urology. 2003;169(4):1458-61. Not comparative treatments. [pmid: 12629383].
452 Penson DF, Stoddard ML, Pasta DJ, Lubeck DP, Flanders SC, Litwin MS. The association between socioeconomic status, health insurance coverage, and quality of life in men with prostate cancer. Journal of Clinical Epidemiology. 2001;54(4):350-8. Not comparative treatments. [pmid: 11297885].
453 Perczek RE, Burke MA, Carver CS, Krongrad A, Terris MK. Facing a prostate cancer diagnosis: who is at risk for increased distress?. Cancer. 2002;94(11):2923-9. Not comparative treatments. [pmid: 12115380].
454 Perdona S, Autorino R, De Placido S, D'Armiento M, Gallo A, Damiano R, et al. Efficacy of tamoxifen and radiotherapy for prevention and treatment of gynaecomastia and breast pain caused by bicalutamide in prostate cancer: a randomised controlled trial. Lancet Oncology. 2005;6(5):295-300. Not comparative treatments. [pmid: 15863377].
455 Piccirillo JF. Importance of comorbidity in head and neck cancer. Laryngoscope. 2000;110(4):593-602. Not localized prostate cancer. [pmid: 10764003].
456 Pickard AS, Hung SY, McKoy JM, Witt WP, Arseven A, Sharifi R, et al. Opportunities for disease state management in prostate cancer. Disease Management. 2005;8(4):235-44. Not comparative treatments. [pmid: 16117718].
457 Pietrow PK, Parekh DJ, Smith JA Jr, Shyr Y, Cookson MS. Health related quality of life assessment after radical prostatectomy in men with prostate specific antigen only recurrence. Journal of Urology. 2001;166(6):2286-90. Not localized prostate cancer. [pmid: 11696753].
458 Pinkawa M, Fischedick K, Asadpour B, Gagel B, Piroth MD, Eble MJ. Low-grade toxicity after conformal radiation therapy for prostate cancer—impact of bladder volume. International Journal of Radiation Oncology, Biology, Physics. 2006;64(3):835-41. Not comparative treatments.
459 Pinkawa M, Fischedick K, Gagel B, Piroth MD, Borchers H, Jakse G, et al. Association of neoadjuvant hormonal therapy with adverse health-related quality of life after permanent iodine-125 brachytherapy for localized prostate cancer. Urology. Jul. 2006;68(1):104-9. Not comparative treatments. [pmid: 16806434].
460 Pinkawa M, Fischedick K, Piroth MD, Gagel B, Borchers H, Jakse G, et al. Health-related quality of life after permanent interstitial brachytherapy for prostate cancer: correlation with postimplant CT scan parameters. Strahlentherapie und Onkologie. Nov. 2006;182(11):660-5. Less than 100 patients per study arm. [pmid: 17072524].
461 Pinsky PF, Miller A, Kramer BS, Church T, Reding D, Prorok P, et al. Evidence of a healthy volunteer effect in the prostate, lung, colorectal, and ovarian cancer screening trial. Am J Epidemiol. Apr 15. 2007;165(8):874-81. Not comparative treatments. [pmid: 17244633].
462 Plante MK, Bunnell ML, Trotter SJ, Jackson TL, Esenler AC, Zvara P. Transurethral prostatic tissue ablation via a single needle delivery system: initial experience with radio-frequency energy and ethanol. Prostate Cancer & Prostatic Diseases. 2002;5(3):183-8. Not localized prostate cancer. [pmid: 12496979].
463 Ponholzer A, Brossner C, Struhal G, Marszalek M, Madersbacher S. Lower urinary tract symptoms, urinary incontinence, sexual function and quality of life after radical prostatectomy and external beam radiation therapy: real life experience in Austria. World Journal of Urology. Aug. 2006;24(3):325-30. Not localized prostate cancer. [pmid: 16688458].
464 Ponholzer A, Struhal G, Madersbacher S. Frequent use of complementary medicine by prostate cancer patients. European Urology. 2003;43(6):604-8. Not localized prostate cancer. [pmid: 12767359].
465 Porterfield H. UsToo PC-SPES surveys: review of studies and update of previous survey results. Molecular Urology. 2000;4(3):289-91. discussion 93. Not comparative treatments. [pmid: 11062386].
466 Potosky AL, Knopf K, Clegg LX, Albertsen PC, Stanford JL, Hamilton AS, et al. Quality-of-life outcomes after primary androgen deprivation therapy: results from the Prostate Cancer Outcomes Study. Journal of Clinical Oncology. 2001;19(17):3750-7. Not localized prostate cancer. [pmid: 11533098].
467 Potosky AL, Legler J, Albertsen PC, Stanford JL, Gilliland FD, Hamilton AS, et al. Health outcomes after prostatectomy or radiotherapy for prostate cancer: results from the Prostate Cancer Outcomes Study.[see comment]. Journal of the National Cancer Institute. 2000;92(19):1582-92. Previously published data updated. [pmid: 11018094].
468 Potosky AL, Reeve BB, Clegg LX, Hoffman RM, Stephenson RA, Albertsen PC, et al. Quality of life following localized prostate cancer treated initially with androgen deprivation therapy or no therapy.[see comment]. Journal of the National Cancer Institute. 2002;94(6):430-7. Previously published data updated. [pmid: 11904315].
469 Potters L, Torre T, Fearn PA, Leibel SA, Kattan MW. Potency after permanent prostate brachytherapy for localized prostate cancer. International Journal of Radiation Oncology, Biology, Physics. 2001;50(5):1235-42. Not comparative treatments.
470 Poulakis V, Witzsch U, de Vries R, Dillenburg W, Becht E. Laparoscopic radical prostatectomy in men older than 70 years of age with localized prostate cancer: comparison of morbidity, reconvalescence, and short-term clinical outcomes between younger and older men. European Urology. May. 2007;51(5):1341-8. discussion 9. Less than 100 patients per study arm. [pmid: 17184898].
471 Powel LL, Clark JA. The value of the marginalia as an adjunct to structured questionnaires: experiences of men after prostate cancer surgery. Quality of Life Research. 2005;14(3):827-35. Not comparative treatments. [pmid: 16022075].
472 Rago RP, Einstein A Jr, Lush R, Beer TM, Ko YJ, Henner WD, et al. Safety and efficacy of the MDR inhibitor Incel (biricodar, VX-710) in combination with mitoxantrone and prednisone in hormone-refractory prostate cancer. Cancer Chemotherapy & Pharmacology. 2003;51(4):297-305. Not localized prostate cancer. [pmid: 12721757].
473 Ramsawh HJ, Morgentaler A, Covino N, Barlow DH, DeWolf WC. Quality of life following simultaneous placement of penile prosthesis with radical prostatectomy. Journal of Urology. 2005;174(4 Pt 1):1395-8. Not comparative treatments. [pmid: 16145445].
474 Ramsden AR, Thurairaja R, Persad R, Chodak GW. Current trends in the management of radical retropubic prostatectomy: is short-stay RRP feasible in the United Kingdom?. Prostate Cancer & Prostatic Diseases. 2004;7(1):50-3. Not comparative treatments. [pmid: 14999239].
475 Rao J, Koay SK, Lau WK, Cheng CW. Patient-reported urinary continence (third-party interview): results of post-radical retropubic prostatectomy in Singaporeans. Asian Journal of Surgery. 2005;28(3):207-10. Not comparative treatments. [pmid: 16024318].
476 Reed SD, Radeva JI, Glendenning GA, Saad F, Schulman KA. Cost-effectiveness of zoledronic acid for the prevention of skeletal complications in patients with prostate cancer.[see comment]. Journal of Urology. 2004;171(4):1537-42. No QOL outcomes. [pmid: 15017215].
477 Reeve BB, Potosky AL, Willis GB. Should function and bother be measured and reported separately for prostate cancer quality-of-life domains?. Urology. Sep. 2006;68(3):599-603. Not comparative treatments. [pmid: 16979720].
478 Rehman J, Ragab MM, Venkatesh R, Landman J, Lee D, Chen C, et al. Laparoscopic radical prostatectomy: Washington University initial experience and prospective evaluation of quality of life. Journal of Endourology. 2004;18(3):277-87. Not comparative treatments. [pmid: 15225395].
479 Reis F, Netto NR Jr, Reinato JA, Thiel M, Zani E. The impact of prostatectomy and brachytherapy in patients with localized prostate cancer. International Urology & Nephrology. 2004;36(2):187-90. No QOL outcomes. [pmid: 15368690].
480 Richman MB, Forman EH, Bayazit Y, Einstein DB, Resnick MI, Stovsky MD. A novel computer based expert decision making model for prostate cancer disease management.[see comment]. Journal of Urology. Dec. 2005;174(6):2310-8. No QOL outcomes. [pmid: 16280831].
481 Ritvo P, Irvine J, Naglie G, Tomlinson G, Bezjak A, Matthew A, et al. Reliability and validity of the PORPUS, a combined psychometric and utility-based quality-of-life instrument for prostate cancer. Journal of Clinical Epidemiology. 2005;58(5):466-74. Not localized prostate cancer. [pmid: 15845333].
482 Roberts KJ, Lepore SJ, Helgeson V. Social-cognitive correlates of adjustment to prostate cancer. Psycho-Oncology. Mar. 2006;15(3):183-92. Less than 100 patients per study arm. [pmid: 15929030].
483 Robinson JW, Donnelly BJ, Coupland K, Siever JE, Saliken JC, Scott C, et al. Quality of life 2 years after salvage cryosurgery for the treatment of local recurrence of prostate cancer after radiotherapy. Urologic Oncology. Nov–Dec. 2006;24(6):472-86. Less than 100 patients per study arm. [pmid: 17138127].
484 Robinson JW, Donnelly BJ, Saliken JC, Weber BA, Ernst S, Rewcastle JC. Quality of life and sexuality of men with prostate cancer 3 years after cryosurgery. Urology. 2002;60(2 Suppl 1):12-8. Not comparative treatments. [pmid: 12206843].
485 Rodgers JK, Sawhney R, Chaudhary U, Bissada NK. Quality of life in men with localized prostate cancer treated by radical prostatectomy or radiotherapy. Archives of Andrology. 2006;52(2):129-33. Not prospective or longitudinal survey study. [pmid: 16443590].
486 Rodrigues G, Bauman G, Lock M, D'Souza D, Mahon J. Psychometric properties of a prostate cancer radiation late toxicity questionnaire. Health & Quality of Life Outcomes. 2007;5:29. Not comparative treatments. [pmid: 17540022].
487 Rodrigues G, Bezjak A, Osoba D, Catton P, Tsuji D, Taylor D, et al. The relationship of changes in EORTC QLQ-C30 scores to ratings on the Subjective Significance Questionnaire in men with localized prostate cancer. Quality of Life Research. 2004;13(7):1235-46. Not comparative treatments. [pmid: 15473502].
488 Rogers CG, Su LM, Link RE, Sullivan W, Wagner A, Pavlovich CP. Age stratified functional outcomes after laparoscopic radical prostatectomy. Journal of Urology. Dec. 2006;176(6 Pt 1):2448-52. Not comparative treatments. [pmid: 17085126].
489 Roos IA. Reacting to the diagnosis of prostate cancer: patient learning in a community of practice. Patient Education & Counseling. 2003;49(3):219-24. Not comparative treatments. [pmid: 12642193].
490 Ross LE, Coates RJ, Breen N, Uhler RJ, Potosky AL, Blackman D. Prostate-specific antigen test use reported in the 2000 National Health Interview Survey. Preventive Medicine. 2004;38(6):732-44. Not comparative treatments. [pmid: 15193893].
491 Ross LE, Uhler RJ, Williams KN. Awareness and use of the prostate-specific antigen test among African-American men. Journal of the National Medical Association. 2005;97(7):963-71. Not comparative treatments. [pmid: 16080666].
492 Ross PL, Littenberg B, Fearn P, Scardino PT, Karakiewicz PI, Kattan MW. Paper standard gamble: a paper-based measure of standard gamble utility for current health. International Journal of Technology Assessment in Health Care. 2003;19(1):135-47. Not comparative treatments. [pmid: 12701946].
493 Ruthman JL, Ferrans CE. Efficacy of a video for teaching patients about prostate cancer screening and treatment. American Journal of Health Promotion. 2004;18(4):292-5. Not comparative treatments. [pmid: 15011928].
494 Sadler GR, Ko CM, Malcarne VL, Banthia R, Gutierrez I, Varni JW. Costs of recruiting couples to a clinical trial. Contemp Clin Trials. Jul. 2007;28(4):423-32. No QOL outcomes. [pmid: 17218166].
495 Saigal CS, Gornbein J, Nease R, Litwin MS. Predictors of utilities for health states in early stage prostate cancer. Journal of Urology. 2001;166(3):942-6. Not comparative treatments. [pmid: 11490251].
496 Saigal CS, Gornbein J, Reid K, Litwin MS. Stability of time trade-off utilities for health states associated with the treatment of prostate cancer. Quality of Life Research. 2002;11(5):405-14. Not comparative treatments. [pmid: 12113388].
497 Saito S, Namiki S, Numahata K, Satoh M, Ishidoya S, Ito A, et al. Relevance of postcatheter removal incontinence to postoperative urinary function after radical prostatectomy. International Journal of Urology. Sep. 2006;13(9):1191-6. Less than 100 patients per study arm. [pmid: 16984551].
498 Salminen E, Portin R, Korpela J, Backman H, Parvinen LM, Helenius H, et al. Androgen deprivation and cognition in prostate cancer. British Journal of Cancer. 2003;89(6):971-6. No QOL outcomes. [pmid: 12966411].
499 Salminen EK, Portin RI, Koskinen A, Helenius H, Nurmi M. Associations between serum testosterone fall and cognitive function in prostate cancer patients. Clinical Cancer Research. 2004;10(22):7575-82. No QOL outcomes. [pmid: 15569988].
500 Salomon L, Anastasiadis A, Saint F, De La Taille A, Chopin D, Abbou CC. Introducing a new, simple scoring system to evaluate oncological and functional outcome after radical prostatectomy. Scandinavian Journal of Urology & Nephrology. 2003;37(5):392-5. Not comparative treatments. [pmid: 14594687].
501 Salomon L, Saint F, Anastasiadis AG, Sebe P, Chopin D, Abbou CC. Combined reporting of cancer control and functional results of radical prostatectomy. European Urology. 2003;44(6):656-60. Not comparative treatments. [pmid: 14644116].
502 Sanchez-Ortiz RF, Broderick GA, Rovner ES, Wein AJ, Whittington R, Malkowicz SB. Erectile function and quality of life after interstitial radiation therapy for prostate cancer. International Journal of Impotence Research. 2000;12(Suppl 3):S18-24. Not comparative treatments. [pmid: 11002395].
503 Sandblom G, Carlsson P, Sennfalt K, Varenhorst E. A population-based study of pain and quality of life during the year before death in men with prostate cancer. British Journal of Cancer. 2004;90(6):1163-8. Not comparative treatments. [pmid: 15026796].
504 Sandblom G, Carlsson P, Sigsjo P, Varenhorst E. Pain and health-related quality of life in a geographically defined population of men with prostate cancer. British Journal of Cancer. 2001;85(4):497-503. Not comparative treatments. [pmid: 11506486].
505 Sanders S, Pedro LW, Bantum EOC, Galbraith ME. Couples surviving prostate cancer: Long-term intimacy needs and concerns following treatment. Clin J Oncol Nurs. Aug. 2006;10(4):503-8. Not comparative treatments. [pmid: 16927903].
506 Sanderson KM, Penson DF, Cai J, Groshen S, Stein JP, Lieskovsky G, et al. Salvage radical prostatectomy: quality of life outcomes and long-term oncological control of radiorecurrent prostate cancer. Journal of Urology. Nov. 2006;176(5):2025-31. discussion 31–2. Not comparative treatments. [pmid: 17070244].
507 Santis WF, Hoffman MA, Dewolf WC. Early catheter removal in 100 consecutive patients undergoing radical retropubic prostatectomy. BJU International. 2000;85(9):1067-8. Not comparative treatments. [pmid: 10848696].
508 Sarma AV, McLaughlin JC, Jacobsen SJ, Logie J, Dolin P, Dunn RL, et al. Longitudinal changes in lower urinary tract symptoms among a cohort of black American men: the Flint Men's Health Study. Urology. 2004;64(5):959-65. Not localized prostate cancer. [pmid: 15533486].
509 Sarosdy MF. Urinary and rectal complications of contemporary permanent transperineal brachytherapy for prostate carcinoma with or without external beam radiation therapy.[see comment]. Cancer. 2004;101(4):754-60. Less than 100 patients per study arm. [pmid: 15305406].
510 Savard J, Simard S, Hervouet S, Ivers H, Lacombe L, Fradet Y. Insomnia in men treated with radical prostatectomy for prostate cancer. Psycho-Oncology. 2005;14(2):147-56. Not comparative treatments. [pmid: 15386779].
511 Schmid HP, Morant R, Bernhard J, Maibach R. Swiss Group for Clinical Cancer R. Prostate specific antigen doubling time as auxiliary end point in hormone refractory prostatic carcinoma. European Urology. 2003;43(1):28-30. Not localized prostate cancer. [pmid: 12507540].
512 Scholz MC, Jennrich RI, Strum SB, Johnson HJ, Guess BW, Lam RY. Intermittent use of testosterone inactivating pharmaceuticals using finasteride prolongs the time off period. Journal of Urology. 2006;175(5):1673-8. Not comparative treatments. [pmid: 16600727].
513 Schroder FH, Wildhagen MF. Rotterdam Study Group of the 'European Randomised Study of Screening for Prostate C. Screening for prostate cancer: evidence and perspectives. BJU International. 2001;88(8):811-7. Not comparative treatments. [pmid: 11736853].
514 Schuster TG, Marcovich R, Sheffield J, Montie JE, Lee CT. Radical cystectomy for bladder cancer after definitive prostate cancer treatment. Urology. 2003;61(2):342-7. discussion 7. Not localized prostate cancer. [pmid: 12597943].
515 Sciarra A, Cardi A, Salvatori G, D'Eramo G, Mariotti G, Di Silverio F. Which patients with prostate cancer are actually candidates for hormone therapy?. International Braz J Urol. 2004;30(6):455-65. Not comparative treatments. [pmid: 15663802].
516 Seftel A. Sexual, psychological and dyadic qualities of the prostate cancer ‘couple’. Journal of Urology. 2005;174(5):1939. Review article.
517 Segal RJ, Reid RD, Courneya KS, Malone SC, Parliament MB, Scott CG, et al. Resistance exercise in men receiving androgen deprivation therapy for prostate cancer.[see comment]. Journal of Clinical Oncology. 2003;21(9):1653-9. Not comparative treatments. [pmid: 12721238].
518 Seki N, Tatsugami K, Naito S. Holmium laser enucleation of the prostate: comparison of outcomes according to prostate size in 97 Japanese patients. Journal of Endourology. Feb. 2007;21(2):192-6. Not comparative treatments. [pmid: 17338621].
519 Selek U, Cheung R, Lii M, Allen P, Steadham RE, Vantreese TR Jr, et al. Erectile dysfunction and radiation dose to penile base structures: a lack of correlation.[see comment]. International Journal of Radiation Oncology, Biology, Physics. 2004;59(4):1039-46. Not comparative treatments.
520 Selli C, De Antoni P, Moro U, Macchiarella A, Giannarini G, Crisci A. Role of bladder neck preservation in urinary continence following radical retropubic prostatectomy. Scandinavian Journal of Urology & Nephrology. 2004;38(1):32-7. Not comparative treatments. [pmid: 15204424].
521 Sennfalt K, Carlsson P, Sandblom G, Varenhorst E. The estimated economic value of the welfare loss due to prostate cancer pain in a defined population. Acta Oncologica. 2004;43(3):290-6. No QOL outcomes. [pmid: 15244254].
522 Shah SH. A patient with dementia and cancer: to feed via percutaneous endoscopic gastrostomy tube or not?. Palliat Med. Oct. 2006;20(7):711-4. Not localized prostate cancer. [pmid: 17060270].
523 Shapiro PJ, Coyne JC, Kruus LK, Palmer SC, Vaughn DJ, Malkowicz SB. Interest in services among prostate cancer patients receiving androgen deprivation therapy. Psycho-Oncology. 2004;13(8):512-25. No QOL outcomes. [pmid: 15295773].
524 Sharkey J, Cantor A, Solc Z, Huff W, Chovnick SD, Behar RJ, et al. Brachytherapy versus radical prostatectomy in patients with clinically localized prostate cancer. Current Urology Reports. 2002;3(3):250-7. No QOL outcomes. [pmid: 12084197].
525 Sheriff SK, Shohara RA, Dumican SB, Small EJ, Carroll PR, Chan JM. Lifestyle correlates of health perception and treatment satisfaction in a clinical cohort of men with prostate cancer. Clinical Prostate Cancer. 2005;3(4):239-45. Not comparative treatments. [pmid: 15882480].
526 Simon HB. On call. September 11 was an emotional day for all of us, but September 12 was a confusing day for me. I read two newspapers that reported on research in the New England Journal of Medicine. The New York Times headline said: “Prostate cancer surgery found to cut death risk,” but the Washington Post announced: “Studies find no advantage to prostate cancer surgery.” Which was right?. Harvard Mens Health Watch. 2002;7(5):8. Review article. [pmid: 12356554].
527 Singh H, Maskarinec G, Shumay DM. Understanding the motivation for conventional and complementary/alternative medicine use among men with prostate cancer. Integrative Cancer Therapies. 2005;4(2):187-94. Not comparative treatments. [pmid: 15911931].
528 Sloan JA, Varricchio C. Quality of Life endpoints in prostate chemoprevention trials. Urology. 2001;57(4 Suppl 1):235-40. Not comparative treatments. [pmid: 11295635].
529 Small EJ, Meyer M, Marshall ME, Reyno LM, Meyers FJ, Natale RB, et al. Suramin therapy for patients with symptomatic hormone-refractory prostate cancer: results of a randomized phase III trial comparing suramin plus hydrocortisone to placebo plus hydrocortisone. Journal of Clinical Oncology. 2000;18(7):1440-50. Not localized prostate cancer. [pmid: 10735891].
530 Smith DP, Supramaniam R, King MT, Ward J, Berry M, Armstrong BK. Age, health, and education determine supportive care needs of men younger than 70 years with prostate cancer. Journal of Clinical Oncology. Jun 20. 2007;25(18):2560-6. Not comparative treatments. [pmid: 17577034].
531 Smith DS, Carvalhal GF, Schneider K, Krygiel J, Yan Y, Catalona WJ. Quality-of-life outcomes for men with prostate carcinoma detected by screening. Cancer. 2000;88(6):1454-63. Not comparative treatments. [pmid: 10717630].
532 Smith DS, Krygiel J, Nease RF Jr, Sumner W 2nd, Catalona WJ. Patient preferences for outcomes associated with surgical management of prostate cancer. Journal of Urology. 2002;167(5):2117-22. Not comparative treatments. [pmid: 11956454].
533 Soloway CT, Soloway MS, Kim SS, Kava BR. Sexual, psychological and dyadic qualities of the prostate cancer ‘couple’. BJU International. 2005;95(6):780-5. Not comparative treatments. [pmid: 15794782].
534 Soumarova R, Homola L, Stursa M, Perkova H. Acute toxicity of conformal high dose interstitial brachytherapy boost in prostate cancer. Neoplasma. 2006;53(5):410-7. Not localized prostate cancer. [pmid: 17013535].
535 Speight JL, Elkin EP, Pasta DJ, Silva S, Lubeck DP, Carroll PR, et al. Longitudinal assessment of changes in sexual function and bother in patients treated with external beam radiotherapy or brachytherapy, with and without neoadjuvant androgen ablation: data from CaPSURE. International Journal of Radiation Oncology, Biology, Physics. 2004;60(4):1066-75. CaPSURE data.
536 Spry NA, Kristjanson L, Hooton B, Hayden L, Neerhut G, Gurney H, et al. Adverse effects to quality of life arising from treatment can recover with intermittent androgen suppression in men with prostate cancer. European Journal of Cancer. May. 2006;42(8):1083-92. Not comparative treatments. [pmid: 16632343].
537 Srinualnad S, Charoenkraikamol C, Toraksa S, Uiprasertkul M, Amornvesukit T, Taweemonkongsap T, et al. Prevalence of prostate cancer in aging males receiving PSA (prostate specific antigen) screening test (A campaign for celebration of Siriraj Established Day). Journal of the Medical Association of Thailand. 2006;89(1):37-42. Not comparative treatments. [pmid: 16583579].
538 Staff I, Salner A, Bohannon R, Panatieri P, Maljanian R. Disease-specific symptoms and general quality of life of patients with prostate carcinoma before and after primary three-dimensional conformal radiotherapy. Cancer. 2003;98(11):2335-43. Not comparative treatments. [pmid: 14635067].
539 Stamogiannou I, Grunfeld EA, Denison K, Muir G. Beliefs about illness and quality of life among men with erectile dysfunction. International Journal of Impotence Research. 2005;17(2):142-7. Not localized prostate cancer. [pmid: 15014554].
540 Stavridis S, Georgiev V, Popov Z, Penev M, Lekovski Lj, Stankov O, et al. Radical retropubic prostatectomy for prostate carcinoma; first results of the Clinic of Urology in Skopje. Acta Chirurgica Iugoslavica. 2005;52(4):37-40. Not comparative treatments. [pmid: 16673592].
541 Steginga SK, Occhipinti S, Gardiner RA, Yaxley J, Heathcote P. Prospective study of men's psychological and decision-related adjustment after treatment for localized prostate cancer. Urology. 2004;63(4):751-6. Less than 100 patients per study arm. [pmid: 15072894].
542 Steginga SK, Pinnock C, Gardner M, Gardiner RA, Dunn J. Evaluating peer support for prostate cancer: the Prostate Cancer Peer Support Inventory. BJU International. 2005;95(1):46-50. Not comparative treatments. [pmid: 15663527].
543 Steiner MS, Pound CR. Phase IIA clinical trial to test the efficacy and safety of Toremifene in men with high-grade prostatic intraepithelial neoplasia.[see comment]. Clinical Prostate Cancer. 2003;2(1):24-31. Not localized prostate cancer. [pmid: 15046680].
544 Stewart SL, King JB, Thompson TD, Friedman C, Wingo PA. Cancer mortality surveillance—United States, 1990-2000. Morbidity & Mortality Weekly Report 2004;Surveillance Summaries. 53(3):1–108. No QOL outcomes
545 Stewart ST, Lenert L, Bhatnagar V, Kaplan RM. Utilities for prostate cancer health states in men aged 60 and older. Medical Care. 2005;43(4):347-55. Not comparative treatments. [pmid: 15778638].
546 Stojanovic S, Radosvic-Jelic Lj, Tulic C, Popov I, Babic D, Acimovic M, et al. Radical radiotherapy for localized prostate cancer in elderly. Acta Chirurgica Iugoslavica. 2005;52(4):103-7. Not comparative treatments. [pmid: 16673605].
547 Stommel M, Kurtz ME, Kurtz JC, Given CW, Given BA. A longitudinal analysis of the course of depressive symptomatology in geriatric patients with cancer of the breast, colon, lung, or prostate. Health Psychology. 2004;23(6):564-73. Not localized prostate cancer. [pmid: 15546224].
548 Stone NN, Stock RG. Prospective assessment of patient-reported long-term urinary morbidity and associated quality of life changes after 125I prostate brachytherapy. Brachytherapy. 2003;2(1):32-9. Not comparative treatments. [pmid: 15062161].
549 Stone NN, Stock RG. Practical considerations in permanent brachytherapy for localized adenocarcinoma of the prostate. Urologic Clinics of North America. 2003;30(2):351-62. Not comparative treatments. [pmid: 12735510].
550 Stone NN, Stock RG. Long-term urinary, sexual, and rectal morbidity in patients treated with iodine-125 prostate brachytherapy followed up for a minimum of 5 years. Urology. Feb. 2007;69(2):338-42. Not comparative treatments. [pmid: 17320674].
551 Stone P, Hardy J, Huddart R, A'Hern R, Richards M. Fatigue in patients with prostate cancer receiving hormone therapy. European Journal of Cancer. 2000;36(9):1134-41. Not comparative treatments. [pmid: 10854947].
552 Stone P, Richards M, A'Hern R, Hardy J. Fatigue in patients with cancers of the breast or prostate undergoing radical radiotherapy. Journal of Pain & Symptom Management. 2001;22(6):1007-15. Not localized prostate cancer. [pmid: 11738163].
553 Stranzl H, Gabor S, Mayer R, Prettenhofer U, Wurzinger G, Hackl A. Fractionated intraluminal HDR 192Ir brachytherapy as palliative treatment in patients with endobronchial metastases from non-bronchogenic primaries. Strahlentherapie und Onkologie. 2002;178(8):442-5. Not localized prostate cancer. [pmid: 12240550].
554 Studer UE, Hauri D, Hanselmann S, Chollet D, Leisinger HJ, Gasser T, et al. Immediate versus deferred hormonal treatment for patients with prostate cancer who are not suitable for curative local treatment: results of the randomized trial SAKK 08/88.[erratum appears in J Clin Oncol. 2005 Feb 1;23(4):936]. Journal of Clinical Oncology. 2004;22(20):4109-18. Not localized prostate cancer. [pmid: 15483020].
555 Sullivan LD, Weir MJ, Kinahan JF, Taylor DL. A comparison of the relative merits of radical perineal and radical retropubic prostatectomy. BJU International. 2000;85(1):95-100. Less than 100 patients per study arm. [pmid: 10619954].
556 Sunny L, Hopfgarten T, Adolfsson J, Steineck G. Economic conditions and marriage quality of men with prostate cancer. BJU International. Jun. 2007;99(6):1391-7. Not comparative treatments. [pmid: 17355370].
557 Sweeney CJ. ECOG: CHAARTED—ChemoHormonal therapy versus androgen ablation randomized trial for extensive disease in prostate cancer. Clin. Aug. 2006;4(8):588-90. Not localized prostate cancer.
558 Sydes MR, Stephens RJ, Moore AR, Aird EG, Bidmead AM, Fallowfield LJ, et al. Implementing the UK Medical Research Council (MRC) RT01 trial (ISRCTN 47772397): methods and practicalities of a randomised controlled trial of conformal radiotherapy in men with localised prostate cancer. Radiotherapy & Oncology. 2004;72(2):199-211. No QOL outcomes. [pmid: 15297138].
559 Symon Z, Daignault S, Symon R, Dunn RL, Sanda MG, Sandler HM. Measuring patients' expectations regarding health-related quality-of-life outcomes associated with prostate cancer surgery or radiotherapy. Urology. Dec. 2006;68(6):1224-9. Less than 100 patients per study arm. [pmid: 17141840].
560 Talcott JA, Clark JA, Manola J, Mitchell SP. Bringing prostate cancer quality of life research back to the bedside: translating numbers into a format that patients can understand. Journal of Urology. Oct. 2006;176(4 Pt 1):1558-63. discussion 63–4. Previously published data. [pmid: 16952681].
561 Talcott JA, Manola J, Clark JA, Kaplan I, Beard CJ, Mitchell SP, et al. Time course and predictors of symptoms after primary prostate cancer therapy. Journal of Clinical Oncology. 2003;21(21):3979-86. Not RCT. [pmid: 14581420].
562 Tangen CM, Goodman PJ, Crowley JJ, Thompson IM. Statistical design issues and other practical considerations for conducting phase III prostate cancer prevention trials. Journal of Urology. 2004;171(2 Pt 2):S64-7. No QOL outcomes. [pmid: 14713757].
563 Tannor BB, Ross L. Physician-patient discussions about prostate-specific antigen test use among African-American men. Journal of the National Medical Association. 2006;98(4):532-8. Not comparative treatments. [pmid: 16623065].
564 Taussky D, Schneider U, Rousson V, Pescia R. Patient-reported toxicity correlated to dose-volume histograms of the rectum in radiotherapy of the prostate. American Journal of Clinical Oncology. 2003;26(5):e144-9. Not comparative treatments. [pmid: 14528089].
565 Taylor KL, Shelby R, Gelmann E, McGuire C. Quality of life and trial adherence among participants in the prostate, lung, colorectal, and ovarian cancer screening trial.[see comment]. Journal of the National Cancer Institute. 2004;96(14):1083-94. Not localized prostate cancer. [pmid: 15265970].
566 Templeton H, Coates V. Evaluation of an evidence-based education package for men with prostate cancer on hormonal manipulation therapy. Patient Education & Counseling. 2004;55(1):55-61. Not comparative treatments. [pmid: 15476990].
567 Terret C, Albrand G, Droz JP. Geriatric assessment in elderly patients with prostate cancer. Clinical Prostate Cancer. 2004;2(4):236-40. Not comparative treatments. [pmid: 15072607].
568 Tewari A, Kaul S, Menon M. Robotic radical prostatectomy: a minimally invasive therapy for prostate cancer. Current Urology Reports. 2005;6(1):45-8. Not comparative treatments. [pmid: 15610696].
569 Tewari A, Menon M. Vattikuti Institute prostatectomy: surgical technique and current results. Current Urology Reports. 2003;4(2):119-23. Not comparative treatments. [pmid: 12648428].
570 Tewari A, Srivasatava A, Menon M. Members of the VIPT. A prospective comparison of radical retropubic and robot-assisted prostatectomy: experience in one institution. BJU International. 2003;92(3):205-10. Not RCT. [pmid: 12887468].
571 Thompson RH, Slezak JM, Webster WS, Lieber MM. Radical prostatectomy for octogenarians: how old is too old?. Urology. Nov. 2006;68(5):1042-5. Not comparative treatments. [pmid: 17095073].
572 Thornton AA, Perez MA. Posttraumatic growth in prostate cancer survivors and their partners. Psycho-Oncology. Apr. 2006;15(4):285-96. Not comparative treatments. [pmid: 16035136].
573 Thuroff S, Chaussy C. High-intensity focused ultrasound: complications and adverse events. Molecular Urology. 2000;4(3):183-7. discussion 9. Not comparative treatments. [pmid: 11062373].
574 Tiffany NM, Wersinger EM, Garzotto M, Beer TM. Imatinib mesylate and zoledronic acid in androgen-independent prostate cancer.[see comment]. Urology. 2004;63(5):934-9. Not localized prostate cancer. [pmid: 15134984].
575 Truong PT, Berthelet E, Lee JC, Petersen R, Lim JTW, Gaul CA, et al. Prospective evaluation of the prevalence and severity of fatigue in patients with prostate cancer undergoing radical external beam radiotherapy and neoadjuvant hormone therapy. Canadian Journal of Urology. Jun. 2006;13(3):3139-46. Not comparative treatments. [pmid: 16813705].
576 Tsai HK, Manola J, Abner A, Talcott JA, D'Amico AV, Beard C. Patient-reported acute gastrointestinal toxicity in men receiving 3-dimensional conformal radiation therapy for prostate cancer with or without neoadjuvant androgen suppression therapy. Urologic Oncology. 2005;23(4):230-7. Less than 100 patients per study arm. [pmid: 16018937].
577 Turk IA, Deger S, Morgan WR, Davis JW, Schellhammer PF, Loening SA. Sural nerve graft during laparoscopic radical prostatectomy. Initial experience. Urologic Oncology. 2002;7(5):191-4. Not comparative treatments. [pmid: 12644215].
578 Uchida T, Baba S, Irie A, Soh S, Masumori N, Tsukamoto T, et al. Transrectal high-intensity focused ultrasound in the treatment of localized prostate cancer: a multicenter study. Hinyokika Kiyo - Acta Urologica Japonica. 2005;51(10):651-8. Not comparative treatments. [pmid: 16285617].
579 Ueda T, Suzuki H, Akakura K, Ishihara M, Kamiya N, Komiya A, et al. Bisphosphonate and low-dose dexamethasone treatment for patients with hormone-refractory prostate cancer. Hinyokika Kiyo - Acta Urologica Japonica. Jul. 2006;52(7):515-21. Not comparative treatments. [pmid: 16910582].
580 Ukoli FA, Lynch BS, Adams-Campbell LL. Radical prostatectomy and quality of life among African Americans. Ethn Dis. 2006;16(4):988-93. Not comparative treatments. [pmid: 17061757].
581 Unger JM, LeBlanc M, Thompson IM, Coltman CA Jr. The person-years saved model and other methodologies for assessing the population impact of cancer-prevention strategies. Urologic Oncology. 2004;22(4):362-8. Not comparative treatments. [pmid: 15283898].
582 Valdimarsdottir U, Helgason AR, Furst CJ, Adolfsson J, Steineck G. The unrecognised cost of cancer patients' unrelieved symptoms:a nationwide follow-up of their surviving partners. British Journal of Cancer. 2002;86(10):1540-5. Not localized prostate cancer. [pmid: 12085201].
583 Valdimarsdottir U, Helgason AR, Furst CJ, Adolfsson J, Steineck G. Long-term effects of widowhood after terminal cancer: a Swedish nationwide follow-up. Scandinavian Journal of Public Health. 2003;31(1):31-6. Not localized prostate cancer. [pmid: 12623522].
584 Vale J. Erectile dysfunction following radical therapy for prostate cancer. Radiotherapy & Oncology. 2000;57(3):301-5. Review article. [pmid: 11104890].
585 van Andel G, Kurth KH. The impact of androgen deprivation therapy on health related quality of life in asymptomatic men with lymph node positive prostate cancer. European Urology. 2003;44(2):209-14. Not localized prostate cancer. [pmid: 12875940].
586 Van Andel G, Visser AP, Hulshof MC, Horenblas S, Kurth KH. Health-related quality of life and psychosocial factors in patients with prostate cancer scheduled for radical prostatectomy or external radiation therapy. BJU International. 2003;92(3):217-22. Not localized prostate cancer. [pmid: 12887470].
587 van Andel G, Visser AP, Zwinderman AH, Hulshof MC, Horenblas S, Kurth KH. A prospective longitudinal study comparing the impact of external radiation therapy with radical prostatectomy on health related quality of life (HRQOL) in prostate cancer patients. Prostate. 2004;58(4):354-65. Less than 100 patients per study arm. [pmid: 14968436].
588 van Dis FW, Mols F, Vingerhoets AJJM, Ferrell B, van de Poll-Franse LV. A validation study of the Dutch version of the Quality of Life-Cancer Survivor (QOL-CS) questionnaire in a group of prostate cancer survivors. Quality of Life Research. Dec. 2006;15(10):1607-12. Not localized prostate cancer. [pmid: 16826441].
589 Van Gellekom MP, Moerland MA, Van Vulpen M, Wijrdeman HK, Battermann JJ. Quality of life of patients after permanent prostate brachytherapy in relation to dosimetry. International Journal of Radiation Oncology, Biology, Physics. 2005;63(3):772-80. Not comparative treatments.
590 van Haarst EP, Heldeweg EA, Newling DW, Schlatmann TJ. A cross-sectional study of the international prostate symptom scores related to age and gender in Dutch adults reporting no voiding complaints. European Urology. 2005;47(3):334-9. Not comparative treatments. [pmid: 15716197].
591 Van Steen K, Curran D, Molenberghs G. Sensitivity analysis of longitudinal binary quality of life data with drop-out: an example using the EORTC QLQ-C30. Statistics in Medicine. 2001;20(24):3901-20. Not localized prostate cancer. [pmid: 11782042].
592 van Tol-Geerdink JJ, Stalmeier PFM, van Lin ENJT, Schimmel EC, Huizenga H, van Daal WAJ, et al. Do patients with localized prostate cancer treatment really want more aggressive treatment?. Journal of Clinical Oncology. Oct 1. 2006;24(28):4581-6. Not localized prostate cancer. [pmid: 17008699].
593 Visser A, van Andel G, Willems P, Voogt E, Dijkstra A, Rovers P, et al. Changes in health-related quality of life of men with prostate cancer 3 months after diagnosis: the role of psychosocial factors and comparisment with benign prostate hyperplasia patients. Patient Education & Counseling. 2003;49(3):225-32. Not comparative treatments. [pmid: 12642194].
594 Voerman B, Fischer M, Visser A, Garssen B, van Andel G, Bensing J. Health-related quality of life in Dutch men with prostate cancer. J Psychosoc Oncol. 2006;24(2):49-64. Not localized prostate cancer. [pmid: 17046806].
595 Vogel CL, Yanagihara RH, Wood AJ, Schnell FM, Henderson C, Kaplan BH, et al. Safety and pain palliation of zoledronic acid in patients with breast cancer, prostate cancer, or multiple myeloma who previously received bisphosphonate therapy. Oncologist. 2004;9(6):687-95. Not localized prostate cancer. [pmid: 15561812].
596 Vojkovic SJ, Kristjanson LJ. Case study report of two palliative care patients receiving intracerebroventricular (ICV) analgesia. Journal of Palliative Care. 2003;19(4):280-3. Not localized prostate cancer. [pmid: 14959600].
597 Vordermark D, Schwab M, Flentje M, Sailer M, Kolbl O. Chronic fatigue after radiotherapy for carcinoma of the prostate: correlation with anorectal and genitourinary function. Radiotherapy & Oncology. 2002;62(3):293-7. Not localized prostate cancer. [pmid: 12175560].
598 Vordermark D, Wulf J, Markert K, Baier K, Kolbl O, Beckmann G, et al. 3-D conformal treatment of prostate cancer to 74 Gy vs. high-dose-rate brachytherapy boost: a cross-sectional quality-of-life survey. Acta Oncologica. 2006;45(6):708-16. Less than 100 patients per study arm. [pmid: 16938814].
599 Votron L, D'Hoore W, Swine C, Daisne JF, Scalliet P. The opinion of general practitioners on the treatment of prostate and breast cancer in elderly people: results of a survey based on clinical models. Clinical Oncology (Royal College of Radiologists). 2004;16(7):474-8. Not localized prostate cancer.
600 Wahlgren T, Brandberg Y, Haggarth L, Hellstrom M, Nilsson S. Health-related quality of life in men after treatment of localized prostate cancer with external beam radiotherapy combined with (192)ir brachytherapy: a prospective study of 93 cases using the EORTC questionnaires QLQ-C30 and QLQ-PR25. International Journal of Radiation Oncology, Biology, Physics. 2004;60(1):51-9. Not comparative treatments.
601 Wallace M. Uncertainty and quality of life of older men who undergo watchful waiting for prostate cancer. Oncology Nursing Forum 2003;Online. 30(2):303–9. Not comparative treatments
602 Walsh PC. Radical prostatectomy for localized prostate cancer provides durable cancer control with excellent quality of life: a structured debate.[see comment]. Journal of Urology. 2000;163(6):1802-7. Not comparative treatments. [pmid: 10799186].
603 Walsh PC. Sexual function and bother after radical prostatectomy or radiation for prostate cancer: multivariate quality-of-life analysis from CaPSURE. Journal of Urology. 2000;163(1):370. CaPSURE data. [pmid: 10604391].
604 Walsh PC, Marschke PL. Intussusception of the reconstructed bladder neck leads to earlier continence after radical prostatectomy. Urology. 2002;59(6):934-8. Not comparative treatments. [pmid: 12031385].
605 Walter LC, Bertenthal D, Lindquist K, Konety BR. PSA screening among elderly men with limited life expectancies. JAMA. Nov 15. 2006;296(19):2336-42. Not comparative treatments. [pmid: 17105796].
606 Wang H, Huang E, Dale W, Campbell T, Ignacio L, Kopnick M, et al. Self-assessed health-related quality of life in men who have completed radiotherapy for prostate cancer: instrument validation and its relation to patient-assessed bother of symptoms. International Journal of Cancer. 2000;90(3):163-72. Not comparative treatments. [pmid: 10900429].
607 Wang L, Hricak H, Kattan MW, Chen HN, Kuroiwa K, Eisenberg HF, et al. Prediction of seminal vesicle invasion in prostate cancer: incremental value of adding endorectal MR imaging to the Kattan nomogram. Radiology. Jan. 2007;242(1):182-8. Not localized prostate cancer. [pmid: 17090712].
608 Wang LG, Mencher SK, McCarron JP, Ferrari AC. The biological basis for the use of an anti-androgen and a 5-alpha-reductase inhibitor in the treatment of recurrent prostate cancer: Case report and review. Oncology Reports. 2004;11(6):1325-9. Less than 100 patients per study arm. [pmid: 15138573].
609 Warde P, Tsuji D, Bristow R. A randomized phase III study of neoadjuvant hormonal therapy in patients with localized prostate cancer. Clin Genitourin Cancer. Dec. 2006;5(3):235-7. No QOL outcomes. [pmid: 17239279].
610 Ward-Smith P. Brachytherapy for prostate cancer: the patient's perspective. Urologic Nursing. 2003;23(3):213-7. Not comparative treatments. [pmid: 12861739].
611 Ward-Smith P, Kapitan D. Quality of life among men treated with radiation therapy for prostate cancer. Urologic Nursing. 2005;25(4):263-8. Not comparative treatments. [pmid: 16225343].
612 Ward-Smith P, Wittkopp D, Sheldon JM. Quality of life among men treated with brachytherapy for prostate cancer. Urologic Nursing. 2004;24(2):95-9. Not comparative treatments. [pmid: 15131916].
613 Wei JT, Dunn RL, Litwin MS, Sandler HM, Sanda MG. Development and validation of the expanded prostate cancer index composite (EPIC) for comprehensive assessment of health-related quality of life in men with prostate cancer. Urology. 2000;56(6):899-905. Validation study. [pmid: 11113727].
614 Wei JT, Dunn RL, Sandler HM, McLaughlin PW, Montie JE, Litwin MS, et al. Comprehensive comparison of health-related quality of life after contemporary therapies for localized prostate cancer.[see comment]. Journal of Clinical Oncology. 2002;20(2):557-66. Not prospective or longitudinal survey study. [pmid: 11786586].
615 Wernicke AG, Valicenti R, Dieva K, Houser C, Pequignot E. Radiation dose delivered to the proximal penis as a predictor of the risk of erectile dysfunction after three-dimensional conformal radiotherapy for localized prostate cancer. International Journal of Radiation Oncology, Biology, Physics. 2004;60(5):1357-63. Not comparative treatments.
616 Widmark A, Fossa SD, Lundmo P, Damber JE, Vaage S, Damber L, et al. Does prophylactic breast irradiation prevent antiandrogen-induced gynecomastia? Evaluation of 253 patients in the randomized Scandinavian trial SPCG-7/SFUO-3.[see comment]. Urology. 2003;61(1):145-51. No QOL outcomes. [pmid: 12559286].
617 Wilkinson S, Gomella LG, Smith JA, Brawer MK, Dawson NA, Wajsman Z, et al. Attitudes and use of complementary medicine in men with prostate cancer. Journal of Urology. 2002;168(6):2505-9. Not localized prostate cancer. [pmid: 12441950].
618 Willener R, Hantikainen V. Individual quality of life following radical prostatectomy in men with prostate cancer. Urologic Nursing. 2005;25(2):88-90. Not comparative treatments. [pmid: 15900977].
619 Windsor PM, Nicol KF, Potter J. A randomized, controlled trial of aerobic exercise for treatment-related fatigue in men receiving radical external beam radiotherapy for localized prostate carcinoma. Cancer. 2004;101(3):550-7. Not comparative treatments. [pmid: 15274068].
620 Winquist E, Waldron T, Berry S, Ernst DS, Hotte S, Lukka H. Non-hormonal systemic therapy in men with hormone-refractory prostate cancer and metastases: a systematic review from the Cancer Care Ontario Program in Evidence-based Care's Genitourinary Cancer Disease Site Group. BMC Cancer. 2006;6:112. Review article. [pmid: 16670021].
621 Wiygul JB, Evans BR, Peterson BL, Polascik TJ, Walther PJ, Robertson CN, et al. Supplement use among men with prostate cancer. Urology. 2005;66(1):161-6. Not localized prostate cancer. [pmid: 15992901].
622 Woel R, Beard C, Chen MH, Hurwitz M, Loffredo M, McMahon E, et al. Acute gastrointestinal, genitourinary, and dermatological toxicity during dose-escalated 3D-conformal radiation therapy (3DCRT) using an intrarectal balloon for prostate gland localization and immobilization. International Journal of Radiation Oncology, Biology, Physics. 2005;62(2):392-6. Not comparative treatments.
623 Wu S. Sickness and preventive medical behavior. Journal of Health Economics. 2003;22(4):675-89. Not localized prostate cancer. [pmid: 12842321].
624 Wust P, von Borczyskowski DW, Henkel T, Rosner C, Graf R, Tilly W, et al. Clinical and physical determinants for toxicity of 125-I seed prostate brachytherapy. Radiotherapy & Oncology. 2004;73(1):39-48. Not comparative treatments. [pmid: 15465144].
625 Xu K, Ling MT, Wang X, Wong YC. Evidence of a novel biomarker, alphas1-Casein, a milk protein, in benign prostate hyperplasia. Prostate Cancer & Prostatic Diseases. 2006;9(3):293-7. Not localized prostate cancer. [pmid: 16683014].
626 Yang BK, Crisci A, Young MD, Silverstein AD, Peterson BL, Dahm P. Cross-sectional survey of long-term quality of life after radical perineal prostatectomy. Urology. 2005;65(1):120-5. Not comparative treatments. [pmid: 15667876].
627 Yang BK, Young MD, Calingaert B, Albala DM, Vieweg J, Murphy BC, et al. Prospective and longitudinal patient self-assessment of health-related quality of life following radical perineal prostatectomy. Journal of Urology. 2004;172(1):264-8. Not comparative treatments. [pmid: 15201791].
628 Yokomizo A, Kawamoto H, Nihei K, Ishizuka N, Kakehi Y, Tobisu K, et al. Randomized controlled trial to evaluate radiotherapy +/- endocrine therapy versus endocrine therapy alone for PSA failure after radical prostatectomy: Japan Clinical Oncology Group Study JCOG 0401. Japanese Journal of Clinical Oncology. 2005;35(1):34-6. No QOL outcomes. [pmid: 15681602].
629 Yoshimura K, Arai Y, Ichioka K, Matsui Y, Ogura K, Terai A. A 3-y prospective study of health-related and disease-specific quality of life in patients with nonmetastatic prostate cancer treated with radical prostatectomy or external beam radiotherapy. Prostate Cancer & Prostatic Diseases. 2004;7(2):144-51. Less than 100 patients per study arm. [pmid: 15111981].
630 Yoshimura K, Ichioka K, Terada N, Terai A, Arai Y. Use of complementary and alternative medicine by patients with localized prostate carcinoma: study at a single institute in Japan. International Journal of Clinical Oncology. 2003;8(1):26-30. Not comparative treatments. [pmid: 12601539].
631 Young MD, Weizer AZ, Silverstein AD, Crisci A, Albala DM, Vieweg J, et al. Urinary continence and quality of life in the first year after radical perineal prostatectomy. Journal of Urology. 2003;170(6 Pt 1):2374-8. Not comparative treatments. [pmid: 14634420].
632 Zeliadt SB, Ramsey SD, Penson DF, Hall IJ, Ekwueme DU, Stroud L, et al. Why do men choose one treatment over another?: a review of patient decision making for localized prostate cancer. Cancer. 2006;106(9):1865-74. No QOL outcomes. [pmid: 16568450].
633 Zhang AY, Strauss GJ, Siminoff LA. Intervention of urinary incontinence and quality of life outcome in prostate cancer patients. J Psychosoc Oncol. 2006;24(2):17-30. Less than 100 patients per study arm. [pmid: 17046804].
634 Zisman A, Leibovici D, Kleinmann J, Cooper A, Siegel Y, Lindner A. The impact of prostate biopsy on patient well-being: a prospective study of voiding impairment. Journal of Urology. 2001;166(6):2242-6. Not comparative treatments. [pmid: 11696744].

### Proton beam radiation therapy (PBRT), high-intensity focused ultrasound (HIFU), intensity modulated radiation therapy (IMRT), cryosurgery, and laparoscopic/robotic surgery

1 Austin-Seymour M, Urie M, Munzenrider J, et al. Considerations in fractionated proton radiation therapy: clinical potential and results. Radiother Oncol. Jan. 1990;17(1):29-35. Not eligible outcomes. [pmid: 2157240].
2 Banerjee S, Das T, Chakraborty S, et al. 177Lu-DOTA-lanreotide: a novel tracer as a targeted agent for tumor therapy. Nuclear Medicine & Biology. 2004;31(6):753-9. Not eligible exposure. [pmid: 15246366].
3 Brahme A. Individualizing cancer treatment: biological optimization models in treatment planning and delivery. Int J Radiat Oncol Biol Phys. Feb 1. 2001;49(2):327-37. Review. [pmid: 11173125].
4 Casciani E, Polettini E, Bertini L, et al. Prostate cancer: evaluation with endorectal MR imaging and three-dimensional proton MR spectroscopic imaging. Radiologia Medica. 2004;108(56):530-41. Not eligible exposure. [pmid: 15722999].
5 Cella L, Lomax A, Miralbell R. Potential role of intensity modulated proton beams in prostate cancer radiotherapy. Int J Radiat Oncol Biol Phys. Jan 1. 2001;49(1):217-23. Not eligible outcomes. [pmid: 11163518].
6 Chabanova E, Logager V, Thomsen H. Combined MR examination of prostate: is it reliable?. Acta Radiologica. 2004;45(5):591-3. Not eligible exposure. [pmid: 15515525].
7 Chan I, Wells W 3rd, Mulkern RV, et al. Detection of prostate cancer by integration of line-scan diffusion, T2-mapping and T2-weighted magnetic resonance imaging; a multichannel statistical classifier. Med Phys. Sep. 2003;30(9):2390-8. Not eligible exposure. [pmid: 14528961].
8 Cheng LL, Burns MA, Taylor JL, et al. Metabolic characterization of human prostate cancer with tissue magnetic resonance spectroscopy. Cancer Research. 2005;65(8):3030-4. Not eligible exposure. [pmid: 15833828].
9 Crook J, Toi A, McLean M, et al. The utility of transition zone index in predicting acute urinary morbidity after 125I prostate brachytherapy. Brachytherapy. 2002;1(3):131-7. Not eligible outcomes. [pmid: 15090275].
10 Delen S, Eyben J. Gastroenteropancreatic neuroendocrine tumours (carcinoid tumours): definition, clinical aspects, diagnosis and therapy. Nederlands Tijdschrift voor Geneeskunde. 2006;150(43):2401. Not English language. [pmid: 17100134].
11 Ficarra V, Antoniolli SZ, Novara G, et al. Short-term outcome after high-intensity focused ultrasound in the treatment of patients with high-risk prostate cancer. BJU Int. Dec. 2006;98(6):1193-8. Case series, 30 patients. [pmid: 17125477].
12 Fourkal E, Li JS, Xiong W, et al. Intensity modulated radiation therapy using laser-accelerated protons: a Monte Carlo dosimetric study. Phys Med Biol. Dec 21. 2003;48(24):3977-4000. Not eligible outcomes. [pmid: 14727747].
13 Fricke ST, Rodriguez O, Vanmeter J, et al. In vivo magnetic resonance volumetric and spectroscopic analysis of mouse prostate cancer models. Prostate. 2006;66(7):708-17. Not human study. [pmid: 16425198].
14 Fujita T, Teh BS, Timme TL, et al. Sustained long-term immune responses after in situ gene therapy combined with radiotherapy and hormonal therapy in prostate cancer patients. Int J Radiat Oncol Biol Phys. May 1. 2006;65(1):84-90. Not eligible outcomes. [pmid: 16472937].
15 Futterer JJ, Heijmink SWTPJ, Scheenen TWJ, et al. Prostate cancer localization with dynamic contrast-enhanced MR imaging and proton MR spectroscopic imaging. Radiology. 2006;241(2):449-58. Not eligible exposure. [pmid: 16966484].
16 Futterer JJ, Scheenen TWJ, Heijmink SWTPJ, et al. Standardized threshold approach using three-dimensional proton magnetic resonance spectroscopic imaging in prostate cancer localization of the entire prostate. Investigative Radiology. 2007;42(2):116-22. Not eligible exposure. [pmid: 17220729].
17 Galbraith ME, Ramirez JM, Pedro LW. Quality of life, health outcomes, and identity for patients with prostate cancer in five different treatment groups. Oncol Nurs Forum. Apr. 2001;28(3):551-60. Case series. [pmid: 11338762].
18 Gelet A, Chapelon JY, Poissonnier L, et al. Local recurrence of prostate cancer after external beam radiotherapy: early experience of salvage therapy using high-intensity focused ultrasonography. Urology. Apr. 2004;63(4):625-9. Not eligible target population. [pmid: 15072864].
19 Gonzalez-Gronow M, Misra UK, Gawdi G, Pizzo SV. Association of plasminogen with dipeptidyl peptidase IV and Na+/H+ exchanger isoform NHE3 regulates invasion of human 1-LN prostate tumor cells. Journal of Biological Chemistry. 2005;280(29):27173-8. Not eligible exposure. [pmid: 15911629].
20 Hara I, Murakami M, Kagawa K, et al. Experience with conformal proton therapy for early prostate cancer. American Journal of Clinical Oncology. 2004;27(4):323-7. Less than 50 subjects per study arm. [pmid: 15289722].
21 Hartford AC, Niemierko A, Adams JA, et al. Conformal irradiation of the prostate: estimating long-term rectal bleeding risk using dose-volume histograms. Int J Radiat Oncol Biol Phys. Oct 1. 1996;36(3):721-30. Case series study. [pmid: 8948358].
22 Hoffelt SC, Marshall LM, Garzotto M, et al. A comparison of CT scan to transrectal ultrasound-measured prostate volume in untreated prostate cancer. Int J Radiat Oncol Biol Phys. Sep 1. 2003;57(1):29-32. Not eligible outcomes. [pmid: 12909212].
23 Hricak H. MR imaging and MR spectroscopic imaging in the pre-treatment evaluation of prostate cancer. Br J Radiol. 2005;78(Spec No 2):S103-11. Not eligible exposure. [pmid: 16306632].
24 Humez S, Monet M, van Coppenolle F, Delcourt P, Prevarskaya N. The role of intracellular pH in cell growth arrest induced by ATP. American Journal of Physiology - Cell Physiology. 2004;287(6):C1733-46. Not eligible exposure. [pmid: 15355852].
25 Hurwitz MD, Kaplan ID, Hansen JL, et al. Association of rectal toxicity with thermal dose parameters in treatment of locally advanced prostate cancer with radiation and hyperthermia. Int J Radiat Oncol Biol Phys. Jul 15. 2002;53(4):913-8. Not eligible exposure. [pmid: 12095557].
26 Illing RO, Leslie TA, Kennedy JE, et al. Visually directed high-intensity focused ultrasound for organ-confined prostate cancer: A proposed standard for the conduct of therapy. BJU Int. Dec. 2006;98(6):1187-92. Case series, 34 patients. [pmid: 17125476].
27 Isidoro A, Martinez M, Fernandez PL, et al. Alteration of the bioenergetic phenotype of mitochondria is a hallmark of breast, gastric, lung and oesophageal cancer. Biochemical Journal. 2004;378(Pt 1):17-20. Not prostate cancer. [pmid: 14683524].
28 Johansson B, Ridderheim M, Glimelius B. The potential of proton beam radiation therapy in prostate cancer, other urological cancers and gynaecological cancers. Acta Oncologica. 2005;44(8):890-5. Review. [pmid: 16332598].
29 Kagei K, Tokuuye K, Sugahara S, et al. Initial experience of proton beam therapy at the new facility of the University of Tsukuba. Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica. 2004;64(4):225-30. Not English language.
30 Kiessling F, Huber PE, Grobholz R, et al. Dynamic magnetic resonance tomography and proton magnetic resonance spectroscopy of prostate cancers in rats treated by radiotherapy. Investigative Radiology. 2004;39(1):34-44. Not human study. [pmid: 14701987].
31 Kline EE, Treat EG, Averna TA, Davis MS, Smith AY, Sillerud LO. Citrate concentrations in human seminal fluid and expressed prostatic fluid determined via 1H nuclear magnetic resonance spectroscopy outperform prostate specific antigen in prostate cancer detection. Journal of Urology. 2006;176(5):2274-9. Not eligible exposure. [pmid: 17070311].
32 Kline RP, Wu EX, Petrylak DP, et al. Rapid in vivo monitoring of chemotherapeutic response using weighted sodium magnetic resonance imaging. Clin Cancer Res. Jun. 2000;6(6):2146-56. Not eligible target population. [pmid: 10873063].
33 Kodibagkar VD, Cui W, Merritt ME, Mason RP. Novel 1H NMR approach to quantitative tissue oximetry using hexamethyldisiloxane. Magnetic Resonance in Medicine. 2006;55(4):743-8. Not eligible exposure. [pmid: 16506157].
34 Kondrat'ev BV, Vinogradov VM, Shalek RA, Ialynych NN, Kopaneva MV. Proton irradiation of the pituitary gland for alleviating pain in patients with disseminated prostate cancer. Voprosy Onkologii. 2006;52(1):92-4. Not English language. [pmid: 16715713].
35 Kumar R, Kumar M, Jagannathan NR, Gupta NP, Hemal AK. Proton magnetic resonance spectroscopy with a body coil in the diagnosis of carcinoma prostate. Urological Research. 2004;32(1):36-40. Not eligible exposure. [pmid: 14534764].
36 Kumar V, Jagannathan NR, Kumar R, et al. Correlation between metabolite ratios and ADC values of prostate in men with increased PSA level. Magnetic Resonance Imaging. 2006;24(5):541-8. Not eligible exposure. [pmid: 16735174].
37 Kurhanewicz J, Vigneron DB, Hricak H, et al. Prostate cancer: metabolic response to cryosurgery as detected with 3D H-1 MR spectroscopic imaging. Radiology. Aug. 1996;200(2):489-96. Not eligible exposure. [pmid: 8685346].
38 Kwock L, Smith JK, Castillo M, et al. Clinical role of proton magnetic resonance spectroscopy in oncology: brain, breast, and prostate cancer. Lancet Oncology. 2006;7(10):859-68. Not eligible exposure. [pmid: 17012048].
39 Lawton CA, DeSilvio M, Lee WR, et al. Results of a phase II trial of transrectal ultrasound-guided permanent radioactive implantation of the prostate for definitive management of localized adenocarcinoma of the prostate (radiation therapy oncology group 98-05). Int J Radiat Oncol Biol Phys. Jan 1. 2007;67(1):39-47. Not eligible outcomes. [pmid: 17084551].
40 Lee J, Yamaguchi T, Abe A, et al. Clinical evaluation of choline measurement by proton MR spectroscopy in patients with malignant tumors. Radiation Medicine. 2004;22(3):148-54. Not eligible exposure. [pmid: 15287529].
41 Lee M, Wynne C, Webb S, et al. A comparison of proton and megavoltage X-ray treatment planning for prostate cancer. Radiother Oncol. Dec. 1994;33(3):239-53. Not eligible outcomes. [pmid: 7716264].
42 Lichy MP, Pintaske J, Kottke R, et al. 3D proton MR spectroscopic imaging of prostate cancer using a standard spine coil at 1.5 T in clinical routine: a feasibility study. European Radiology. 2005;15(4):653-60. Not eligible exposure. [pmid: 15627193].
43 Liney GP, Turnbull LW, Lowry M, et al. In vivo quantification of citrate concentration and water T2 relaxation time of the pathologic prostate gland using 1H MRS and MRI. Magn Reson Imaging. 1997;15(10):1177-86. Not eligible exposure. [pmid: 9408138].
44 Manenti G, Squillaci E, Carlani M, Mancino S, Di Roma M, Simonetti G. Magnetic resonance imaging of the prostate with spectroscopic imaging using a surface coil. Initial clinical experience. Radiologia Medica. 2006;111(1):22-32. Not eligible exposure. [pmid: 16623302].
45 Merrick GS, Butler WM, Wallner KE, et al. Variability of prostate brachytherapy pre-implant dosimetry: a multi-institutional analysis. Brachytherapy. 2005;4(4):241-51. Not eligible outcomes. [pmid: 16344253].
46 Michalski JM. Radiation therapy in the management of locally advanced prostate cancer. Current Urology Reports. 2006;7(3):217-24. Review. [pmid: 16630525].
47 Mock U, Bogner J, Georg D, Auberger T, Potter R. Comparative treatment planning on localized prostate carcinoma conformal photon- versus proton-based radiotherapy. Strahlentherapie und Onkologie. 2005;181(7):448-55. Not eligible outcomes. [pmid: 15995838].
48 Morakkabati-Spitz N, Bastian PJ, Meissner A, et al. MR techniques for noninvasive diagnosis of prostate cancer. Urologe A. 2006;45(6):702-5. Not English language. [pmid: 16788787].
49 Moyers MF, Miller DW. Range, range modulation, and field radius requirements for proton therapy of prostate cancer. Technol Cancer Res Treat. Oct. 2003;2(5):445-7. Not eligible outcomes. [pmid: 14529309].
50 Mueller-Lisse UG, Vigneron DB, Hricak H, et al. Localized prostate cancer: effect of hormone deprivation therapy measured by using combined three-dimensional 1H MR spectroscopy and MR imaging: clinicopathologic case-controlled study. Radiology. Nov. 2001;221(2):380-90. Not eligible exposure. [pmid: 11687679].
51 Murayama S, Fuji H, Yamashita H, et al. Initial clinical experience of proton therapy at Shizuoka Cancer Center. Nippon Igaku Hoshasen Gakkai Zasshi - Nippon Acta Radiologica. 2005;65(4):424-31. Not English language.
52 Nilsson S, Norlen BJ, Widmark A. A systematic overview of radiation therapy effects in prostate cancer. Acta Oncologica. 2004;43(4):316-81. Review. [pmid: 15303499].
53 Ogino T. Proton beam therapy. Gan to Kagaku Ryoho [Japanese Journal of Cancer & Chemotherapy]. 2006;33(4):450-4. Not English language.
54 Paganetti H, Niemierko A, Ancukiewicz M, et al. Relative biological effectiveness (RBE) values for proton beam therapy. Int J Radiat Oncol Biol Phys. Jun 1. 2002;53(2):407-21. Not eligible outcomes. [pmid: 12023146].
55 Parivar F, Hricak H, Shinohara K, et al. Detection of locally recurrent prostate cancer after cryosurgery: evaluation by transrectal ultrasound, magnetic resonance imaging, and three-dimensional proton magnetic resonance spectroscopy. Urology. Oct. 1996;48(4):594-9. Not eligible exposure. [pmid: 8886066].
56 Petros JA, Baumann AK, Ruiz-Pesini E, et al. mtDNA mutations increase tumorigenicity in prostate cancer. Proceedings of the National Academy of Sciences of the United States of America. 2005;102(3):719-24. Not eligible exposure. [pmid: 15647368].
57 Pickles T, Pollack A. The case for dose escalation versus adjuvant androgen deprivation therapy for intermediate risk prostate cancer. Can J Urol. 2006;13(Suppl 2):68-71. Review. [pmid: 16672133].
58 Pisani LJ, Ross AB, Diederich CJ, et al. Effects of spatial and temporal resolution for MR image-guided thermal ablation of prostate with transurethral ultrasound. Journal of Magnetic Resonance Imaging. 2005;22(1):109-18. Not eligible exposure. [pmid: 15971190].
59 Portalez D, Malavaud B, Herigault G, et al. Predicting prostate cancer with dynamic endorectal coil MR and proton spectroscopic MR imaging. Journal de Radiologie. 2004;85(12 Pt 1):1999-2004. Not English language. [pmid: 15692410].
60 Pucar D, Koutcher JA, Shah A, et al. Preliminary assessment of magnetic resonance spectroscopic imaging in predicting treatment outcome in patients with prostate cancer at high risk for relapse. Clinical Prostate Cancer. 2004;3(3):174-81. Not eligible exposure. [pmid: 15636684].
61 Ronson BB, Yonemoto LT, Rossi CJ, Slater JM, Slater JD. Patient tolerance of rectal balloons in conformal radiation treatment of prostate cancer. International Journal of Radiation Oncology, Biology, Physics. 2006;64(5):1367-70. Not eligible outcomes.
62 Ross AB, Diederich CJ, Nau WH, et al. Highly directional transurethral ultrasound applicators with rotational control for MRI-guided prostatic thermal therapy. Physics in Medicine & Biology. 2004;49(2):189-204. Not eligible exposure. [pmid: 15083666].
63 Sacco DE, Daller M, Grocela JA, et al. Corticosteroid use after prostate brachytherapy reduces the risk of acute urinary retention. BJU Int. Mar. 2003;91(4):345-9. Not eligible exposure. [pmid: 12603412].
64 Sahab ZJ, Suh Y, Sang QXA. Isoelectric point-based prefractionation of proteins from crude biological samples prior to two-dimensional gel electrophoresis. Journal of Proteome Research. 2005;4(6):2266-72. Not eligible exposure. [pmid: 16335975].
65 Scheenen TWJ, Gambarota G, Weiland E, et al. Optimal timing for in vivo 1H-MR spectroscopic imaging of the human prostate at 3T. Magnetic Resonance in Medicine. 2005;53(6):1268-74. Not eligible exposure. [pmid: 15906304].
66 Scheenen TWJ, Klomp DWJ, Roll SA, Futterer JJ, Barentsz JO, Heerschap A. Fast acquisition-weighted three-dimensional proton MR spectroscopic imaging of the human prostate. Magnetic Resonance in Medicine. 2004;52(1):80-8. Not eligible exposure. [pmid: 15236370].
67 Schneider U, Lomax A, Pemler P, et al. The impact of IMRT and proton radiotherapy on secondary cancer incidence. Strahlentherapie und Onkologie. 2006;182(11):647-52. Case series. [pmid: 17072522].
68 Schulte RW, Li T. Innovative strategies for image-guided proton treatment of prostate cancer. Technology in Cancer Research & Treatment. 2006;5(2):91-100. Review. [pmid: 16551129].
69 Schulz-Ertner D, Tsujii H. Particle radiation therapy using proton and heavier ion beams. J Clin Oncol. 2007;25(8):953-64. Review. [pmid: 17350944].
70 Shah SK, Lui PD, Baldwin DD, Ruckle HC. Urothelial carcinoma after external beam radiation therapy for prostate cancer. Journal of Urology. 2006;175(6):2063-6. Not eligible exposure. [pmid: 16697804].
71 Shukla-Dave A, Hricak H, Eberhardt SC, et al. Chronic prostatitis: MR imaging and 1H MR spectroscopic imaging findings—initial observations. Radiology. 2004;231(3):717-24. Not eligible exposure. [pmid: 15163811].
72 Slater JD, Yonemoto LT, Rossi CJ Jr, et al. Conformal proton therapy for prostate carcinoma. Int J Radiat Oncol Biol Phys. Sep 1. 1998;42(2):299-304. Duplicate report. [pmid: 9788407].
73 Smyslov AI, Konchili IN, Lebedev LA, Khmelevski EB. Comparative analysis of dose distribution in photon and proton therapy of prostate cancer. Meditsinskaia Tekhnika 2006(5):16–20. Not English language.
74 Sovak M, Seligson AL, Konas M, et al. Herbal composition PC-SPES for management of prostate cancer: identification of active principles. J Natl Cancer Inst. Sep 4. 2002;94(17):1275-81. Not eligible exposure. [pmid: 12208892].
75 Squillaci E, Manenti G, Mancino S, et al. MR spectroscopy of prostate cancer. Initial clinical experience. Journal of Experimental & Clinical Cancer Research. 2005;24(4):523-30. Not eligible exposure. [pmid: 16471314].
76 Thomas SJ. Margins for treatment planning of proton therapy. Physics in Medicine & Biology. 2006;51(6):1491-501. Not eligible outcomes. [pmid: 16510958].
77 Timmermann B, Schuck A, Niggli F, Weiss M, Lomax A, Goitein G. “Spot-scanning” proton therapy for rhabdomyosarcomas of early childhood. First experiences at PSI. Strahlentherapie und Onkologie. 2006;182(11):653-9. Not English language. [pmid: 17072523].
78 Uchida T, Sanghvi NT, Gardner TA, et al. Transrectal high-intensity focused ultrasound for treatment of patients with stage T1b-2n0m0 localized prostate cancer: a preliminary report. Urology. Mar. 2002;59(3):394-8. Case series, 20 patients. [pmid: 11880077].
79 Vallancien G, Prapotnich D, Cathelineau X, et al. Transrectal focused ultrasound combined with transurethral resection of the prostate for the treatment of localized prostate cancer: feasibility study. J Urol. Jun. 2004;171(6 Pt 1):2265-7. Case series, 30 patients. [pmid: 15126799].
80 Wambersie A, Hendry J, Gueulette J, Gahbauer R, Potter R, Gregoire V. Radiobiological rationale and patient selection for high-LET radiation in cancer therapy. Radiother Oncol. 2004;73(Suppl 2):S1-14. Review. [pmid: 15971301].
81 Wust P, Cho CH, Hildebrandt B, Gellermann J. Thermal monitoring: invasive, minimal-invasive and non-invasive approaches. International Journal of Hyperthermia. 2006;22(3):255-62. Review. [pmid: 16754347].
82 Yamaguchi T, Lee J, Uemura H, et al. Prostate cancer: a comparative study of 11C-choline PET and MR imaging combined with proton MR spectroscopy. European Journal of Nuclear Medicine & Molecular Imaging. 2005;32(7):742-8. Not eligible exposure. [pmid: 16052370].
83 Yeboah C, Sandison GA. Optimized treatment planning for prostate cancer comparing IMPT, VHEET and 15 MV IMXT. Phys Med Biol. Jul 7. 2002;47(13):2247-61. Not eligible outcomes. [pmid: 12164585].
84 Yeboah C, Sandison GA, Chvetsov AV. Intensity and energy modulated radiotherapy with proton beams: variables affecting optimal prostate plan. Med Phys. Feb. 2002;29(2):176-89. Not eligible outcomes. [pmid: 11865989].
85 Zakian KL, Sircar K, Hricak H, et al. Correlation of proton MR spectroscopic imaging with gleason score based on step-section pathologic analysis after radical prostatectomy. Radiology. 2005;234(3):804-14. Not eligible exposure. [pmid: 15734935].
86 Zhang X, Dong L, Lee AK, et al. Effect of anatomic motion on proton therapy dose distributions in prostate cancer treatment. International Journal of Radiation Oncology, Biology, Physics. 2007;67(2):620-9. Not eligible exposure.

## Question 3. Provider Characteristics Associated with Patient Outcomes

1 Results of 12-year study show brachytherapy is as effective as surgery. Rep Med Guidel Outcomes Res. Jul 20 2000;11(15):10, 12. News.
2 Antiandrogen therapy and side effects following radical prostatectomy. Clin J Oncol Nurs. Jul–Aug 2000;4(4):179–180. Review.
3 Prostate cancer surgery: busier is better. Harv Mens Health Watch. Feb 2003;7(7):7–8. Review.
4 Abbas F, Siddiqui K, Biyabani SR, et al. Early surgical results with intent to treat by radical retropubic prostatectomy for clinically localized prostate cancer. J Pak Med Assoc. May. 2002;52(5):200-205. Not eligible exposure. [pmid: 12174491].
5 Abbou CC, Salomon L, Hoznek A, et al. Laparoscopic radical prostatectomy: preliminary results. Urology. May. 2000;55(5):630-634. No provider characteristics. [pmid: 10792066].
6 Abdalla I, Basu A, Hellman S. An evidence-based analysis of the management of localized prostate cancer. Cancer J. Jan–Feb. 2002;8(1):40-46. Review. [pmid: 11895202].
7 Abrahamsson PA. The risks outweigh the benefits of radical prostatectomy in localised prostate cancer: the argument for. Eur Urol. 1996;29(Suppl 2):27-30. Review. [pmid: 8717458].
8 Adolfsson J, Steineck G, Whitmore WF Jr. Recent results of management of palpable clinically localized prostate cancer. Cancer. Jul 15. 1993;72(2):310-322. Review. [pmid: 8319164].
9 Ahlgren G, Pedersen K, Lundberg S, et al. Tumor cell proliferation in prostate cancer after 3 months of neoadjuvant LHRH analogue treatment is a prognostic marker of recurrence after radical prostatectomy. Urology. Aug. 1999;54(2):329-334. Not eligible exposure. [pmid: 10443734].
10 Akaza H. Adjuvant goserelin improves clinical disease-free survival and reduces disease-related mortality in patients with locally advanced or localized prostate cancer. BJU Int. Jan. 2004;93(1):42-46. Not eligible exposure. [pmid: 14678365].
11 Akdas A, Tarcan T, Turkeri L, et al. The impact of prostate-specific antigen, its density and the Gleason score in the prediction of extracapsular disease in prostate carcinoma. Eur Urol. 1997;31(3):311-316. Not eligible exposure. [pmid: 9129922].
12 Akporiaye LE. Early results of transurethral vaporisation of prostate in Nigeria. West Afr J Med. Apr–Jun. 2004;23(2):139-141. Not eligible exposure. [pmid: 15287293].
13 Akyol M, Kilicarslan H, Goze F, et al. Granuloma annulare associated with prostate carcinoma. J Eur Acad Dermatol Venereol. Jul. 2003;17(4):464-465. Review. [pmid: 12834464].
14 Albertsen PC, Hanley JA, Barrows GH, et al. Prostate cancer and the Will Rogers phenomenon. J Natl Cancer Inst. Sep 7. 2005;97(17):1248-1253. Not eligible exposure. [pmid: 16145045].
15 Alibhai SM, Klotz LH. A systematic review of randomized trials in localized prostate cancer. Can J Urol. Feb. 2004;11(1):2110-2117. Review. [pmid: 15003149].
16 Alibhai SM, Naglie G, Nam R, et al. Do older men benefit from curative therapy of localized prostate cancer?. J Clin Oncol. Sep 1. 2003;21(17):3318-3327. Not eligible exposure. [pmid: 12947068].
17 Altwein JE. Enhancing the efficacy of radical prostatectomy in locally advanced prostate cancer. Urol Int. 1998;60(Suppl 2):2-10. discussion 35. Review. [pmid: 9607552].
18 Amling CL, Lerner SE, Martin SK, et al. Deoxyribonucleic acid ploidy and serum prostate specific antigen predict outcome following salvage prostatectomy for radiation refractory prostate cancer. J Urol. Mar. 1999;161(3):857-862. discussion 862–853. Not eligible exposure. [pmid: 10022701].
19 Anast JW, Sadetsky N, Pasta DJ, et al. The impact of obesity on health related quality of life before and after radical prostatectomy (data from CaPSURE). J Urol. Apr. 2005;173(4):1132-1138. Not eligible exposure. [pmid: 15758721].
20 Anastasiadis AG, Benson MC, Rosenwasser MP, et al. Cavernous nerve graft reconstruction during radical prostatectomy or radical cystectomy: safe and technically feasible. Prostate Cancer Prostatic Dis. 2003;6(1):56-60. Not eligible exposure. [pmid: 12664067].
21 Andersson J, Ekman P, Egevad L, et al. Relatively high risk of treatment failure after prostatectomy: tumour grade, histopathological stage and the preoperative serum PSA level are key prognosticators. Scand J Urol Nephrol. Dec. 2001;35(6):453-458. Not eligible exposure. [pmid: 11848423].
22 Andersson SO, Johansson JE, Windahl T. Neodymium-YAG laser treatment in localized prostatic cancer. High rate of local failure. Scand J Urol Nephrol. 1993;27(4):485-487. Not eligible exposure. [pmid: 8159921].
23 Andriole GL. Adjuvant therapy for prostate cancer patients at high risk of recurrence following radical prostatectomy. Eur Urol. 1997;32(Suppl 3):65-69. Review. [pmid: 9267788].
24 Ansari MS, Nabi G, Aron M. Solitary radial head metastasis with wrist drop: a rare presentation of metastatic prostate cancer. Urol Int. 2003;70(1):77-79. Not eligible target population. [pmid: 12635643].
25 Anscher MS, Robertson CN, Prosnitz R. Adjuvant radiotherapy for pathologic stage T3/4 adenocarcinoma of the prostate: ten-year update. Int J Radiat Oncol Biol Phys. Aug 30. 1995;33(1):37-43. Not eligible exposure. [pmid: 7543893].
26 Ansong S. Re: Preoperative reverse transcriptase polymerase chain reaction for prostate specific antigen predicts treatment failure following radical prostatectomy. J Urol. Jan. 1997;157(1):269-270. Comment. [pmid: 8976276].
27 Antiphon P, Hoznek A, Benyoussef A, et al. Complete solo laparoscopic radical prostatectomy: initial experience. Urology. Apr. 2003;61(4):724-728. discussion 728–729. Not eligible exposure. [pmid: 12670553].
28 Aprikian AG, Fair WR, Reuter VE, et al. Experience with neoadjuvant diethylstilboestrol and radical prostatectomy in patients with locally advanced prostate cancer. Br J Urol. Nov. 1994;74(5):630-636. Not eligible exposure. [pmid: 7530128].
29 Arcangeli G, Micheli A, Verna L, et al. Prognostic impact of transurethral resection on patients irradiated for localized prostate cancer. Radiother Oncol. May. 1995;35(2):123-128. Not eligible exposure. [pmid: 7569020].
30 Augustin H, Hammerer P, Graefen M, et al. Intraoperative and perioperative morbidity of contemporary radical retropubic prostatectomy in a consecutive series of 1243 patients: results of a single center between 1999 and 2002. Eur Urol. Feb. 2003;43(2):113-118. Not eligible exposure. [pmid: 12565767].
31 Augustin H, Hammerer PG, Blonski J, et al. Zonal location of prostate cancer: significance for disease-free survival after radical prostatectomy?. Urology. Jul. 2003;62(1):79-85. Not eligible exposure. [pmid: 12837427].
32 Augustin H, Pummer K, Daghofer F, et al. Patient self-reporting questionnaire on urological morbidity and bother after radical retropubic prostatectomy. Eur Urol. Aug. 2002;42(2):112-117. Not eligible exposure. [pmid: 12160580].
33 Aus G. Prostate cancer. Mortality and morbidity after non-curative treatment with aspects on diagnosis and treatment. Scand J Urol Nephrol Suppl. 1994;167:1-41. Not eligible exposure. [pmid: 7542397].
34 Aus G, Abrahamsson PA, Ahlgren G, et al. Hormonal treatment before radical prostatectomy: a 3-year followup. J Urol. Jun. 1998;159(6):2013-2016. discussion 2016–2017. Not eligible exposure. [pmid: 9598509].
35 Aus G, Becker C, Lilja H, et al. Free-to-total prostate-specific antigen ratio as a predictor of non-organ-confined prostate cancer (stage pT3). Scand J Urol Nephrol. 2003;37(6):466-470. Not eligible exposure. [pmid: 14675918].
36 Ayala G, Wang D, Wulf G, et al. The prolyl isomerase Pin1 is a novel prognostic marker in human prostate cancer. Cancer Res. Oct 1. 2003;63(19):6244-6251. Not eligible exposure. [pmid: 14559810].
37 Bahn DK, Lee F. Cryosurgical ablation therapy for prostate cancer. Arch Ital Urol Androl. Dec. 2000;72(4):302-304. Review. [pmid: 11221060].
38 Baniel J, Israilov S, Segenreich E, et al. Comparative evaluation of treatments for erectile dysfunction in patients with prostate cancer after radical retropubic prostatectomy. BJU Int. Jul. 2001;88(1):58-62. Not eligible exposure. [pmid: 11446847].
39 Barqawi AB, Moul JW, Ziada A, et al. Combination of low-dose flutamide and finasteride for PSA-only recurrent prostate cancer after primary therapy. Urology. Nov. 2003;62(5):872-876. Not eligible exposure. [pmid: 14624911].
40 Barrou B, Benoit G, Ouldkaci M, et al. Vaccination of prostatectomized prostate cancer patients in biochemical relapse, with autologous dendritic cells pulsed with recombinant human PSA. Cancer Immunol Immunother. May. 2004;53(5):453-460. Not eligible exposure. [pmid: 14760510].
41 Barry MJ. PSA screening for prostate cancer: the current controversy—a viewpoint. Patient Outcomes Research Team for Prostatic Diseases. Ann Oncol. Dec. 1998;9(12):1279-1282. Review. [pmid: 9932155].
42 Barry MJ, Fleming C, Coley CM, et al. Should Medicare provide reimbursement for prostate-specific antigen testing for early detection of prostate cancer? Part III: Management strategies and outcomes. Urology. Sep. 1995;46(3):277-289. Review. [pmid: 7544931].
43 Bates TS, Sugiono M, James ED, et al. Is the conservative management of chronic retention in men ever justified?. BJU Int. Oct. 2003;92(6):581-583. Not eligible target population. [pmid: 14511038].
44 Battermann JJ, van Es CA. The learning curve in prostate seed implantation. Cancer Radiother. Nov. 2000;4(Suppl 1):119s-122s. No provider charactertistics. [pmid: 11194949].
45 Baur H, Frimberger M, Altwein JE. Simultaneous radical prostatectomy and partial rectum resection without colostomy. Eur Urol. 1997;31(3):380-381. Not eligible exposure. [pmid: 9129936].
46 Beer TM, Bubalo JS. Prevention and management of prostate cancer chemotherapy complications. Urol Clin North Am. May. 2004;31(2):367-378. Review. [pmid: 15123414].
47 Beer TM, Lemmon D, Lowe BA, et al. High-dose weekly oral calcitriol in patients with a rising PSA after prostatectomy or radiation for prostate carcinoma. Cancer. Mar 1. 2003;97(5):1217-1224. Not eligible exposure. [pmid: 12599228].
48 Begg CB, Scardino PT. Taking stock of volume-outcome studies. J Clin Oncol. Feb 1. 2003;21(3):393-394. Comment. [pmid: 12560422].
49 Bentas W, Wolfram M, Jones J, et al. Robotic technology and the translation of open radical prostatectomy to laparoscopy: the early Frankfurt experience with robotic radical prostatectomy and one year follow-up. Eur Urol. Aug. 2003;44(2):175-181. No provider characteristics. [pmid: 12875935].
50 Bergstralh EJ, Myers RP. Re: Radical surgery for advanced prostate cancer and for radiation failures. J Urol. Jun. 1993;149(6):1560. Comment. [pmid: 8501814].
51 Bhandari A, McIntire L, Kaul SA, et al. Perioperative complications of robotic radical prostatectomy after the learning curve. J Urol. Sep. 2005;174(3):915-918. No provider characteristics. [pmid: 16093987].
52 Bhatnagar V, Stewart ST, Bonney WW, et al. Treatment options for localized prostate cancer: quality-adjusted life years and the effects of lead-time. Urology. Jan. 2004;63(1):103-109. Not eligible exposure. [pmid: 14751359].
53 Bhatta-Dhar N, Reuther AM, Zippe C, et al. No difference in six-year biochemical failure rates with or without pelvic lymph node dissection during radical prostatectomy in low-risk patients with localized prostate cancer. Urology. Mar. 2004;63(3):528-531. Not eligible exposure. [pmid: 15028451].
54 Bhayani SB, Pavlovich CP, Hsu TS, et al. Prospective comparison of short-term convalescence: laparoscopic radical prostatectomy versus open radical retropubic prostatectomy. Urology. Mar. 2003;61(3):612-616. Not eligible exposure. [pmid: 12639657].
55 Bianco FJ Jr, Scardino PT, Stephenson AJ, et al. Long-term oncologic results of salvage radical prostatectomy for locally recurrent prostate cancer after radiotherapy. Int J Radiat Oncol Biol Phys. Jun 1. 2005;62(2):448-453. Not eligible outcomes. [pmid: 15890586].
56 Bissada NK, Gunhan M, Hull JW. Surgical management of localized prostate cancer. J S C Med Assoc. Feb. 2000;96(2):60-64. Review. [pmid: 10710901].
57 Blana A, Walter B, Rogenhofer S, et al. High-intensity focused ultrasound for the treatment of localized prostate cancer: 5-year experience. Urology. Feb. 2004;63(2):297-300. Not eligible exposure. [pmid: 14972475].
58 Bloom KD, Richie JP, Schultz D, et al. Invasion of seminal vesicles by adenocarcinoma of the prostate: PSA outcome determined by preoperative and postoperative factors. Urology. Feb. 2004;63(2):333-336. Not eligible exposure. [pmid: 14972484].
59 Boccon-Gibod L. The management of localised cancer of the prostate. Eur Urol. 1996;29(Suppl 2):62-68. Review. [pmid: 8717466].
60 Boccon-Gibod L, Djavan WB, Hammerer P, et al. Management of prostate-specific antigen relapse in prostate cancer: a European Consensus. Int J Clin Pract. Apr. 2004;58(4):382-390. Review. [pmid: 15161124].
61 Bochner BH, Figueroa AJ, Skinner EC, et al. Salvage radical cystoprostatectomy and orthotopic urinary diversion following radiation failure. J Urol. Jul. 1998;160(1):29-33. Not eligible exposure. [pmid: 9628599].
62 Boczko J, Melman A. Radical perineal prostatectomy in obese patients. Urology. Sep. 2003;62(3):467-469. Not eligible exposure. [pmid: 12946748].
63 Bollens R, Sandhu S, Roumeguere T, et al. Laparoscopic radical prostatectomy: the learning curve. Curr Opin Urol. Mar. 2005;15(2):79-82. Review. [pmid: 15725929].
64 Bono AV, Celato N, Cova V, et al. Microvessel density in prostate carcinoma. Prostate Cancer Prostatic Dis. 2002;5(2):123-127. Not eligible exposure. [pmid: 12497001].
65 Bottke D, Wiegel T, Hocht S, et al. Salvage radiotherapy in patients with persisting prostate-specific antigen after radical prostatectomy for prostate cancer. Oncology. 2003;65(Suppl 1):18-23. Review. [pmid: 12949429].
66 Brant LA, Brantt WO, Brown MH, et al. A new minimally invasive open pelvic lymphadenectomy surgical technique for the staging of prostate cancer. Urology. Mar. 1996;47(3):416-421. No provider characteristics. [pmid: 8633413].
67 Brawer MK, Stamey TA, Fowler J, et al. Perspectives on prostate cancer diagnosis and treatment: a roundtable. Urology. Aug. 2001;58(2):135-140. Comment. [pmid: 11489681].
68 Brehmer B, Borchers H, Kirschner-Hermanns R, et al. Perioperative morbidity of the extended radical perineal prostatectomy. Eur Urol. Aug. 2001;40(2):139-143. No provider characteristics. [pmid: 11528190].
69 Brehmer B, Kirschner-Hermanns R, Donner A, et al. Efficacy of unilateral nerve sparing in radical perineal prostatectomy. Urol Int. 2005;74(4):308-314. Not eligible exposure. [pmid: 15897694].
70 Brierly RD, Hindley RG, Challacombe BJ, et al. “Urological cold shower”—a novel treatment for intraoperative erection. Urology. Feb. 2003;61(2):462. Not eligible exposure. [pmid: 12597976].
71 Brink S. Prostate cancer: kinder cuts mean sharper dilemmas. US News World Rep. Apr 3. 2000;128(13):58-60. News.
72 Brinker DA, Potter SR, Epstein JI. Ductal adenocarcinoma of the prostate diagnosed on needle biopsy: correlation with clinical and radical prostatectomy findings and progression. Am J Surg Pathol. Dec. 1999;23(12):1471-1479. Not eligible exposure. [pmid: 10584700].
73 Brown JA, Garlitz C, Gomella LG, et al. Pathologic comparison of laparoscopic versus open radical retropubic prostatectomy specimens. Urology. Sep. 2003;62(3):481-486. Not eligible exposure. [pmid: 12946751].
74 Brucker PS, Cella D. Measuring self-reported sexual function in men with prostate cancer. Urology. Oct. 2003;62(4):596-606. Review. [pmid: 14550425].
75 Bukkapatnam R, Pow-Sang JM. Radical prostatectomy in the management of clinically localized prostate cancer. Cancer Control. Nov–Dec. 2001;8(6):496-502. Review. [pmid: 11807419].
76 Burney TL, Campbell EC Jr, Naslund MJ, et al. Complications of staging laparoscopic pelvic lymphadenectomy. Surg Laparosc Endosc. Jun. 1993;3(3):184-190. No provider characteristics. [pmid: 8111554].
77 Bussemakers MJ. Changes in gene expression and targets for therapy. Eur Urol. 1999;35(56):408-412. Review. [pmid: 10325497].
78 Cadeddu JA, Kavoussi LR. Laparoscopic radical prostatectomy: is it feasible and reasonable?. Urol Clin North Am. Aug. 2001;28(3):655-661. Review. [pmid: 11590820].
79 Cagiannos I, Karakiewicz P, Graefen M, et al. Is year of radical prostatectomy a predictor of outcome in prostate cancer?. J Urol. Feb. 2004;171(2 Pt 1):692-696. Not eligible exposure. [pmid: 14713788].
80 Cangiano TG, Litwin MS, Naitoh J, et al. Intraoperative frozen section monitoring of nerve sparing radical retropubic prostatectomy. J Urol. Sep. 1999;162(3 Pt 1):655-658. Not eligible exposure. [pmid: 10458335].
81 Cantor SB, Spann SJ, Volk RJ, et al. Prostate cancer screening: a decision analysis. J Fam Pract. Jul. 1995;41(1):33-41. Not eligible exposure. [pmid: 7798064].
82 Carswell CI, Figgitt DP. Bicalutamide: in early-stage prostate cancer. Drugs. 2002;62(17):2471-2479. discussion 2480–2471. Not eligible exposure. [pmid: 12421104].
83 Catton C, Gospodarowicz M, Warde P, et al. Adjuvant and salvage radiation therapy after radical prostatectomy for adenocarcinoma of the prostate. Radiother Oncol. Apr. 2001;59(1):51-60. Not eligible exposure. [pmid: 11295206].
84 Chang CP, Chang YH, Chiang H, Chen MT, Chang LS. Incidental adenocarcinoma of the prostate: a retrospective analysis. Eur Urol. 1991;20(4):282-286. Not eligible exposure. [pmid: 1726085].
85 Chaussy C, Thuroff S. The status of high-intensity focused ultrasound in the treatment of localized prostate cancer and the impact of a combined resection. Curr Urol Rep. Jun. 2003;4(3):248-252. Not eligible exposure. [pmid: 12756090].
86 Chen BT, Wood DP Jr. Salvage prostatectomy in patients who have failed radiation therapy or cryotherapy as primary treatment for prostate cancer. Urology. Dec 29. 2003;62(Suppl 1):69-78. Review. [pmid: 14747044].
87 Cheng L, Cheville JC, Bostwick DG. Diagnosis of prostate cancer in needle biopsies after radiation therapy. Am J Surg Pathol. Oct. 1999;23(10):1173-1183. Not eligible exposure. [pmid: 10524518].
88 Cheng L, Cheville JC, Pisansky TM, et al. Prevalence and distribution of prostatic intraepithelial neoplasia in salvage radical prostatectomy specimens after radiation therapy. Am J Surg Pathol. Jul. 1999;23(7):803-808. Not eligible exposure. [pmid: 10403303].
89 Cheng L, Koch MO, Juliar BE, et al. The combined percentage of Gleason patterns 4 and 5 is the best predictor of cancer progression after radical prostatectomy. J Clin Oncol. May 1. 2005;23(13):2911-2917. Not eligible exposure. [pmid: 15860849].
90 Cher ML, Shinohara K, Breslin S, et al. High failure rate associated with long-term follow-up of neoadjuvant androgen deprivation followed by radical prostatectomy for stage C prostatic cancer. Br J Urol. Jun. 1995;75(6):771-777. Not eligible exposure. [pmid: 7542137].
91 Cherullo EE, Ponsky LE, Goyal KK, et al. Variable definitions influence the reporting of biochemical failure rates. Prostate Cancer Prostatic Dis. 2002;5(1):54-58. Not eligible exposure. [pmid: 15195131].
92 Cheung R, Altschuler MD, D'Amico AV, et al. Using the receiver operating characteristic curve to select pretreatment and pathologic predictors for early and late postprostatectomy PSA failure. Urology. Sep. 2001;58(3):400-405. Not eligible exposure. [pmid: 11549488].
93 Cheung R, Altschuler MD, D'Amico AV, et al. ROC optimization may improve risk stratification of prostate cancer patients. Urology. Feb. 2001;57(2):286-290. Not eligible exposure. [pmid: 11182338].
94 Cheville JC, Tindall D, Boelter C, et al. Metastatic prostate carcinoma to bone: clinical and pathologic features associated with cancer-specific survival. Cancer. Sep 1. 2002;95(5):1028-1036. Not eligible target population. [pmid: 12209687].
95 Chodak G. Conservative management of clinically-localized prostate cancer. Can J Oncol. Nov. 1994;4(Suppl 1):20-21. discussion 22–23. Review. [pmid: 8853484].
96 Chodak GW. Prostate cancer. Lancet. May 24. 1997;349(9064):1551. author reply 1551–1552. Comment. [pmid: 9167480].
97 Choo R, Morton G, Danjoux C, et al. Limited efficacy of salvage radiotherapy for biopsy confirmed or clinically palpable local recurrence of prostate carcinoma after surgery. Radiother Oncol. Feb. 2005;74(2):163-167. Not eligible exposure. [pmid: 15734204].
98 Chow P, Wong M, Foo KT. Clinical profile of stage D carcinoma of the prostate—a ten-year experience. Ann Acad Med Singapore. Mar. 1993;22(2):254-256. Not eligible exposure. [pmid: 8363343].
99 Clark JA, Talcott JA. Symptom indexes to assess outcomes of treatment for early prostate cancer. Med Care. Oct. 2001;39(10):1118-1130. Not eligible exposure. [pmid: 11567174].
100 Clark PE, Peereboom DM, Dreicer R, et al. Phase II trial of neoadjuvant estramustine and etoposide plus radical prostatectomy for locally advanced prostate cancer. Urology. Feb. 2001;57(2):281-285. Not eligible exposure. [pmid: 11182337].
101 Clegg LX, Feuer EJ, Midthune DN, et al. Impact of Reporting Delay and Reporting Error on Cancer Incidence Rates and Trends. J Natl Cancer Inst. October 16, 2002 2002;94(20):1537–1545. Not eligible exposure.
102 Coetzee LJ, Hars V, Paulson DF. Postoperative prostate-specific antigen as a prognostic indicator in patients with margin-positive prostate cancer, undergoing adjuvant radiotherapy after radical prostatectomy. Urology. Feb. 1996;47(2):232-235. Not eligible exposure. [pmid: 8607240].
103 Cohen YC, Olmer L, Mozes B. Two-dimensional outcome analysis as a guide for quality assurance of prostatectomy. Int J Qual Health Care. Feb. 1996;8(1):67-73. Not eligible target population. [pmid: 8680819].
104 Cookson MS, Sogani PC, Russo P, et al. Pathological staging and biochemical recurrence after neoadjuvant androgen deprivation therapy in combination with radical prostatectomy in clinically localized prostate cancer: results of a phase II study. Br J Urol. Mar. 1997;79(3):432-438. Not eligible exposure. [pmid: 9117227].
105 Copeland B, Clark JM, Sura A, et al. Prostate carcinoma metastatic to the cervical lymph nodes: report of two cases and review of the literature. Am J Otolaryngol. Nov–Dec. 2001;22(6):420-423. Review. [pmid: 11713729].
106 Corn BW, Valicenti RK, Mulholland SG, et al. Stage T3 prostate cancer: a nonrandomized comparison between definitive irradiation and induction hormonal manipulation plus prostatectomy. Urology. May. 1998;51(5):782-787. Not eligible exposure. [pmid: 9610592].
107 Costello AJ. Contemporary view of prostate cancer diagnosis and treatment. Aust Fam Physician. Jun. 2003;32(6):396-398. Review. [pmid: 12833761].
108 Costello AJ. Minimally invasive radical prostatectomy: now safe and efficacious. ANZ J Surg. Dec. 2004;74(12):1038. Comment. [pmid: 15574141].
109 Costello AJ, Haxhimolla H, Crowe H, et al. Installation of telerobotic surgery and initial experience with telerobotic radical prostatectomy. BJU Int. Jul. 2005;96(1):34-38. Not eligible exposure. [pmid: 15963116].
110 Crawford ED, DeAntoni EP, Hussain M, et al. Prostate cancer clinical trials of the Southwest Oncology Group. Oncology (Williston Park). Aug. 1997;11(8):1154-1163. discussion 1163–1170. Review. [pmid: 9268978].
111 Critz FA. Summary of simultaneous irradiation for prostate cancer. Urology. Oct. 2004;64(4):633-636. Not eligible exposure. [pmid: 15491686].
112 Cross CK, Shultz D, Malkowicz SB, et al. Impact of race on prostate-specific antigen outcome after radical prostatectomy for clinically localized adenocarcinoma of the prostate. J Clin Oncol. Jun 15. 2002;20(12):2863-2868. Not eligible exposure. [pmid: 12065563].
113 Da Pozzo LF, Francesca F, Colombo R, et al. Pathologic features and clinical outcome after anatomic radical prostatectomy by transcoccygeal approach. Urology. Mar. 1997;49(3):392-399. Not eligible exposure. [pmid: 9123704].
114 Dahm P, Vieweg J, Newhall PM, et al. Outcome profiles of locoregional disease after radical prostatectomy and radiotherapy. World J Urol. Jun. 2000;18(3):173-178. Not eligible exposure. [pmid: 10926080].
115 Dalkin BL. Endoscopic evaluation and treatment of anastomotic strictures after radical retropubic prostatectomy. J Urol. Jan. 1996;155(1):206-208. Not eligible exposure. [pmid: 7490836].
116 Dalkin BL. Re: Health outcomes after prostatectomy or radiotherapy for prostate cancer: results from the Prostate Cancer Outcomes Study. J Natl Cancer Inst. Mar 7. 2001;93(5):401-402. Comment. [pmid: 11238710].
117 Dalkin BL, Ahmann FR, Nagle R, et al. Randomized study of neoadjuvant testicular androgen ablation therapy before radical prostatectomy in men with clinically localized prostate cancer. J Urol. Apr. 1996;155(4):1357-1360. Not eligible exposure. [pmid: 8632574].
118 D'Amico A, Altschuler M, Whittington R, et al. The use of clinical parameters in an interactive statistical package to predict pathological features associated with local failure after radical prostatectomy for prostate cancer. Clin Perform Qual Health Care. Oct–Dec. 1993;1(4):219-222. Not eligible exposure. [pmid: 10135639].
119 D'Amico AV, Tempany CM, Schultz D, et al. Comparing PSA outcome after radical prostatectomy or magnetic resonance imaging-guided partial prostatic irradiation in select patients with clinically localized adenocarcinoma of the prostate. Urology. Dec. 2003;62(6):1063-1067. Not eligible exposure. [pmid: 14665356].
120 D'Amico AV. Combined-modality staging for localized adenocarcinoma of the prostate. Oncology (Williston Park). Aug. 2001;15(8):1049-1059. discussion 1060–1042, 1064–1045, 1069–1070,1073–1045. Review. [pmid: 11548976].
121 D'Amico AV, Chen MH, Oh-Ung J, et al. Changing prostate-specific antigen outcome after surgery or radiotherapy for localized prostate cancer during the prostate-specific antigen era. Int J Radiat Oncol Biol Phys. Oct 1. 2002;54(2):436-441. Not eligible exposure. [pmid: 12243819].
122 D'Amico AV, Chen MH, Roehl KA, et al. Identifying patients at risk for significant versus clinically insignificant postoperative prostate-specific antigen failure. J Clin Oncol. Aug 1. 2005;23(22):4975-4979. Not eligible exposure. [pmid: 16051949].
123 D'Amico AV, Coleman CN. Role of interstitial radiotherapy in the management of clinically organ-confined prostate cancer: the jury is still out. J Clin Oncol. Jan. 1996;14(1):304-315. Review. [pmid: 8558212].
124 D'Amico AV, Cote K, Loffredo M, et al. Advanced age at diagnosis is an independent predictor of time to death from prostate carcinoma for patients undergoing external beam radiation therapy for clinically localized prostate carcinoma. Cancer. Jan 1. 2003;97(1):56-62. Not eligible exposure. [pmid: 12491505].
125 D'Amico AV, Desjardin A, Chung A, et al. Assessment of outcome prediction models for patients with localized prostate carcinoma managed with radical prostatectomy or external beam radiation therapy. Cancer. May 15. 1998;82(10):1887-1896. Not eligible exposure. [pmid: 9587121].
126 D'Amico AV, Moul JW, Carroll PR, et al. Surrogate end point for prostate cancer-specific mortality after radical prostatectomy or radiation therapy. J Natl Cancer Inst. Sep 17. 2003;95(18):1376-1383. Not eligible exposure. [pmid: 13130113].
127 D'Amico AV, Whittington R, Kaplan I, et al. Calculated prostate carcinoma volume: The optimal predictor of 3-year prostate specific antigen (PSA) failure free survival after surgery or radiation therapy of patients with pretreatment PSA levels of 4–20 nanograms per milliliter. Cancer. Jan 15. 1998;82(2):334-341. Not eligible exposure. [pmid: 9445191].
128 D'Amico AV, Whittington R, Malkowicz B, et al. Endorectal magnetic resonance imaging as a predictor of biochemical outcome after radical prostatectomy in men with clinically localized prostate cancer. J Urol. Sep. 2000;164(3 Pt 1):759-763. Not eligible exposure. [pmid: 10953141].
129 D'Amico AV, Whittington R, Malkowicz SB, et al. Estimating the impact on prostate cancer mortality of incorporating prostate-specific antigen testing into screening. Urology. Sep. 2001;58(3):406-410. Not eligible exposure. [pmid: 11549489].
130 D'Amico AV, Whittington R, Malkowicz SB, et al. Clinical utility of the percentage of positive prostate biopsies in defining biochemical outcome after radical prostatectomy for patients with clinically localized prostate cancer. J Clin Oncol. Mar. 2000;18(6):1164-1172. Not eligible exposure. [pmid: 10715284].
131 D'Amico AV, Whittington R, Malkowicz SB, et al. A multivariate analysis of clinical and pathological factors that predict for prostate specific antigen failure after radical prostatectomy for prostate cancer. J Urol. Jul. 1995;154(1):131-138. Not eligible exposure. [pmid: 7539857].
132 D'Amico AV, Whittington R, Malkowicz SB, et al. Clinical utility of percent-positive prostate biopsies in predicting biochemical outcome after radical prostatectomy or external-beam radiation therapy for patients with clinically localized prostate cancer. Mol Urol. Fall. 2000;4(3):171-175. discussion 177. Not eligible exposure. [pmid: 11062371].
133 D'Amico AV, Whittington R, Malkowicz SB, et al. A prostate gland volume of more than 75 cm3 predicts for a favorable outcome after radical prostatectomy for localized prostate cancer. Urology. Oct. 1998;52(4):631-636. Not eligible exposure. [pmid: 9763083].
134 D'Amico AV, Whittington R, Malkowicz SB, et al. Prostate specific antigen outcome based on the extent of extracapsular extension and margin status in patients with seminal vesicle negative prostate carcinoma of Gleason score < or = 7. Cancer. May 1. 2000;88(9):2110-2115. Not eligible exposure. [pmid: 10813723].
135 Davidson PJ, van den Ouden D, Schroeder FH. Radical prostatectomy: prospective assessment of mortality and morbidity. Eur Urol. 1996;29(2):168-173. Not eligible exposure. [pmid: 8647142].
136 Davis BJ, Haddock MG, Wilson TM, et al. Treatment of extraprostatic cancer in clinically organ-confined prostate cancer by permanent interstitial brachytherapy: is extraprostatic seed placement necessary?. Tech Urol. Jun. 2000;6(2):70-77. Not eligible exposure. [pmid: 10798803].
137 Davis M, Sofer M, Gomez-Marin O, et al. The use of cell salvage during radical retropubic prostatectomy: does it influence cancer recurrence?. BJU Int. Apr. 2003;91(6):474-476. Not eligible exposure. [pmid: 12656896].
138 Davis NB, Jani AB, Vogelzang NJ. Selecting a secondary treatment. Urol Clin North Am. May. 2003;30(2):403-414. Review. [pmid: 12735514].
139 De La Rosette JJ, Abbou CC, Rassweiler J, et al. Laparoscopic radical prostatectomy: a European virus with global potentials. Arch Esp Urol. Jul–Aug. 2002;55(6):603-609. Review. [pmid: 12224159].
140 de la Taille A, Flam TA, Thiounn N, et al. Predictive factors of radiation therapy for patients with prostate specific antigen recurrence after radical prostatectomy. BJU Int. Dec. 2002;90(9):887-892. Not eligible exposure. [pmid: 12460351].
141 de Matteis A, Guidi A, Di Paolo B, et al. Endothelin-1 in human prostatic carcinoma treated with androgen withdrawal: an immunohistochemical study. Cancer. May 15. 2001;91(10):1933-1939. Not eligible exposure. [pmid: 11346876].
142 de Vere White R. Present and future management of prostate cancer. Cancer Biother Radiopharm. Apr. 2000;15(2):121-125. Editorial. [pmid: 10803316].
143 Dearnaley DP. Radiotherapy of prostate cancer: established results and new developments. Semin Surg Oncol. Jan–Feb. 1995;11(1):50-59. Review. [pmid: 7754276].
144 Demanes DJ, Rodriguez RR, Schour L, et al. High-dose-rate intensity-modulated brachytherapy with external beam radiotherapy for prostate cancer: California endocurietherapy's 10-year results. Int J Radiat Oncol Biol Phys. Apr 1. 2005;61(5):1306-1316. Not eligible exposure. [pmid: 15817332].
145 Derweesh IH, Kupelian PA, Zippe C, et al. Continuing trends in pathological stage migration in radical prostatectomy specimens. Urol Oncol. Jul–Aug. 2004;22(4):300-306. Not eligible exposure. [pmid: 15283887].
146 Desai S, Kulkarni JN. Re: Long-term outcome in patients with pTxN+ adenocarcinoma of prostate treated with radical prostatectomy and early androgen ablation. J Urol. Oct. 1998;160(4):1442. Comment. [pmid: 9751387].
147 deVere White RW, Hackman RM, Soares SE, et al. Effects of a genistein-rich extract on PSA levels in men with a history of prostate cancer. Urology. Feb. 2004;63(2):259-263. Not eligible exposure. [pmid: 14972467].
148 Di Blasio CJ, Rhee AC, Cho D, et al. Predicting clinical end points: treatment nomograms in prostate cancer. Semin Oncol. Oct. 2003;30(5):567-586. Review. [pmid: 14571407].
149 Di Silverio F, D'Eramo G, Buscarini M, et al. Is there always a role for radical prostatectomy in the treatment of localized prostate cancer?. Minerva Urol Nefrol. Sep. 1995;47(3):117-124. Review. [pmid: 8815548].
150 Di Silverio F, D'Eramo G, Buscarini M, et al. DNA ploidy, Gleason score, pathological stage and serum PSA levels as predictors of disease-free survival in C-D1 prostatic cancer patients submitted to radical retropubic prostatectomy. Eur Urol. 1996;30(3):316-321. Not eligible exposure. [pmid: 8931963].
151 Dillioglugil O, Leibman BD, Kattan MW, et al. Hazard rates for progression after radical prostatectomy for clinically localized prostate cancer. Urology. Jul. 1997;50(1):93-99. Not eligible exposure. [pmid: 9218025].
152 DiMarco DS, Zincke H, Sebo TJ, et al. The extent of lymphadenectomy for pTXNO prostate cancer does not affect prostate cancer outcome in the prostate specific antigen era. J Urol. Apr. 2005;173(4):1121-1125. Not eligible exposure. [pmid: 15758719].
153 DiPaola RS, Chenven ES, Shih WJ, et al. Mitoxantrone in patients with prostate specific antigen progression after local therapy for prostate carcinoma. Cancer. Oct 15. 2001;92(8):2065-2071. Not eligible exposure. [pmid: 11596021].
154 Ditonno P, Battaglia M, Selvaggi FP. Adjuvant hormone therapy after radical prostatectomy: indications and results. Tumori. Mar–Apr. 1997;83(2):567-575. Review. [pmid: 9226023].
155 Djavan B, Moul JW, Zlotta A, et al. PSA progression following radical prostatectomy and radiation therapy: new standards in the new Millennium. Eur Urol. Jan. 2003;43(1):12-27. Review. [pmid: 12507539].
156 Djavan B, Susani M, Shariat S, et al. Transperineal radiofrequency interstitial tumor ablation (RITA) of the prostate. Tech Urol. Jun. 1998;4(2):103-109. Not eligible exposure. [pmid: 9623628].
157 Do T, Dave G, Parker R, et al. Serum PSA evaluations during salvage radiotherapy for post-prostatectomy biochemical failures as prognosticators for treatment outcomes. Int J Radiat Oncol Biol Phys. Aug 1. 2001;50(5):1220-1225. Not eligible exposure. [pmid: 11483332].
158 Donovan J, Hamdy F, Neal D, et al. Prostate Testing for Cancer and Treatment (ProtecT) feasibility study. Health Technol Assess. 2003;7(14):1-88. Review. [pmid: 12709289].
159 Downs TM, Kane CJ, Grossfeld GD, et al. Surgery for prostate cancer: rationale, technique and outcomes. Cancer Metastasis Rev. 2002;21(1):29-44. Review. [pmid: 12400995].
160 Downs TM, Sadetsky N, Pasta DJ, et al. Health related quality of life patterns in patients treated with interstitial prostate brachytherapy for localized prostate cancer—data from CaPSURE. J Urol. Nov. 2003;170(5):1822-1827. Not eligible exposure. [pmid: 14532784].
161 Dreicer R. Controversies in the systemic management of patients with evidence of biochemical failure following radical prostatectomy. Cancer Treat Rev. Aug. 2002;28(4):189-194. Review. [pmid: 12363459].
162 Dreicer R, Magi-Galluzzi C, Zhou M, et al. Phase II trial of neoadjuvant docetaxel before radical prostatectomy for locally advanced prostate cancer. Urology. Jun. 2004;63(6):1138-1142. Not eligible exposure. [pmid: 15183967].
163 Duchesne GM, Dowling C, Frydenberg M, et al. Outcome, morbidity, and prognostic factors in post-prostatectomy radiotherapy: an Australian multicenter study. Urology. Jan. 2003;61(1):179-183. Not eligible exposure. [pmid: 12559292].
164 Dunsmuir WD, McFarlane JP, Tan A, et al. Gyrus bipolar electrovaporization vs transurethral resection of the prostate: a randomized prospective single-blind trial with 1 y follow-up. Prostate Cancer Prostatic Dis. 2003;6(2):182-186. Not eligible exposure. [pmid: 12806380].
165 Eastham JA, Kelly WK, Grossfeld GD, et al. Cancer and Leukemia Group B (CALGB) 90203: a randomized phase 3 study of radical prostatectomy alone versus estramustine and docetaxel before radical prostatectomy for patients with high-risk localized disease. Urology. Dec 29. 2003;62(Suppl 1):55-62. Not eligible exposure. [pmid: 14747042].
166 Eden CG, Cahill D, Vass JA, et al. Laparoscopic radical prostatectomy: the initial UK series. BJU Int. Dec. 2002;90(9):876-882. Not eligible exposure. [pmid: 12460349].
167 Egawa S, Arai Y, Kawakita M, et al. Surgical outcome of laparoscopic radical prostatectomy: summary of early multiinstitutional experience in Japan. Int J Clin Oncol. Apr. 2003;8(2):97-103. No provider characteristics. [pmid: 12720102].
168 Egawa S, Matsui Y, Matsumoto K, et al. Impact of biochemical failure on long-term clinical outcome after radical prostatectomy for prostate cancer in Japan. Prostate Cancer Prostatic Dis. 2004;7(2):152-157. Not eligible exposure. [pmid: 15175664].
169 Egawa S, Matsumoto K, Iwamura M, et al. Impact of life expectancy and tumor doubling time on the clinical significance of prostate cancer in Japan. Jpn J Clin Oncol. Dec. 1997;27(6):394-400. Not eligible exposure. [pmid: 9438001].
170 Egawa S, Ohori M, Iwamura M, et al. Efficacy and limitations of delayed/salvage radiation therapy after radical prostatectomy. BJU Int. Nov. 1999;84(7):815-820. Not eligible exposure. [pmid: 10532978].
171 Egawa S, Suyama K, Arai Y, et al. A study of pretreatment nomograms to predict pathological stage and biochemical recurrence after radical prostatectomy for clinically resectable prostate cancer in Japanese men. Jpn J Clin Oncol. Feb. 2001;31(2):74-81. Not eligible exposure. [pmid: 11302346].
172 Egawa S, Suyama K, Arai Y, et al. Treatment outcome by risk group after radical prostatectomy in Japanese men. Int J Urol. Jun. 2001;8(6):295-300. Not eligible exposure. [pmid: 11389745].
173 Egevad L, Granfors T, Karlberg L, et al. Prognostic value of the Gleason score in prostate cancer. BJU Int. Apr. 2002;89(6):538-542. Not eligible exposure. [pmid: 11942960].
174 Elkin EB, Cowen ME, Cahill D, et al. Preference assessment method affects decision-analytic recommendations: a prostate cancer treatment example. Med Decis Making. Sep–Oct. 2004;24(5):504-510. Not eligible exposure. [pmid: 15358999].
175 Elliott K, Wallner K, Merrick G, et al. Medical malpractice of prostate brachytherapy. Brachytherapy. 2004;3(4):231-236. Not eligible exposure. [pmid: 15607155].
176 Eng TY, Thomas CR, Herman TS. Primary radiation therapy for localized prostate cancer. Urol Oncol. Nov–Dec. 2002;7(6):239-257. Review. [pmid: 12504845].
177 Epperson WJ. Radical prostatectomy in the treatment of prostate cancer. Am Fam Physician. Dec 1998;58(9):1972, 1977–1978. Comment.
178 Epstein JI, Partin AW, Potter SR, et al. Adenocarcinoma of the prostate invading the seminal vesicle: prognostic stratification based on pathologic parameters. Urology. Aug 1. 2000;56(2):283-288. Not eligible exposure. [pmid: 10925095].
179 Erdogru T, Teber D, Frede T, et al. Comparison of transperitoneal and extraperitoneal laparoscopic radical prostatectomy using match-pair analysis. Eur Urol. Sep. 2004;46(3):312-319. discussion 320. Not eligible exposure. [pmid: 15306100].
180 Escandon AS, Garcia OG. Use of a laparoscopic instrument to improve urethrovesical anastomosis quality during retropubic radical prostatectomy. Tech Urol. Mar. 2000;6(1):39-41. Not eligible exposure. [pmid: 10708148].
181 Evans RA. Re: Salvage radical prostatectomy: outcome measured by serum prostate specific antigen levels. J Urol. Aug. 1995;154(2 Pt 1):537-538. Comment. [pmid: 7541867].
182 Fair WR, Scher HI. Neoadjuvant hormonal therapy plus surgery for prostate cancer. The MSKCC experience. Surg Oncol Clin N Am. Oct. 1997;6(4):831-846. Review. [pmid: 9309096].
183 Farhat WA, Habbal AA, Khauli RB. A guideline to clinical utility of prostate specific antigen. Saudi Med J. Mar. 2000;21(3):223-227. Review. [pmid: 11533789].
184 Febbo PG, Sellers WR. Use of expression analysis to predict outcome after radical prostatectomy. J Urol. Dec. 2003;170(6 Pt 2):S11-19. discussion S19–20. Not eligible exposure. [pmid: 14610405].
185 Feleppa EJ, Fair WR, Liu T, et al. Three-dimensional ultrasound analyses of the prostate. Mol Urol. Fall. 2000;4(3):133-139. discussion 141. No provider characteristics. [pmid: 11062367].
186 Feneley MR, Gillatt DA, Hehir M, et al. A review of radical prostatectomy from three centres in the UK: clinical presentation and outcome. Br J Urol. Dec. 1996;78(6):911-918. discussion 919–920. Not eligible exposure. [pmid: 9014719].
187 Fergany A, Kupelian PA, Levin HS, et al. No difference in biochemical failure rates with or without pelvic lymph node dissection during radical prostatectomy in low-risk patients. Urology. Jul. 2000;56(1):92-95. Not eligible exposure. [pmid: 10869632].
188 Fichtner J. The management of prostate cancer in patients with a rising prostate-specific antigen level. BJU Int. Jul. 2000;86(2):181-190. quiz ii–iii. Review. [pmid: 10886105].
189 Filipas D, Fisch M, Stein R, et al. Rhabdomyosarcoma of the bladder, prostate or vagina: the role of surgery. BJU Int. Jan. 2004;93(1):125-129. Not eligible target population. [pmid: 14678383].
190 Fleming C, Wasson JH, Albertsen PC, et al. A decision analysis of alternative treatment strategies for clinically localized prostate cancer. Prostate Patient Outcomes Research Team. Jama. May 26. 1993;269(20):2650-2658. Not eligible exposure. [pmid: 8487449].
191 Fletcher SG, Theodorescu D. Surgery or radiation: what is the optimal management for locally advanced prostate cancer?. Can J Urol. Feb. 2005;12(Suppl 1):58-61. discussion 101–102. Review. [pmid: 15780168].
192 Flood AB, Scott WR, Ewy W. Does practice make perfect? Part I: The relation between hospital volume and outcomes for selected diagnostic categories. Med Care. Feb. 1984;22(2):98-114. Not eligible target population. [pmid: 6700280].
193 Foley CL, Bott SR, Thomas K, et al. A large prostate at radical retropubic prostatectomy does not adversely affect cancer control, continence or potency rates. BJU Int. Sep. 2003;92(4):370-374. Not eligible exposure. [pmid: 12930421].
194 Forman JD. The metamorphosis of a postprostatectomy patient: from curable to palliative. Urol Oncol. Jan–Feb. 2004;22(1):48-49. Not eligible exposure. [pmid: 14969804].
195 Forman JD, Velasco J. Therapeutic radiation in patients with a rising post-prostatectomy PSA level. Oncology (Williston Park). Jan. 1998;12(1):33-39. discussion 39, 43–34, 47. Review. [pmid: 9474586].
196 Forster TH, Stoffel F, Gasser TC. Hormone therapy in advanced prostate cancer. Front Radiat Ther Oncol. 2002;36:49-65. Review. [pmid: 11842755].
197 Fourcade RO. Adjuvant treatment for failure of local radical therapy. Eur Urol. 1997;31(Suppl 2):11-13. discussion 24–17. Not eligible exposure. [pmid: 9074905].
198 Fowler JE Jr, Braswell NT, Pandey P, et al. Experience with radical prostatectomy and radiation therapy for localized prostate cancer at a Veterans Affairs Medical Center. J Urol. Mar. 1995;153(3 Pt 2):1026-1031. Not eligible exposure. [pmid: 7853550].
199 Frauscher F, Gradl J, Pallwein L. Prostate ultrasound—for urologists only. Cancer Imaging. 2005;5(Spec No A):S76-82. Review. [pmid: 16361140].
200 Frazier HA, Robertson JE, Dodge RK, et al. The value of pathologic factors in predicting cancer-specific survival among patients treated with radical cystectomy for transitional cell carcinoma of the bladder and prostate. Cancer. Jun 15. 1993;71(12):3993-4001. Not eligible exposure. [pmid: 8508365].
201 Frazier HA, Robertson JE, Humphrey PA, et al. Is prostate specific antigen of clinical importance in evaluating outcome after radical prostatectomy. J Urol. Mar. 1993;149(3):516-518. Not eligible exposure. [pmid: 7679755].
202 Freedland SJ, Amling CL, Terris MK, et al. Is there a difference in outcome after radical prostatectomy between patients with biopsy Gleason sums 4, 5, and 6? Results from the SEARCH database. Prostate Cancer Prostatic Dis. 2003;6(3):261-265. Not eligible exposure. [pmid: 12970733].
203 Freedland SJ, Aronson WJ, Kane CJ, et al. Biochemical outcome after radical prostatectomy among men with normal preoperative serum prostate-specific antigen levels. Cancer. Aug 15. 2004;101(4):748-753. Not eligible exposure. [pmid: 15305405].
204 Freedland SJ, Aronson WJ, Terris MK, et al. Percent of prostate needle biopsy cores with cancer is significant independent predictor of prostate specific antigen recurrence following radical prostatectomy: results from SEARCH database. J Urol. Jun. 2003;169(6):2136-2141. Not eligible exposure. [pmid: 12771735].
205 Freedland SJ, deGregorio F, Sacoolidge JC, et al. Preoperative p27 status is an independent predictor of prostate specific antigen failure following radical prostatectomy. J Urol. Apr. 2003;169(4):1325-1330. Not eligible exposure. [pmid: 12629353].
206 Freedland SJ, Presti JC Jr, Kane CJ, et al. Do younger men have better biochemical outcomes after radical prostatectomy?. Urology. Mar. 2004;63(3):518-522. Not eligible exposure. [pmid: 15028449].
207 Froehner M, Koch R, Litz R, et al. Comparison of the American Society of Anesthesiologists Physical Status classification with the Charlson score as predictors of survival after radical prostatectomy. Urology. Oct. 2003;62(4):698-701. Not eligible exposure. [pmid: 14550446].
208 Froehner M, Koch R, Litz R, et al. Preoperative cardiopulmonary risk assessment as predictor of early noncancer and overall mortality after radical prostatectomy. Urology. Mar. 2003;61(3):596-600. Not eligible exposure. [pmid: 12639654].
209 Fromme EK, Eilers KM, Mori M, et al. How accurate is clinician reporting of chemotherapy adverse effects? A comparison with patient-reported symptoms from the Quality-of-Life Questionnaire C30. J Clin Oncol. Sep 1. 2004;22(17):3485-3490. Not eligible target population. [pmid: 15337796].
210 Fromont G, Guillonneau B, Validire P, et al. Laparoscopic radical prostatectomy. preliminary pathologic evaluation. Urology. Oct. 2002;60(4):661-665. Not eligible exposure. [pmid: 12385929].
211 Fujikawa K, Itoh T, Nishio Y, et al. The role of volume-weighted mean nuclear volume in predicting disease outcome in patients with prostate cancer treated with radical prostatectomy. Apmis. Aug. 1999;107(8):773-778. Not eligible exposure. [pmid: 10515128].
212 Fukawa T, Numata K, Yamanaka M, et al. Prostatic carcinosarcoma: a case report and review of literature. Int J Urol. Feb. 2003;10(2):108-113. Review. [pmid: 12588610].
213 Galalae RM, Kovacs G, Schultze J, et al. Long-term outcome after elective irradiation of the pelvic lymphatics and local dose escalation using high-dose-rate brachytherapy for locally advanced prostate cancer. Int J Radiat Oncol Biol Phys. Jan 1. 2002;52(1):81-90. Not eligible exposure. [pmid: 11777625].
214 Gallucci M, Puppo P, Perachino M, et al. Transurethral electrovaporization of the prostate vs transurethral resection. Results of a multicentric, randomized clinical study on 150 patients. Eur Urol. 1998;33(4):359-364. Not eligible target population. [pmid: 9612677].
215 Gancarczyk KJ, Wu H, McLeod DG, et al. Using the percentage of biopsy cores positive for cancer, pretreatment PSA, and highest biopsy Gleason sum to predict pathologic stage after radical prostatectomy: the Center for Prostate Disease Research nomograms. Urology. Mar. 2003;61(3):589-595. Not eligible exposure. [pmid: 12639653].
216 Gao X, Qiu JG, Cai YB, et al. Laparoscopic radical prostatectomy. Chin Med J (Engl). Jan. 2004;117(1):148-149. Case reports. [pmid: 14733793].
217 Gardner TA, Bissonette EA, Petroni GR, et al. Surgical and postoperative factors affecting length of hospital stay after radical prostatectomy. Cancer. Jul 15. 2000;89(2):424-430. Not eligible exposure. [pmid: 10918175].
218 Garg MK, Tekyi-Mensah S, Bolton S, et al. Impact of postprostatectomy prostate-specific antigen nadir on outcomes following salvage radiotherapy. Urology. Jun. 1998;51(6):998-1002. Not eligible exposure. [pmid: 9609639].
219 Garnick MB, Fair WR. Prostate cancer: emerging concepts. Part I. Ann Intern Med. Jul 15. 1996;125(2):118-125. Review. [pmid: 8678366].
220 Garrett KL, McNeal JE, Cohen RJ. Intraoperative lymph node staging of prostate cancer: the case against. ANZ J Surg. May. 2003;73(5):263-266. Not eligible exposure. [pmid: 12752279].
221 Garzotto M, Wajsman Z. Androgen deprivation with salvage surgery for radiorecurrent prostate cancer: results at 5-year followup. J Urol. Mar. 1998;159(3):950-954. discussion 954–955. Not eligible exposure. [pmid: 9474190].
222 George DJ. Receptor tyrosine kinases as rational targets for prostate cancer treatment: platelet-derived growth factor receptor and imatinib mesylate. Urology. Sep. 2002;60(3 Suppl 1):115-121. discussion 122. Review. [pmid: 12231066].
223 Gerber GS. Conservative approach to the management of prostate cancer. A critical review. Eur Urol. 1994;26(4):271-275. Review. [pmid: 7713123].
224 Gheiler EL, Tefilli MV, Tiguert R, et al. Predictors for maximal outcome in patients undergoing salvage surgery for radio-recurrent prostate cancer. Urology. May. 1998;51(5):789-795. Not eligible exposure. [pmid: 9610593].
225 Gill IS. Laparoscopic pelvic lymphadenectomy: transperitoneal approach. Semin Surg Oncol. Mar–Apr. 1996;12(2):126-133. Review. [pmid: 8685578].
226 Gilling PJ, Kennett K, Das AK, et al. Holmium laser enucleation of the prostate (HoLEP) combined with transurethral tissue morcellation: an update on the early clinical experience. J Endourol. Oct. 1998;12(5):457-459. Not eligible exposure. [pmid: 9847070].
227 Gilling PJ, Kennett KM, Fraundorfer MR. Holmium laser enucleation of the prostate for glands larger than 100 g: an endourologic alternative to open prostatectomy. J Endourol. Aug. 2000;14(6):529-531. Not eligible exposure. [pmid: 10954311].
228 Gleave ME, Bruchovsky N, Moore MJ, et al. Prostate cancer: 9. Treatment of advanced disease. Cmaj. Jan 26. 1999;160(2):225-232. Review. [pmid: 9951446].
229 Gleave ME, Goldenberg SL, Jones EC, et al. Optimal duration of neoadjuvant androgen withdrawal therapy before radical prostatectomy in clinically confined prostate cancer. Semin Urol Oncol. May. 1996;14(2 Suppl 2):39-45. discussion 46–37. Review. [pmid: 8725890].
230 Gleave ME, La Bianca SE, Goldenberg SL, et al. Long-term neoadjuvant hormone therapy prior to radical prostatectomy: evaluation of risk for biochemical recurrence at 5-year follow-up. Urology. Aug 1. 2000;56(2):289-294. Not eligible exposure. [pmid: 10925096].
231 Glode LM. Early prostate cancer diagnosis and therapy. Adv Intern Med. 2000;45:41-64. Review. [pmid: 10635045].
232 Goharderakhshan RZ, Grossfeld GD, Kassis A, et al. Additional treatments and reimbursement rates associated with prostate cancer treatment for patients undergoing radical prostatectomy, interstitial brachytherapy, and external beam radiotherapy. Urology. Oct 1. 2000;56(4):622-626. Not eligible exposure. [pmid: 11018618].
233 Goluboff ET, Benson MC. External beam radiation therapy does not offer long-term control of prostate cancer. Urol Clin North Am. Nov. 1996;23(4):617-621. Review. [pmid: 8948415].
234 Gomella LG, Zeltser I, Valicenti RK. Use of neoadjuvant and adjuvant therapy to prevent or delay recurrence of prostate cancer in patients undergoing surgical treatment for prostate cancer. Urology. Dec 29. 2003;62(Suppl 1):46-54. Review. [pmid: 14747041].
235 Gomez P, Manoharan M, Sved P, et al. Radical retropubic prostatectomy in Hispanic patients. Cancer. Apr 15. 2004;100(8):1628-1632. Not eligible exposure. [pmid: 15073849].
236 Gomha MA, Boone TB. Artificial urinary sphincter for post-prostatectomy incontinence in men who had prior radiotherapy: a risk and outcome analysis. J Urol. Feb. 2002;167(2 Pt 1):591-596. Not eligible exposure. [pmid: 11792924].
237 Gontero P, Fontana F, Zitella A, et al. A prospective evaluation of efficacy and compliance with a multistep treatment approach for erectile dysfunction in patients after non-nerve sparing radical prostatectomy. BJU Int. Feb. 2005;95(3):359-365. Not eligible exposure. [pmid: 15679794].
238 Gontero P, Kirby RS. Nerve-sparing radical retropubic prostatectomy: techniques and clinical considerations. Prostate Cancer Prostatic Dis. 2005;8(2):133-139. Review. [pmid: 15711608].
239 Gorey K, Holowaty E, Fehringer G, et al. Gorey K, Holowaty E, Fehringer G, et al. An international comparison of cancer survival: metropolitan Toronto, Ontario, and Honolulu, Hawaii. Am J Public Health. December 1, 2000 2000;90(12):1866–1872. Not eligible target population.
240 Gould RS. Total cryosurgery of the prostate versus standard cryosurgery versus radical prostatectomy: comparison of early results and the role of transurethral resection in cryosurgery. J Urol. Nov. 1999;162(5):1653-1657. Not eligible exposure. [pmid: 10524891].
241 Graefen M, Karakiewicz PI, Cagiannos I, et al. Percent free prostate specific antigen is not an independent predictor of organ confinement or prostate specific antigen recurrence in unscreened patients with localized prostate cancer treated with radical prostatectomy. J Urol. Mar. 2002;167(3):1306-1309. Not eligible exposure. [pmid: 11832719].
242 Graefen M, Noldus J, Pichlmeier U, et al. Early prostate-specific antigen relapse after radical retropubic prostatectomy: prediction on the basis of preoperative and postoperative tumor characteristics. Eur Urol. 1999;36(1):21-30. Not eligible exposure. [pmid: 10364651].
243 Grampsas SA, Miller GJ, Crawford ED. Salvage radical prostatectomy after failed transperineal cryotherapy: histologic findings from prostate whole-mount specimens correlated with intraoperative transrectal ultrasound images. Urology. Jun. 1995;45(6):936-941. Not eligible exposure. [pmid: 7771026].
244 Gregorio DI, Kulldorff M, Sheehan TJ, et al. Geographic distribution of prostate cancer incidence in the era of PSA testing, Connecticut, 1984 to 1998. Urology. 2004/1 2004;63(1):78–82. Not eligible outcomes.
245 Grein U, Meyer WW. Local recurrent cancer after radical prostatectomy and incontinence. Is the artificial urinary sphincter a useful therapeutic option?. Urol Int. 2001;66(1):9-12. Not eligible exposure. [pmid: 11150943].
246 Gretzer MB, Trock BJ, Han M, et al. A critical analysis of the interpretation of biochemical failure in surgically treated patients using the American Society for Therapeutic Radiation and Oncology criteria. J Urol. Oct. 2002;168(4 Pt 1):1419-1422. Not eligible exposure. [pmid: 12352408].
247 Grignon DJ, Sakr WA. Pathologic staging of prostate carcinoma. What are the issues?. Cancer. Jul 15. 1996;78(2):337-340. Review. [pmid: 8674013].
248 Grimm MO, Kamphausen S, Hugenschmidt H, et al. Clinical outcome of patients with lymph node positive prostate cancer after radical prostatectomy versus androgen deprivation. Eur Urol. Jun. 2002;41(6):628-634. discussion 634. Not eligible exposure. [pmid: 12074780].
249 Grimm PD, Blasko JC, Sylvester JE, et al. Technical improvement in permanent seed implantation: a two-stage brachytherapy system. Description and comparison with current technique. Brachytherapy. 2004;3(1):34-40. No provider characteristics. [pmid: 15110312].
250 Grise P, Thurman S. Urinary incontinence following treatment of localized prostate cancer. Cancer Control. Nov–Dec. 2001;8(6):532-539. Review. [pmid: 11807423].
251 Gross C, Stamey T, Hancock S, et al. Treatment of early recurrent prostate cancer with 1,25-dihydroxyvitamin D3 (calcitriol). J Urol. Jun. 1998;159(6):2035-2039. discussion 2039–2040. Not eligible exposure. [pmid: 9598513].
252 Grossfeld GD, Li YP, Lubeck DP, et al. Patterns of failure after primary local therapy for prostate cancer and rationale for secondary therapy. Urology. Sep. 2002;60(3 Suppl 1):57-62. discussion 62–53. Review. [pmid: 12231051].
253 Grossfeld GD, Small EJ, Lubeck DP, et al. Androgen deprivation therapy for patients with clinically localized (stages T1 to T3) prostate cancer and for patients with biochemical recurrence after radical prostatectomy. Urology. Aug. 2001;58(2 Suppl 1):56-64. Review. [pmid: 11502450].
254 Guazzoni G, Montorsi F, Bergamaschi F, et al. Open surgical revision of laparoscopic pelvic lymphadenectomy for staging of prostate cancer: the impact of laparoscopic learning curve. J Urol. Apr. 1994;151(4):930-933. No provider characteristics. [pmid: 8126828].
255 Guillonneau B, Cathelineau X, Barret E, et al. Laparoscopic radical prostatectomy: technical and early oncological assessment of 40 operations. Eur Urol. 1999;36(1):14-20. Not eligible exposure. [pmid: 10364650].
256 Guillonneau B, Cathelineau X, Doublet JD, et al. Laparoscopic radical prostatectomy: the lessons learned. J Endourol. May. 2001;15(4):441-445. discussion 447–448. Not eligible exposure. [pmid: 11394459].
257 Guillonneau B, Vallancien G. Laparoscopic radical prostatectomy: the Montsouris technique. J Urol. Jun. 2000;163(6):1643-1649. Not eligible exposure. [pmid: 10799152].
258 Gurdal M, Tekin A, Yucebas E, et al. Nd:YAG laser ablation plus transurethral resection for large prostates in high-risk patients. Urology. Nov. 2003;62(5):914-917. Not eligible target population. [pmid: 14624919].
259 Hachiya T, Akakura K, Saito S, et al. A retrospective study of the treatment of locally advanced prostate cancer by six institutions in eastern and north-eastern Japan. BJU Int. Mar. 2005;95(4):534-540. Not eligible exposure. [pmid: 15705075].
260 Hachiya T, Endo M, Nogaki J, et al. Significance of prostate-specific antigen after radical prostatectomy. Int J Urol. Sep. 1997;4(5):461-466. Not eligible exposure. [pmid: 9354947].
261 Haese A, Huland E, Graefen M, et al. Supersensitive PSA-analysis after radical prostatectomy: a powerful tool to reduce the time gap between surgery and evidence of biochemical failure. Anticancer Res. Jul–Aug. 1999;19(4A):2641-2644. Not eligible exposure. [pmid: 10470210].
262 Haggman M, Brandstedt S, Norlen BJ. Rectal perforation after retropubic radical prostatectomy: occurrence and management. Eur Urol. 1996;29(3):337-340. Not eligible exposure. [pmid: 8740020].
263 Hammadeh MY, Madaan S, Hines J, et al. 5-year outcome of a prospective randomized trial to compare transurethral electrovaporization of the prostate and standard transurethral resection. Urology. Jun. 2003;61(6):1166-1171. Not eligible target population. [pmid: 12809891].
264 Hammadeh MY, Philp T. Transurethral electrovaporization of the prostate (TUVP) is effective, safe and durable. Prostate Cancer Prostatic Dis. 2003;6(2):121-126. Review. [pmid: 12806369].
265 Han KR, Cohen JK, Miller RJ, et al. Treatment of organ confined prostate cancer with third generation cryosurgery: preliminary multicenter experience. J Urol. Oct. 2003;170(4 Pt 1):1126-1130. No provider characteristics. [pmid: 14501706].
266 Han M, Snow PB, Epstein JI, et al. A neural network predicts progression for men with gleason score 3+4 versus 4+3 tumors after radical prostatectomy. Urology. Dec 20. 2000;56(6):994-999. Not eligible exposure. [pmid: 11113746].
267 Handler S. How valuable is prostate-specific antigen screening?. Minn Med. Jun. 1996;79(6):2. Comment. [pmid: 8692130].
268 Hanks GE. External beam radiation treatment for prostate cancer: still the gold standard. Oncology (Williston Park). Mar 1992;6(3):79–86, 89; discussion 90–74. Not eligible exposure.
269 Hara I, Kawabata G, Miyake H, et al. Feasibility and usefulness of laparoscopic radical prostatectomy: Kobe University experience. Int J Urol. Nov. 2002;9(11):635-640. Not eligible exposure. [pmid: 12534908].
270 Harris MJ. Radical perineal prostatectomy: cost efficient, outcome effective, minimally invasive prostate cancer management. Eur Urol. Sep. 2003;44(3):303-308. discussion 308. Not eligible exposure. [pmid: 12932927].
271 Harris RD, Schned AR, Heaney JA. Staging of prostate cancer with endorectal MR imaging: lessons from a learning curve. Radiographics. Jul. 1995;15(4):813-829. discussion 829–832. No provider characteristics. [pmid: 7569131].
272 Hasan WA, Gill IS. Laparoscopic radical prostatectomy: current status. BJU Int. Jul. 2004;94(1):7-11. Review. [pmid: 15217422].
273 Hassan Y, Tazaki E, Egawa S, et al. Decision making using hybrid rough sets and neural networks. Int J Neural Syst. Dec. 2002;12(6):435-446. Not eligible exposure. [pmid: 12528195].
274 Hautmann RE, Stein JP. Neobladder with prostatic capsule and seminal-sparing cystectomy for bladder cancer: a step in the wrong direction. Urol Clin North Am. May. 2005;32(2):177-185. Review. [pmid: 15862615].
275 Hawatmeh AS, Walters FP, Wooster CA. Early clinical experience with percutaneous cryosurgical ablation of the prostate. Mo Med. Nov. 1995;92(11):705-709. No provider characteristics. [pmid: 8569673].
276 Held-Warmkessel J. What your patient needs to know about prostate cancer. Nursing. Dec. 2002;32(12):36-42. quiz N232. Review. [pmid: 12468938].
277 Hellerstedt B. Hormonal therapy options for patients with a rising prostate-specific antigen level after primary treatment for prostate cancer. Urology. Dec 29. 2003;62(Suppl 1):79-86. Review. [pmid: 14747045].
278 Henry AM, Wilkinson C, Wylie JP, et al. Trans-perineal implantation of radio-opaque treatment verification markers into the prostate: an assessment of procedure related morbidity, patient acceptability and accuracy. Radiother Oncol. Oct. 2004;73(1):57-59. No provider characteristics. [pmid: 15465146].
279 Herrell SD, Trachtenberg J, Theodorescu D. Staging pelvic lymphadenectomy for localized carcinoma of the prostate: a comparison of 3 surgical techniques. J Urol. Apr. 1997;157(4):1337-1339. No provider characteristics. [pmid: 9120934].
280 Hindley RG, Mostafid AH, Brierly RD, et al. The 2-year symptomatic and urodynamic results of a prospective randomized trial of interstitial radiofrequency therapy vs transurethral resection of the prostate. BJU Int. Aug. 2001;88(3):217-220. Not eligible target population. [pmid: 11488732].
281 Hoffman RM, Stone SN, Hunt WC, et al. Effects of Misattribution in Assigning Cause of Death on Prostate Cancer Mortality Rates. Annals of Epidemiology. 2003/7 2003;13(6):450–454. Not eligible exposure.
282 Hoinkis C, Hakenberg OW, Lehmann D, et al. Evaluation of dose-volume histograms after prostate seed implantation. 4-year experience. Strahlenther Onkol. Sep. 2004;180(9):550-556. No provider characteristics. [pmid: 15378185].
283 Hollenbeck BK, Rubin MA. Prostate sampling to predict radical prostatectomy outcome. Urology. Feb. 2001;57(2):394-395. Comment. [pmid: 11246646].
284 Holzman D. Surgery's role in prostate cancer spurs ongoing debate. J Natl Cancer Inst. Feb 19. 1997;89(4):282-283. News. [pmid: 9048830].
285 Homma Y, Akaza H, Okada K, et al. Preoperative endocrine therapy for clinical stage A2, B, and C prostate cancer: an interim report on short-term effects. Prostate Cancer Study Group. Int J Urol. Mar. 1997;4(2):144-151. Not eligible exposure. [pmid: 9179687].
286 Homma Y, Akaza H, Okada K, et al. Early results of radical prostatectomy and adjuvant endocrine therapy for prostate cancer with or without preoperative androgen deprivation. The Prostate Cancer Study Group. Int J Urol. May. 1999;6(5):229-237. discussion 238–229. Not eligible exposure. [pmid: 10375185].
287 Homma Y, Akaza H, Okada K, et al. Radical prostatectomy and adjuvant endocrine therapy for prostate cancer with or without preoperative androgen deprivation: Five-year results. Int J Urol. May. 2004;11(5):295-303. Not eligible exposure. [pmid: 15147545].
288 Homma Y, Kawabe K, Hayashi K. Urologic morbidity and its influence on global satisfaction with treatment outcome after radical prostatectomy for prostate cancer. Int J Urol. Nov. 1998;5(6):556-561. Not eligible exposure. [pmid: 9855124].
289 Horwich A, Parker CC, Huddart RA, et al. Management of early prostate cancer. Ann Oncol. 2002;13(Suppl 4):83-87. Review. [pmid: 12401671].
290 Horwitz EM, Hanlon AL, Pinover WH, et al. The cost effectiveness of 3D conformal radiation therapy compared with conventional techniques for patients with clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. Dec 1. 1999;45(5):1219-1225. Not eligible exposure. [pmid: 10613316].
291 Hoznek A, Antiphon P, Borkowski T, et al. Assessment of surgical technique and perioperative morbidity associated with extraperitoneal versus transperitoneal laparoscopic radical prostatectomy. Urology. Mar. 2003;61(3):617-622. Not eligible exposure. [pmid: 12639658].
292 Hoznek A, Menard Y, Salomon L, et al. Update on laparoscopic and robotic radical prostatectomy. Curr Opin Urol. May. 2005;15(3):173-180. Review. [pmid: 15815194].
293 Hsu EI, Hong EK, Lepor H. Influence of body weight and prostate volume on intraoperative, perioperative, and postoperative outcomes after radical retropubic prostatectomy. Urology. Mar. 2003;61(3):601-606. Not eligible exposure. [pmid: 12639655].
294 Hughes PD. Prostate cancer in Victoria in 1993: patterns of reported management. Med J Aust. Jun 5. 2000;172(11):565-566. Comment. [pmid: 10920760].
295 Hugosson J, Bergdahl S, Norlen L, et al. Outpatient transurethral incision of the prostate under local anesthesia: operative results, patient security and cost effectiveness. Scand J Urol Nephrol. 1993;27(3):381-385. Not eligible target population. [pmid: 7507261].
296 Huland H. The risks outweigh the benefits of radical prostatectomy in localised prostate cancer: the argument against. Eur Urol. 1996;29(Suppl 2):31-33. Review. [pmid: 8717459].
297 Hussain A, Dawson N, Amin P, et al. Docetaxel followed by hormone therapy in men experiencing increasing prostate-specific antigen after primary local treatments for prostate cancer. J Clin Oncol. Apr 20. 2005;23(12):2789-2796. Not eligible exposure. [pmid: 15837994].
298 Ilkjaer LB, Lund L, Nielsen KT. Outcome of transurethral prostatectomy in men over 80 years. Scand J Urol Nephrol. Jul. 1998;32(4):270-272. Not eligible exposure. [pmid: 9764454].
299 Imperato PJ, Nenner RP, Will TO. Trends in radical prostatectomy in New York State. Am J Med Qual. Winter. 1996;11(4):205-213. Not eligible exposure. [pmid: 8972938].
300 Iselin CE, Box JW, Vollmer RT, et al. Surgical control of clinically localized prostate carcinoma is equivalent in African-American and white males. Cancer. Dec 1. 1998;83(11):2353-2360. Not eligible exposure. [pmid: 9840535].
301 Iselin CE, Robertson JE, Paulson DF. Radical perineal prostatectomy: oncological outcome during a 20-year period. J Urol. Jan. 1999;161(1):163-168. Not eligible exposure. [pmid: 10037390].
302 Isom-Batz G, Bianco FJ Jr, Kattan MW, et al. Testosterone as a predictor of pathological stage in clinically localized prostate cancer. J Urol. Jun. 2005;173(6):1935-1937. Not eligible exposure. [pmid: 15879785].
303 Iversen P, Madsen PO, Corle DK. Radical prostatectomy versus expectant treatment for early carcinoma of the prostate. Twenty-three year follow-up of a prospective randomized study. Scand J Urol Nephrol Suppl. 1995;172:65-72. Not eligible exposure. [pmid: 8578259].
304 Jackson CL. Urologic laparoscopy. Surg Oncol Clin N Am. Jul. 2001;10(3):571-578. Review. [pmid: 11685928].
305 Jani AB, Kao J. Postprostatectomy adjuvant versus salvage radiotherapy: a complication-adjusted number-needed-to-treat analysis. Cancer. May 1. 2005;103(9):1833-1842. Review. [pmid: 15756656].
306 Janoff DM, Parra RO. Contemporary appraisal of radical perineal prostatectomy. J Urol. Jun. 2005;173(6):1863-1870. Review. [pmid: 15879765].
307 Jarred RA, Keikha M, Dowling C, et al. Induction of apoptosis in low to moderate-grade human prostate carcinoma by red clover-derived dietary isoflavones. Cancer Epidemiol Biomarkers Prev. Dec. 2002;11(12):1689-1696. Not eligible exposure. [pmid: 12496063].
308 Jayadevappa R, Chhatre S, Weiner M, et al. Medical care cost of patients with prostate cancer. Urol Oncol. May–Jun. 2005;23(3):155-162. Not eligible exposure. [pmid: 15907714].
309 Jhaveri FM, Zippe CD, Klein EA, et al. Biochemical failure does not predict overall survival after radical prostatectomy for localized prostate cancer: 10-year results. Urology. Nov. 1999;54(5):884-890. Not eligible exposure. [pmid: 10565752].
310 Jo Y, Junichi H, Tomohiro F, et al. Radical prostatectomy versus high-dose rate brachytherapy for prostate cancer: effects on health-related quality of life. BJU Int. Jul. 2005;96(1):43-47. Not eligible exposure. [pmid: 15963118].
311 Johnson CW, Anastasiadis AG, McKiernan JM, et al. Prognostic indicators for long term outcome following radical retropubic prostatectomy for prostate cancer involving the seminal vesicles. Urol Oncol. Mar–Apr. 2004;22(2):107-111. Not eligible exposure. [pmid: 15082006].
312 Kabalin JN, Bite G, Doll S. Neodymium:YAG laser coagulation prostatectomy: 3 years of experience with 227 patients. J Urol. Jan. 1996;155(1):181-185. Not eligible exposure. [pmid: 7490827].
313 Kahn D, Austin JC, Maguire RT, et al. A phase II study of [90Y] yttrium-capromab pendetide in the treatment of men with prostate cancer recurrence following radical prostatectomy. Cancer Biother Radiopharm. Apr. 1999;14(2):99-111. Not eligible exposure. [pmid: 10850293].
314 Kahn D, Williams RD, Haseman MK, et al. Radioimmunoscintigraphy with In-111-labeled capromab pendetide predicts prostate cancer response to salvage radiotherapy after failed radical prostatectomy. J Clin Oncol. Jan. 1998;16(1):284-289. Not eligible exposure. [pmid: 9440754].
315 Kaisary AV. Evaluating the use of early hormonal therapy in patients with localised or locally advanced prostate cancer. Prostate Cancer Prostatic Dis. 2005;8(2):140-151. Review. [pmid: 15852051].
316 Kanto S, Ohyama C, Okada Y, et al. Clinical features of prostate cancer patients younger than 50 years: report of seven cases. Int J Urol. Feb. 2002;9(2):91-94. Not eligible exposure. [pmid: 12028298].
317 Kantoff PW, Talcott JA. The prostate specific antigen. Its use as a tumor marker for prostate cancer. Hematol Oncol Clin North Am. Jun. 1994;8(3):555-572. Review. [pmid: 8707772].
318 Kattan MW. Comparison of Cox regression with other methods for determining prediction models and nomograms. J Urol. Dec. 2003;170(6 Pt 2):S6-9. discussion S10. No provider characteristics. [pmid: 14610404].
319 Kattan MW, Eastham JA, Stapleton AM, et al. A preoperative nomogram for disease recurrence following radical prostatectomy for prostate cancer. J Natl Cancer Inst. May 20. 1998;90(10):766-771. Not eligible exposure. [pmid: 9605647].
320 Kattan MW, Wheeler TM, Scardino PT. Postoperative nomogram for disease recurrence after radical prostatectomy for prostate cancer. J Clin Oncol. May. 1999;17(5):1499-1507. Not eligible exposure. [pmid: 10334537].
321 Kaufman JM. Re: Factors predicting recovery of erections after radical prostatectomy. J Urol. Aug. 2001;166(2):634. Comment. [pmid: 11458107].
322 Kavoussi LR, Sosa E, Chandhoke P, et al. Complications of laparoscopic pelvic lymph node dissection. J Urol. Feb. 1993;149(2):322-325. No provider characteristics. [pmid: 8426411].
323 Kaye KW, Creed KE, Wilson GJ, et al. Urinary continence after radical retropubic prostatectomy. Analysis and synthesis of contributing factors: a unified concept. Br J Urol. Sep. 1997;80(3):444-501. Not eligible exposure. [pmid: 9313665].
324 Kendirci M, Hellstrom WJ. Current concepts in the management of erectile dysfunction in men with prostate cancer. Clin Prostate Cancer. Sep. 2004;3(2):87-92. Review. [pmid: 15479491].
325 Kerbl K, Clayman RV, Petros JA, et al. Staging pelvic lymphadenectomy for prostate cancer: a comparison of laparoscopic and open techniques. J Urol. Aug. 1993;150(2 Pt 1):396-398. discussion 399. No provider characteristics. [pmid: 8326562].
326 Keyser D, Kupelian PA, Zippe CD, et al. Stage T1–2 prostate cancer with pretreatment prostate-specific antigen level < or = 10 ng/ml: radiation therapy or surgery?. Int J Radiat Oncol Biol Phys. Jul 1. 1997;38(4):723-729. Not eligible exposure. [pmid: 9240638].
327 Khan FA, Kaisary AV, Boustead GB, et al. PSA recurrence following radical prostatectomy is comparable for all age groups in the UK. Prostate Cancer Prostatic Dis. 2005;8(2):158-162. Not eligible exposure. [pmid: 15768048].
328 Khan MA, Han M, Partin AW, et al. Long-term cancer control of radical prostatectomy in men younger than 50 years of age: update 2003. Urology. Jul. 2003;62(1):86-91. discussion 91–82. Not eligible exposure. [pmid: 12837428].
329 Khatami A, Damber JE, Lodding P, et al. Does initial surveillance in early prostate cancer reduce the chance of cure by radical prostatectomy?—A case control study. Scand J Urol Nephrol. 2003;37(3):213-217. Not eligible exposure. [pmid: 12775279].
330 Khil MS, Kim JH. Therapeutic options for localized carcinoma of the prostate: the role of external beam radiation therapy. Henry Ford Hosp Med J. 1992;40(12):103-107. Review. [pmid: 1428958].
331 Kiel HJ, Wieland WF, Rossler W. Local control of prostate cancer by transrectal HIFU-therapy. Arch Ital Urol Androl. Dec. 2000;72(4):313-319. No provider characteristics. [pmid: 11221062].
332 Kim BS, Lashkari A, Vongtama R, et al. Effect of pelvic lymph node irradiation in salvage therapy for patients with prostate cancer with a biochemical relapse following radical prostatectomy. Clin Prostate Cancer. Sep. 2004;3(2):93-97. Not eligible exposure. [pmid: 15479492].
333 Kim JC, Gerber GS. Should laparoscopy be the standard approach used for pelvic lymph node dissection?. Curr Urol Rep. Apr. 2001;2(2):171-179. Review. [pmid: 12084287].
334 King CR, Presti JC Jr, Gill H, et al. Radiotherapy after radical prostatectomy: does transient androgen suppression improve outcomes?. Int J Radiat Oncol Biol Phys. Jun 1. 2004;59(2):341-347. Not eligible exposure. [pmid: 15145146].
335 Kiriyama I, Ohgaki K, Ohba S, et al. Prostate cancer in patients with Hansen's disease. Int J Urol. Mar. 2003;10(3):177-179. Not eligible target population. [pmid: 12622716].
336 Kish JA. Neoadjuvant androgen ablation in localized carcinoma of the prostate. Cancer Control. Mar–Apr. 2001;8(2):155-162. Review. [pmid: 11326170].
337 Kiyokawa H, Kato H. Radical retropubic prostatectomy through a minimal incision with portless endoscopy: our initial experience. Int J Urol. Jan. 2006;13(1):7-9. No provider characteristics. [pmid: 16448424].
338 Klabunde CN, Potosky AL, Harlan LC, et al. Trends and black/white differences in treatment for nonmetastatic prostate cancer. Med Care. Sep. 1998;36(9):1337-1348. Not eligible outcomes. [pmid: 9749657].
339 Klassen AC, Curriero FC, Hong JH, et al. The role of area-level influences on prostate cancer grade and stage at diagnosis. Preventive Medicine. 2004/9 2004;39(3):441–448. Not eligible outcomes.
340 Klee LW, Grmoljez P. Combined radical retropubic prostatectomy and rectal resection. Urology. Oct. 1999;54(4):679-681. Not eligible exposure. [pmid: 10510927].
341 Klein EA. Prostate cancer. J Urol. Jul. 1995;154(1):143-144. Comment. [pmid: 7539858].
342 Klein EA. Radiation therapy versus radical prostatectomy in the PSA era: a urologist's view. Semin Radiat Oncol. Apr. 1998;8(2):87-94. Review. [pmid: 9516589].
343 Klein EA, Kupelian PA, Dreicer R, et al. Locally advanced prostate cancer. Curr Treat Options Oncol. Oct. 2001;2(5):403-411. Review. [pmid: 12057103].
344 Klein EA, Kupelian PA, Tuason L, et al. Initial dissection of the lateral fascia reduces the positive margin rate in radical prostatectomy. Urology. May. 1998;51(5):766-773. Not eligible exposure. [pmid: 9610590].
345 Klutke CG, Tiemann DD, Nadler RB, et al. Antegrade collagen injection for stress incontinence after radical prostatectomy: technique and early results. J Endourol. Jun. 1996;10(3):279-282. Not eligible exposure. [pmid: 8740392].
346 Knight SJ, Nathan DP, Siston AK, et al. Pilot study of a utilities-based treatment decision intervention for prostate cancer patients. Clin Prostate Cancer. Sep. 2002;1(2):105-114. Not eligible exposure. [pmid: 15046701].
347 Koch MO. Predicting outcomes after radical prostatectomy. J Urol. Nov. 2000;164(5):1601. Comment. [pmid: 11025713].
348 Koch MO, Foster RS, Bell B, et al. Characterization and predictors of prostate specific antigen progression rates after radical retropubic prostatectomy. J Urol. Sep. 2000;164(3 Pt 1):749-753. Not eligible exposure. [pmid: 10953139].
349 Koch MO, Smith JA Jr. Influence of patient age and co-morbidity on outcome of a collaborative care pathway after radical prostatectomy and cystoprostatectomy. J Urol. May. 1996;155(5):1681-1684. Not eligible exposure. [pmid: 8627853].
350 Kochakarn W, Ratana-Olarn K, Viseshsindh V. Vesicourethral strictures after radical prostatectomy: review of treatment and outcome. J Med Assoc Thai. Jan. 2002;85(1):63-66. Not eligible exposure. [pmid: 12075722].
351 Kollermann J, Caprano J, Budde A, et al. Follow-up of nondetectable prostate carcinoma (pT0) after prolonged PSA-monitored neoadjuvant hormonal therapy followed by radical prostatectomy. Urology. Sep. 2003;62(3):476-480. Not eligible exposure. [pmid: 12946750].
352 Kollermann MW, Pantel K, Enzmann T, et al. Supersensitive PSA-monitored neoadjuvant hormone treatment of clinically localized prostate cancer: effects on positive margins, tumor detection and epithelial cells in bone marrow. Eur Urol. Oct. 1998;34(4):318-324. Not eligible exposure. [pmid: 9748679].
353 Koppie TM, Grossfeld GD, Nudell DM, et al. Is anastomotic biopsy necessary before radiotherapy after radical prostatectomy?. J Urol. Jul. 2001;166(1):111-115. Not eligible exposure. [pmid: 11435834].
354 Korman HJ, Mulholland TL, Huang R. Preservation of fecal continence and bowel function after radical perineal and retropubic prostatectomy: a questionnaire-based outcomes study. Prostate Cancer Prostatic Dis. 2004;7(3):249-252. Not eligible exposure. [pmid: 15249929].
355 Koyanagi T. Assessing a new surgical procedure: an initial step to randomized trial. Int J Clin Oncol. Apr. 2003;8(2):124-125. Comment. [pmid: 12720108].
356 Krahn M, Ritvo P, Irvine J, et al. Patient and community preferences for outcomes in prostate cancer: implications for clinical policy. Med Care. Jan. 2003;41(1):153-164. Not eligible exposure. [pmid: 12544552].
357 Krogh J, Jensen JS, Iversen HG, et al. Age as a prognostic variable in patients undergoing transurethral prostatectomy. Scand J Urol Nephrol. 1993;27(2):225-229. Not eligible target population. [pmid: 8351477].
358 Kuefer R, Hofer MD, Zorn CS, et al. Assessment of a fragment of e-cadherin as a serum biomarker with predictive value for prostate cancer. Br J Cancer. Jun 6. 2005;92(11):2018-2023. Not eligible exposure. [pmid: 15870707].
359 Kumar V, Toussi H, Marr C, et al. The benefits of radical prostatectomy beyond cancer control in symptomatic men with prostate cancer. BJU Int. Mar. 2004;93(4):507-509. Not eligible exposure. [pmid: 15008719].
360 Kundel Y, Pfeffer R, Lauffer M, et al. Salvage prostatic fossa radiation therapy for biochemical failure after radical prostatectomy: the Sheba experience. Isr Med Assoc J. Jun. 2004;6(6):329-331. Not eligible exposure. [pmid: 15214457].
361 Kuyu H, Lee WR, Bare R, et al. Recent advances in the treatment of prostate cancer. Ann Oncol. Aug. 1999;10(8):891-898. Review. [pmid: 10509148].
362 Kylmala T, Kaipia A, Matikainen M. Management of prolonged urinary leakage at the urethro-vesical anastomosis. Urol Int. 2005;74(4):298-300. Case reports. [pmid: 15897692].
363 Lacombe L, Maillette A, Meyer F, et al. Expression of p21 predicts PSA failure in locally advanced prostate cancer treated by prostatectomy. Int J Cancer. May 20. 2001;95(3):135-139. Not eligible exposure. [pmid: 11307144].
364 LaFontaine P, Chan D, Partin AW, et al. Minilaparotomy radical retropubic prostatectomy: updated technique and results. Semin Urol Oncol. Feb. 2000;18(1):19-27. Not eligible exposure. [pmid: 10719926].
365 Lam JS, Sclar JD, Desai M, et al. Is Hispanic race an important predictor of treatment failure following radical prostatectomy for prostate cancer?. J Urol. Nov. 2004;172(5 Pt 1):1856-1859. Not eligible exposure. [pmid: 15540738].
366 Lance RS, Freidrichs PA, Kane C, et al. A comparison of radical retropubic with perineal prostatectomy for localized prostate cancer within the Uniformed Services Urology Research Group. BJU Int. Jan. 2001;87(1):61-65. Not eligible exposure. [pmid: 11121994].
367 Landmann C. Radiation therapy of localized prostate cancer. Ann Urol (Paris). 1994;28(4):207-220. Not eligible exposure. [pmid: 7979211].
368 Lang GS, Ruckle HC, Hadley HR, et al. One hundred consecutive laparoscopic pelvic lymph node dissections: comparing complications of the first 50 cases to the second 50 cases. Urology. Aug. 1994;44(2):221-225. Review. [pmid: 8048197].
369 Larson TR, Rrobertson DW, Corica A, et al. In vivo interstitial temperature mapping of the human prostate during cryosurgery with correlation to histopathologic outcomes. Urology. Apr. 2000;55(4):547-552. Not eligible exposure. [pmid: 10736499].
370 Lassiter LK, Eisenberger MA. The dilemma of patients with a rising PSA level after definitive local therapy for prostate cancer. Semin Urol Oncol. May. 2002;20(2):146-154. Not eligible exposure. [pmid: 12012301].
371 Laven BA, Alsikafi NF, Yang XJ, et al. Minor modifications in apical dissection of radical retropubic prostatectomy in patients with clinical stage T2 prostate cancer reduce positive surgical margin incidence. Urology. Jan. 2004;63(1):95-98. Not eligible exposure. [pmid: 14751357].
372 Lawrence G, Crawford J. Systemic benefit of local radiation therapy. Int J Radiat Oncol Biol Phys. Dec 1. 2003;57(5):1510-1511. author reply 1511. Comment. [pmid: 14630294].
373 Lawton CA, Winter K, Murray K, et al. Updated results of the phase III Radiation Therapy Oncology Group (RTOG) trial 85–31 evaluating the potential benefit of androgen suppression following standard radiation therapy for unfavorable prognosis carcinoma of the prostate. Int J Radiat Oncol Biol Phys. Mar 15. 2001;49(4):937-946. Not eligible exposure. [pmid: 11240234].
374 Lee CT. Re: Racial differences in mortality among Medicare recipients after treatment for localized prostate cancer. J Natl Cancer Inst. May 5. 2004;96(9):718-719. Comment. [pmid: 15126615].
375 Lee CT, Capodieci P, Osman I, et al. Overexpression of the cyclin-dependent kinase inhibitor p16 is associated with tumor recurrence in human prostate cancer. Clin Cancer Res. May. 1999;5(5):977-983. Not eligible exposure. [pmid: 10353729].
376 Lee D. Radical prostatectomy improves cancer-specific survival but not overall survival in early-stage prostate cancer. Clin Prostate Cancer. Jun. 2003;2(1):15-17. Not eligible exposure. [pmid: 15046677].
377 Lee LW, McBain CA, Swindell R, et al. Hypofractionated radiotherapy as salvage for rising prostate-specific antigen after radical prostatectomy. Clin Oncol (R Coll Radiol). Dec. 2004;16(8):517-522. Not eligible exposure. [pmid: 15630843].
378 Lee R, Penson DF. Treatment outcomes in localized prostate cancer: a patient-oriented approach. Semin Urol Oncol. Feb. 2002;20(1):63-73. Review. [pmid: 11828359].
379 Lee WR, deGuzman AF, Bare RL, et al. Postimplant analysis of transperineal interstitial permanent prostate brachytherapy: evidence for a learning curve in the first year at a single institution. Int J Radiat Oncol Biol Phys. Jan 1. 2000;46(1):83-88. No provider characteristics. [pmid: 10656377].
380 Leibovich BC, Blute ML, Bostwick DG, et al. Proximity of prostate cancer to the urethra: implications for minimally invasive ablative therapies. Urology. Nov 1. 2000;56(5):726-729. Not eligible exposure. [pmid: 11068288].
381 Leibowitz R, Tucker SJ. PSA response to thalidomide in patients with advanced prostate cancer. Oncology (Williston Park). Sep. 2002;16(9):1146-1148. Not eligible target population. [pmid: 12380944].
382 Lepor H. Radical prostatectomy: status and opportunities for improving outcomes. Cancer Invest. 2004;22(3):435-444. Review. [pmid: 15493364].
383 Lepor H, Kaci L. Contemporary evaluation of operative parameters and complications related to open radical retropubic prostatectomy. Urology. Oct. 2003;62(4):702-706. Not eligible exposure. [pmid: 14550447].
384 Lepor H, Kaci L. Role of intraoperative biopsies during radical retropubic prostatectomy. Urology. Mar. 2004;63(3):499-502. Not eligible exposure. [pmid: 15028445].
385 Lepor H, Kaci L. The impact of open radical retropubic prostatectomy on continence and lower urinary tract symptoms: a prospective assessment using validated self-administered outcome instruments. J Urol. Mar. 2004;171(3):1216-1219. Not eligible exposure. [pmid: 14767305].
386 Lerner SE, Blute ML, Bergstralh EJ, et al. Analysis of risk factors for progression in patients with pathologically confined prostate cancers after radical retropubic prostatectomy. J Urol. Jul. 1996;156(1):137-143. Not eligible exposure. [pmid: 8648775].
387 Lerner SE, Blute ML, Zincke H. Extended experience with radical prostatectomy for clinical stage T3 prostate cancer: outcome and contemporary morbidity. J Urol. Oct. 1995;154(4):1447-1452. Not eligible exposure. [pmid: 7658555].
388 Lerner SE, Blute ML, Zincke H. Critical evaluation of salvage surgery for radio-recurrent/resistant prostate cancer. J Urol. Sep. 1995;154(3):1103-1109. Not eligible exposure. [pmid: 7543608].
389 Lerner SE, Blute ML, Zincke H. Risk factors for progression in patients with prostate cancer treated with radical prostatectomy. Semin Urol Oncol. May. 1996;14(2 Suppl 2):12-20. discussion 21. Review. [pmid: 8725887].
390 Lertakyamanee J, Ruksamanee EO, Tantiwong A, et al. The risk and effectiveness of transurethral resection of prostate. J Med Assoc Thai. Dec. 2002;85(12):1288-1295. Not eligible target population. [pmid: 12678166].
391 Leventis AK, Shariat SF, Kattan MW, et al. Prediction of response to salvage radiation therapy in patients with prostate cancer recurrence after radical prostatectomy. J Clin Oncol. Feb 15. 2001;19(4):1030-1039. Not eligible exposure. [pmid: 11181666].
392 Li H, Sugimura K, Boku M, et al. MR findings of prostatic urethral polyp in an adult. Eur Radiol. Dec. 2003;13(Suppl 4):L105-108. Not eligible target population.
393 Liauw SL, Webster WS, Pistenmaa DA, et al. Salvage radiotherapy for biochemical failure of radical prostatectomy: a single-institution experience. Urology. Jun. 2003;61(6):1204-1210. Not eligible exposure. [pmid: 12809898].
394 Lillis P, Thompson IM Jr. Should asymptomatic progression following definitive local treatment for prostate cancer be treated?. Hematol Oncol Clin North Am. Jun. 1996;10(3):703-712. Review. [pmid: 8773506].
395 Lobe TE, Wiener E, Andrassy RJ, et al. The argument for conservative, delayed surgery in the management of prostatic rhabdomyosarcoma. J Pediatr Surg. Aug. 1996;31(8):1084-1087. Not eligible target population. [pmid: 8863239].
396 Long JP. Cryosurgical ablation of the prostate: current technique and clinical outcomes. Surg Technol Int. 2003;11:213-219. Review. [pmid: 12931304].
397 Loren AW, Bennett I, Cronholm P, et al. Re: Life after radical prostatectomy: a longitudinal study. J Urol. Jul. 2002;168(1):203-204. author reply 204. Comment. [pmid: 12050540].
398 Lorente JA, Arango O, Bielsa O, et al. A longer duration of neo-adjuvant combined androgen blockade prior to radical prostatectomy may lead to lower tumour volume of localised prostate cancer. Eur Urol. Feb. 2003;43(2):119-123. Not eligible exposure. [pmid: 12565768].
399 Losa A, Nava LD, Di Muzio N, et al. Salvage brachytherapy for local recurrence after radical prostatectomy and subsequent external beam radiotherapy. Urology. Dec. 2003;62(6):1068-1072. Not eligible exposure. [pmid: 14665357].
400 Lubeck DP, Grossfeld GD, Carroll PR. A review of measurement of patient preferences for treatment outcomes after prostate cancer. Urology. Sep. 2002;60(3 Suppl 1):72-77. discussion 77–78. Review. [pmid: 12231054].
401 Lu-Yao GL, Barry MJ, Chang CH, et al. Transurethral resection of the prostate among Medicare beneficiaries in the United States: time trends and outcomes. Prostate Patient Outcomes Research Team (PORT). Urology. Nov. 1994;44(5):692-698. discussion 698–699. Not eligible target population. [pmid: 7526526].
402 Madalinska JB, Essink-Bot ML, de Koning HJ, et al. Health-related quality-of-life effects of radical prostatectomy and primary radiotherapy for screen-detected or clinically diagnosed localized prostate cancer. J Clin Oncol. Mar 15. 2001;19(6):1619-1628. Not eligible exposure. [pmid: 11250990].
403 Maier J, Forman J, Tekyi-Mensah S, et al. Salvage radiation for a rising PSA following radical prostatectomy. Urol Oncol. Jan–Feb. 2004;22(1):50-56. Not eligible exposure. [pmid: 14969805].
404 Makhlouf AA, Boyd JC, Chapman TN, et al. Perioperative costs and charges of prostate brachytherapy and prostatectomy. Urology. Oct. 2002;60(4):656-660. Not eligible exposure. [pmid: 12385928].
405 Malkowicz SB. Serum prostate-specific antigen elevation in the post-radical prostatectomy patient. Urol Clin North Am. Nov. 1996;23(4):665-675. Review. [pmid: 8948419].
406 Mameghan H, Fisher R, Mameghan J, et al. Results of external beam radiotherapy in 448 patients with clinically localized adenocarcinoma of the prostate. Aust N Z J Surg. Jun. 1994;64(6):389-394. Not eligible exposure. [pmid: 8010899].
407 Manoharan M, Bird VG, Kim SS, et al. Outcome after radical prostatectomy with a pretreatment prostate biopsy Gleason score of >/=8. BJU Int. Oct. 2003;92(6):539-544. Not eligible exposure. [pmid: 14511029].
408 Manseck A, Wirth M, Theiss M, et al. Radical prostatectomy in patients with incidental prostate carcinoma. Urol Int. 1994;53(4):196-208. Not eligible exposure. [pmid: 7531896].
409 Marcovich R, Wojno KJ, Wei JT, et al. Bladder neck-sparing modification of radical prostatectomy adversely affects surgical margins in pathologic T3a prostate cancer. Urology. Jun. 2000;55(6):904-908. Not eligible exposure. [pmid: 10840106].
410 Mark DH. Mortality of patients after radical prostatectomy: analysis of recent Medicare claims. J Urol. Sep. 1994;152(3):896-898. Not eligible exposure. [pmid: 8051747].
411 Maroni PD, Crawford ED. Surgical management of prostate cancer: optimizing patient selections and clinical outcome. Surg Oncol Clin N Am. Apr. 2005;14(2):301-319. Not eligible exposure. [pmid: 15817241].
412 Maroun L, Jakobsen H, Kromann-Andersen B, et al. Amyloidosis of the seminal vesicle—a case report and review of the literature. Scand J Urol Nephrol. 2003;37(6):519-521. Review. [pmid: 14675929].
413 Marshall CL, Chapin CA, Shapiro L, et al. Radical prostatectomy for localized prostate cancer: trying to define quality care. Clin Perform Qual Health Care. Oct–Dec. 1993;1(4):243-250. Review. [pmid: 10135643].
414 Martorana G, Manferrari F, Bertaccini A, et al. Laparoscopic radical prostatectomy: oncological evaluation in the early phase of the learning curve comparing to retropubic approach. Arch Ital Urol Androl. Mar. 2004;76(1):1-5. No provider characteristics. [pmid: 15185814].
415 Masters JG, Rice ML. Improvement in urinary symptoms after radical prostatectomy: a prospective evaluation of flow rates and symptom scores. BJU Int. Jun. 2003;91(9):795-797. Not eligible exposure. [pmid: 12780834].
416 Masuda M, Iki M, Noguchi S, et al. The worst histologic elements predict prognosis in moderately-differentiated prostate cancer patients with androgen-withdrawal endocrine therapy. Eur Urol. Sep. 1999;36(3):197-202. Not eligible exposure. [pmid: 10450002].
417 Matsushima H, Goto T, Hosaka Y, et al. Correlation between proliferation, apoptosis, and angiogenesis in prostate carcinoma and their relation to androgen ablation. Cancer. Apr 15. 1999;85(8):1822-1827. Not eligible exposure. [pmid: 10223578].
418 Matuszewski M, Stanek A, Maruszak H, et al. Laparoscopic treatment of parapubic postprostatectomy hernia. Eur Urol. Nov. 1999;36(5):418-420. Not eligible exposure. [pmid: 10516453].
419 May F, Hartung R, Breul J. The ability of the American Joint Committee on Cancer Staging system to predict progression-free survival after radical prostatectomy. BJU Int. Nov. 2001;88(7):702-707. Not eligible exposure. [pmid: 11890240].
420 May J, McGovern F. Hemostatic hydrodissection: a new technique to promote nerve-sparing during radical retropubic prostatectomy. Curr Urol Rep. Feb. 2005;6(1):1. Case-reports. [pmid: 15610691].
421 McAllister WJ, Absalom MJ, Mir K, et al. Does endoscopic laser ablation of the prostate stand the test of time? Five-year results from a multicentre randomized controlled trial of endoscopic laser ablation against transurethral resection of the prostate. BJU Int. Mar. 2000;85(4):437-439. Not eligible target population. [pmid: 10691822].
422 McCarthy JF, Catalona WJ, Hudson MA. Effect of radiation therapy on detectable serum prostate specific antigen levels following radical prostatectomy: early versus delayed treatment. J Urol. Jun. 1994;151(6):1575-1578. Not eligible exposure. [pmid: 7514691].
423 McWilliams JM, Zaslavsky AM, Meara E, et al. Impact of Medicare Coverage on Basic Clinical Services for Previously Uninsured Adults. JAMA. August 13, 2003 2003;290(6):757–764. Not eligible exposure.
424 Mehta SS, Lubeck DP, Sadetsky N, et al. Patterns of secondary cancer treatment for biochemical failure following radical prostatectomy: data from CaPSURE. J Urol. Jan. 2004;171(1):215-219. Not eligible exposure. [pmid: 14665879].
425 Meier DE, Tarpley JL, Imediegwu OO, et al. The outcome of suprapubic prostatectomy: a contemporary series in the developing world. Urology. Jul. 1995;46(1):40-44. Not eligible exposure. [pmid: 7541584].
426 Meininger D, Byhahn C, Bueck M, et al. Effects of prolonged pneumoperitoneum on hemodynamics and acid-base balance during totally endoscopic robot-assisted radical prostatectomies. World J Surg. Dec. 2002;26(12):1423-1427. Not eligible exposure. [pmid: 12297911].
427 Meng MV, Grossfeld GD, Williams GH, et al. Minichromosome maintenance protein 2 expression in prostate: characterization and association with outcome after therapy for cancer. Clin Cancer Res. Sep. 2001;7(9):2712-2718. Not eligible exposure. [pmid: 11555583].
428 Menon M, Shrivastava A, Tewari A, et al. Laparoscopic and robot assisted radical prostatectomy: establishment of a structured program and preliminary analysis of outcomes. J Urol. Sep. 2002;168(3):945-949. No provider characteristics. [pmid: 12187196].
429 Menon M, Tewari A. Robotic radical prostatectomy and the Vattikuti Urology Institute technique: an interim analysis of results and technical points. Urology. Apr. 2003;61(4 Suppl 1):15-20. Not eligible exposure. [pmid: 12657356].
430 Meraj S, Nagler HM, Homel P, et al. Radical prostatectomy: size of the prostate gland and its relationship with acute perioperative complications. Can J Urol. Feb. 2003;10(1):1743-1748. Not eligible exposure. [pmid: 12625852].
431 Mettlin C. Changes in patterns of prostate cancer care in the United States: results of American College of Surgeons Commission on Cancer studies, 1974-1993. Prostate. Aug 1. 1997;32(3):221-226. Review. [pmid: 9254902].
432 Mettlin CJ, Murphy GP, Sylvester J, et al. Results of hospital cancer registry surveys by the American College of Surgeons: outcomes of prostate cancer treatment by radical prostatectomy. Cancer. Nov 1. 1997;80(9):1875-1881. Not eligible exposure. [pmid: 9351563].
433 Meyer F, Bairati I, Bedard C, et al. Duration of neoadjuvant androgen deprivation therapy before radical prostatectomy and disease-free survival in men with prostate cancer. Urology. Aug. 2001;58(2 Suppl 1):71-77. Not eligible exposure. [pmid: 11502453].
434 Meyer F, Moore L, Bairati I, et al. Neoadjuvant hormonal therapy before radical prostatectomy and risk of prostate specific antigen failure. J Urol. Dec. 1999;162(6):2024-2028. Not eligible exposure. [pmid: 10569561].
435 Mian BM, Troncoso P, Okihara K, et al. Outcome of patients with Gleason score 8 or higher prostate cancer following radical prostatectomy alone. J Urol. Apr. 2002;167(4):1675-1680. Not eligible exposure. [pmid: 11912386].
436 Migliari R, Pistolesi D, De Angelis M. Polypropilene sling of the bulbar urethra for post-radical prostatectomy incontinence. Eur Urol. Feb. 2003;43(2):152-157. Not eligible exposure. [pmid: 12565773].
437 Milbank AJ, Dreicer R, Klein EA. Hormonal therapy for prostate cancer: primum non nocere. Urology. Nov. 2002;60(5):738-741. Editorial. [pmid: 12429287].
438 Miller DC, Sanda MG, Dunn RL, et al. Long-term outcomes among localized prostate cancer survivors: health-related quality-of-life changes after radical prostatectomy, external radiation, and brachytherapy. J Clin Oncol. Apr 20. 2005;23(12):2772-2780. Not eligible exposure. [pmid: 15837992].
439 Minardi D, Galosi AB, Giannulis I, et al. Comparison of proliferating cell nuclear antigen immunostaining in lymph node metastases and primary prostate adenocarcinoma after neoadjuvant androgen deprivation therapy. Scand J Urol Nephrol. 2004;38(1):19-25. Not eligible exposure. [pmid: 15204422].
440 Mireku-Boateng AO, Oben F. Surgical outcome of radical retropubic prostatectomy is not adversely affected by preexisting three-piece inflatable penile implant. Urol Int. 2005;74(3):221-223. Not eligible exposure. [pmid: 15812207].
441 Mitchell JA, Cooperberg MR, Elkin EP, et al. Ability of 2 pretreatment risk assessment methods to predict prostate cancer recurrence after radical prostatectomy: data from CaPSURE. J Urol. Apr. 2005;173(4):1126-1131. Not eligible exposure. [pmid: 15758720].
442 Mitsiades CS, Lembessis P, Sourla A, et al. Molecular staging by RT-pCR analysis for PSA and PSMA in peripheral blood and bone marrow samples is an independent predictor of time to biochemical failure following radical prostatectomy for clinically localized prostate cancer. Clin Exp Metastasis. 2004;21(6):495-505. Not eligible exposure. [pmid: 15679047].
443 Miyake H, Sakal I, Harada K, et al. Clinicopathological outcome of radical retropubic prostatectomy for 200 men with prostate cancer in a single institution in Japan. Hinyokika Kiyo. Mar. 2004;50(3):151-156. Not eligible exposure. [pmid: 15148765].
444 Mohler JL. Outpatient pelvic lymph node dissection. J Urol. Oct. 1995;154(4):1439-1442. No provider characteristics. [pmid: 7658553].
445 Mohler JL, Figlesthaler WM, Zhang XZ, et al. Nuclear shape analysis for the assessment of local invasion and metastases in clinically localized prostate carcinoma. Cancer. Dec 1. 1994;74(11):2996-3001. Not eligible exposure. [pmid: 7954263].
446 Montironi R, Diamanti L, Santinelli A, et al. Effect of total androgen ablation on pathologic stage and resection limit status of prostate cancer. Initial results of the Italian PROSIT study. Pathol Res Pract. 1999;195(4):201-208. Not eligible exposure. [pmid: 10337657].
447 Moore KN, Gray M. Urinary incontinence in men: current status and future directions. Nurs Res. Nov–Dec. 2004;53(6 Suppl):S36-41. Review. [pmid: 15586146].
448 Moreno JG, Shenot PJ, Shupp-Byrne D, et al. Analysis of tumor spillage during radical prostatectomy using RT-PCR of prostate specific antigen. Tech Urol. Spring. 1996;2(1):54-57. Not eligible exposure. [pmid: 9118404].
449 Morgan WR, Bergstralh EJ, Zincke H. Long-term evaluation of radical prostatectomy as treatment for clinical stage C (T3) prostate cancer. Urology. Feb. 1993;41(2):113-120. Not eligible exposure. [pmid: 7684543].
450 Morton GC. Early prostate cancer. Curr Probl Cancer. Jan–Feb. 2000;24(1):5-51. Review. [pmid: 10749454].
451 Mosbacher MR, Schiff PB, Otoole KM, et al. Postprostatectomy salvage radiation therapy for prostate cancer: impact of pathological and biochemical variables and prostate fossa biopsy. Cancer J. May–Jun. 2002;8(3):242-246. Not eligible exposure. [pmid: 12074323].
452 Mottet N, Boyer C, Chartier-Kastler E, et al. Artificial urinary sphincter AMS 800 for urinary incontinence after radical prostatectomy: the French experience. Urol Int. 1998;60(Suppl 2):25-29. discussion 35. Not eligible exposure. [pmid: 9607555].
453 Moul JW. Outcome research: prostate cancer databases. Urol Oncol. Jan–Feb. 2002;7(1):39-42. Not eligible exposure. [pmid: 12474540].
454 Moul JW, Anderson J, Penson DF, et al. Early prostate cancer: prevention, treatment modalities, and quality of life issues. Eur Urol. Sep. 2003;44(3):283-293. Review. [pmid: 12932925].
455 Moul JW, Douglas TH, McCarthy WF, et al. Black race is an adverse prognostic factor for prostate cancer recurrence following radical prostatectomy in an equal access health care setting. J Urol. May. 1996;155(5):1667-1673. Not eligible exposure. [pmid: 8627850].
456 Moul JW, Wu H, Sun L, et al. Early versus delayed hormonal therapy for prostate specific antigen only recurrence of prostate cancer after radical prostatectomy. J Urol. Mar. 2004;171(3):1141-1147. Not eligible exposure. [pmid: 14767288].
457 Murphy GP, Mettlin C, Menck H, et al. National patterns of prostate cancer treatment by radical prostatectomy: results of a survey by the American College of Surgeons Commission on Cancer. J Urol. Nov. 1994;152(5 Pt 2):1817-1819. Not eligible exposure. [pmid: 7523727].
458 Nadler RB, Andriole GL. Who is best benefited by radical prostatectomy?. Hematol Oncol Clin North Am. Jun. 1996;10(3):581-593. Review. [pmid: 8773498].
459 Nam RK, Jewett MA, Krahn MD, et al. Delay in surgical therapy for clinically localized prostate cancer and biochemical recurrence after radical prostatectomy. Can J Urol. Jun. 2003;10(3):1891-1898. Not eligible exposure. [pmid: 12892576].
460 Namiki S, Kuwahara M, Ioritani N, et al. An evaluation of urinary function after radical prostatectomy in Japanese men: concordance with definitions of urinary continence. BJU Int. Mar. 2005;95(4):530-533. Not eligible exposure. [pmid: 15705074].
461 Namiki S, Tochigi T, Kuwahara M, et al. Health related quality of life in Japanese men after radical prostatectomy or radiation therapy for localized prostate cancer. Int J Urol. Aug. 2004;11(8):619-627. Not eligible exposure. [pmid: 15285752].
462 Narayan P, Jajodia P, Stein R, et al. A comparison of fine needle aspiration and core biopsy in diagnosis and preoperative grading of prostate cancer. J Urol. Mar. 1989;141(3):560-563. No provider characteristics. [pmid: 2918592].
463 Nasr R, Goldenberg SL. Rising prostate specific antigen after radical prostatectomy: a case based review. Can J Urol. Aug. 2001;8(4):1306-1313. Not eligible exposure. [pmid: 11564273].
464 Neal DE. The National Prostatectomy Audit. Br J Urol. Apr. 1997;79(Suppl 2):69-75. Review. [pmid: 9126073].
465 Nelson CP, Dunn RL, Wei JT, et al. Contemporary preoperative parameters predict cancer-free survival after radical prostatectomy: a tool to facilitate treatment decisions. Urol Oncol. May–Jun. 2003;21(3):213-218. Not eligible exposure. [pmid: 12810209].
466 Nelson JB, Lepor H. Prostate cancer: radical prostatectomy. Urol Clin North Am. Nov 2003;30(4):703–723, viii. Review.
467 Neulander EZ. Re: Neoadjuvant hormone therapy before salvage radiotherapy for an increasing post-radical prostatectomy serum prostate specific antigen level. J Urol. Feb. 2004;171(2 Pt 1):809. author reply 809–810. Comment. [pmid: 14713828].
468 Neulander EZ, Soloway MS. Failure after radical prostatectomy. Urology. Jan. 2003;61(1):30-36. Review. [pmid: 12559261].
469 Neulander EZ, Wajsman Z, Greene GF. Radical prostatectomy and postoperative radiation in patients with adenocarcinoma of prostate of intermediate and high risk for recurrence. J Ark Med Soc. Mar. 2005;101(9):276-280. Not eligible exposure. [pmid: 15787077].
470 Newling DW. The management of hormone refractory prostate cancer. Eur Urol. 1996;29(Suppl 2):69-74. Review. [pmid: 8717467].
471 Nickers P, Lenaerts E, Thissen B, et al. Does inverse planning applied to Iridium192 high dose rate prostate brachytherapy improve the optimization of the dose afforded by the Paris system?. Radiother Oncol. Feb. 2005;74(2):131-136. No provider characteristics. [pmid: 15734200].
472 Niehoff P, Loch T, Nurnberg N, et al. Feasibility and preliminary outcome of salvage combined HDR brachytherapy and external beam radiotherapy (EBRT) for local recurrences after radical prostatectomy. Brachytherapy. 2005;4(2):141-145. Not eligible exposure. [pmid: 15893268].
473 Noguchi M, Shimada A, Yahara J, et al. Early catheter removal 3 days after radical retropubic prostatectomy. Int J Urol. Nov. 2004;11(11):983-988. Not eligible exposure. [pmid: 15509202].
474 Noh C, Kshirsagar A, Mohler JL. Outcomes after radical retropubic prostatectomy. Urology. Feb. 2003;61(2):412-416. Not eligible exposure. [pmid: 12597958].
475 Noldus J, Michl U, Graefen M, et al. Patient-reported sexual function after nerve-sparing radical retropubic prostatectomy. Eur Urol. Aug. 2002;42(2):118-124. Not eligible exposure. [pmid: 12160581].
476 Norberg M, Holmberg L, Wheeler T, et al. Five year follow-up after radical prostatectomy for localized prostate cancer—a study of the impact of different tumor variables on progression. Scand J Urol Nephrol. Dec. 1994;28(4):391-399. Not eligible exposure. [pmid: 7533926].
477 Norderhaug I, Dahl O, Hoisaeter PA, et al. Brachytherapy for prostate cancer: a systematic review of clinical and cost effectiveness. Eur Urol. Jul. 2003;44(1):40-46. Review. [pmid: 12814673].
478 Nudell DM, Grossfeld GD, Weinberg VK, et al. Radiotherapy after radical prostatectomy: treatment outcomes and failure patterns. Urology. Dec. 1999;54(6):1049-1057. Not eligible exposure. [pmid: 10604707].
479 Nuttall MC, van der Meulen J, McIntosh G, et al. Threshold volumes for urological cancer surgery: a survey of UK urologists. BJU Int. Nov. 2004;94(7):1010-1013. Not eligible outcomes. [pmid: 15541118].
480 O'Brien MF, Connolly SS, Kelly DG, et al. Should patients with a pre-operative prostate-specific antigen greater than 15 ng/ml be offered radical prostatectomy?. Ir J Med Sci. Jan–Mar. 2004;173(1):23-26. Not eligible exposure. [pmid: 15732232].
481 Oefelein MG, Grayhack JT, McVary KT. Survival after radical retropubic prostatectomy of men with clinically localized high grade carcinoma of the prostate. Cancer. Dec 15. 1995;76(12):2535-2542. Not eligible exposure. [pmid: 8625082].
482 Oesterling JE. Long-term follow-up of patients treated by radical prostatectomy for clinically-localized prostate cancer. Can J Oncol. Nov. 1994;4(Suppl 1):24-28. discussion 29–30. Not eligible exposure. [pmid: 8853485].
483 Oesterling JE. Radical prostatectomy: the retropubic approach. Urology. Apr. 1996;47(4):460-462. Editorial. [pmid: 8638350].
484 Ohori M, Goad JR, Wheeler TM, et al. Can radical prostatectomy alter the progression of poorly differentiated prostate cancer?. J Urol. Nov. 1994;152(5 Pt 2):1843-1849. Not eligible exposure. [pmid: 7523732].
485 Ohori M, Scardino PT. Localized prostate cancer. Curr Probl Surg. Sep. 2002;39(9):833-957. Review. [pmid: 12376729].
486 Ohyama C, Tsuchiya N, Habuchi T, et al. Rectosigmoidal bladder utilizing intussuscepted ileal segment: a surgical technique for urinary diversion and experiences in 30 patients. Int J Urol. Jun. 2004;11(6):379-385. Not eligible target population. [pmid: 15157206].
487 Okotie OT, Aronson WJ, Wieder JA, et al. Predictors of metastatic disease in men with biochemical failure following radical prostatectomy. J Urol. Jun. 2004;171(6 Pt 1):2260-2264. Not eligible exposure. [pmid: 15126798].
488 Oliver SE, Donovan JL, Peters TJ, et al. Recent trends in the use of radical prostatectomy in England: the epidemiology of diffusion. BJU Int. Mar. 2003;91(4):331-336. discussion 336. Not eligible exposure. [pmid: 12603408].
489 Olsson CA, De Vries GM, Benson MC, et al. The use of RT-PCR for prostate-specific antigen assay to predict potential surgical failures before radical prostatectomy: molecular staging of prostate cancer. Br J Urol. Mar. 1996;77(3):411-417. Not eligible exposure. [pmid: 8814848].
490 Olsson CA, de Vries GM, Raffo AJ, et al. Preoperative reverse transcriptase polymerase chain reaction for prostate specific antigen predicts treatment failure following radical prostatectomy. J Urol. May. 1996;155(5):1557-1562. Not eligible exposure. [pmid: 8627821].
491 Olumi AF, Richie JP, Schultz DJ, et al. Calculated volume of prostate cancer identifies patients with clinical stage T1C disease at high risk of biochemical recurrence after radical prostatectomy: a preliminary study. Urology. Aug 1. 2000;56(2):273-277. Not eligible exposure. [pmid: 10925093].
492 Onik G, Narayan P, Vaughan D, et al. Focal “nerve-sparing” cryosurgery for treatment of primary prostate cancer: a new approach to preserving potency. Urology. Jul. 2002;60(1):109-114. Not eligible exposure. [pmid: 12100934].
493 Ornstein DK, Oh J, Herschman JD, et al. Evaluation and management of the man who has failed primary curative therapy for prostate cancer. Urol Clin North Am. Nov. 1998;25(4):591-601. Review. [pmid: 10026768].
494 Ou YC, Chen JT, Cheng CL, et al. Radical prostatectomy for prostate cancer patients with prostate-specific antigen >20 ng/ml. Jpn J Clin Oncol. Nov. 2003;33(11):574-579. Not eligible exposure. [pmid: 14711982].
495 Ozcan F. Correlation of perineural invasion on radical prostatectomy specimens with other pathologic prognostic factors and PSA failure. Eur Urol. Sep. 2001;40(3):308-312. Not eligible exposure. [pmid: 11684847].
496 Pagano F, Prayer-Galetti T, d'Arrigo L, et al. Radical surgery for clinically confined prostate cancer. Ann N Y Acad Sci. Apr 30. 1996;784:85-92. Not eligible exposure. [pmid: 8651620].
497 Palisaar RJ, Graefen M, Karakiewicz PI, et al. Assessment of clinical and pathologic characteristics predisposing to disease recurrence following radical prostatectomy in men with pathologically organ-confined prostate cancer. Eur Urol. Feb. 2002;41(2):155-161. Not eligible exposure. [pmid: 12074402].
498 Palisaar RJ, Noldus J, Graefen M, et al. Influence of nerve-sparing (NS) procedure during radical prostatectomy (RP) on margin status and biochemical failure. Eur Urol. Feb. 2005;47(2):176-184. Not eligible exposure. [pmid: 15661411].
499 Pantel K, Enzmann T, Kollermann J, et al. Immunocytochemical monitoring of micrometastatic disease: reduction of prostate cancer cells in bone marrow by androgen deprivation. Int J Cancer. May 16. 1997;71(4):521-525. Not eligible exposure. [pmid: 9178803].
500 Paquette EL, Connelly RR, Sesterhenn IA, et al. Improvements in pathologic staging for African-American men undergoing radical retropubic prostatectomy during the prostate specific antigen era: implications for screening a high-risk group for prostate carcinoma. Cancer. Nov 15. 2001;92(10):2673-2679. Not eligible exposure. [pmid: 11745203].
501 Park EL, Dalkin B, Escobar C, et al. Site-specific positive margins at radical prostatectomy: assessing cancer-control benefits of wide excision of the neurovascular bundle on a side with cancer on biopsy. BJU Int. Feb. 2003;91(3):219-222. Not eligible exposure. [pmid: 12581008].
502 Parker CC, Dearnaley DP. The management of PSA failure after radical radiotherapy for localized prostate cancer. Radiother Oncol. Nov. 1998;49(2):103-110. Review. [pmid: 10052875].
503 Partin AW, Lee BR, Carmichael M, et al. Radical prostatectomy for high grade disease: a reevaluation 1994. J Urol. Jun. 1994;151(6):1583-1586. Not eligible exposure. [pmid: 8189569].
504 Patel A, Adshead JM. First clinical experience with new transurethral bipolar prostate electrosurgery resection system: controlled tissue ablation (coblation technology). J Endourol. Dec. 2004;18(10):959-964. Not eligible treatment. [pmid: 15801362].
505 Patel VR, Tully AS, Holmes R, et al. Robotic radical prostatectomy in the community setting—the learning curve and beyond: initial 200 cases. J Urol. Jul. 2005;174(1):269-272. No provider characteristics. [pmid: 15947662].
506 Patriarca C, Petrella D, Campo B, et al. Elevated E-cadherin and alpha/beta-catenin expression after androgen deprivation therapy in prostate adenocarcinoma. Pathol Res Pract. 2003;199(10):659-665. Not eligible exposure. [pmid: 14666968].
507 Paul R, Hoppmann M, van Randenborgh H, et al. Residual benign prostatic glands at the urethrovesical anastomosis after radical retropubic prostatectomy: prediction and impact on disease outcome. Eur Urol. Sep. 2004;46(3):321-326. Not eligible exposure. [pmid: 15306101].
508 Paulson DF. Clinically localized prostatic carcinoma. Cancer. Jun 15. 1993;71(12):3797. Comment. [pmid: 8508346].
509 Paulson DF, Vieweg JW. Radical perineal prostatectomy: a model for evaluating local response of prostate therapy. Crit Rev Oncol Hematol. Aug. 2002;43(2):135-139. Not eligible exposure. [pmid: 12191735].
510 Penedo FJ, Dahn JR, Molton I, et al. Cognitive-behavioral stress management improves stress-management skills and quality of life in men recovering from treatment of prostate carcinoma. Cancer. Jan 1. 2004;100(1):192-200. Not eligible exposure. [pmid: 14692040].
511 Perez CA, Beyer DC, Blasko JC, et al. Postradical prostatectomy irradiation in carcinoma of the prostate. American College of Radiology. ACR Appropriateness Criteria. Radiology. Jun. 2000;215(Suppl):1419-1439. Review. [pmid: 11037557].
512 Perez CA, Michalski JM, Baglan K, et al. Radiation therapy for increasing prostate-specific antigen levels after radical prostatectomy. Clin Prostate Cancer. Mar. 2003;1(4):235-241. Not eligible exposure. [pmid: 15040882].
513 Perez LM, Webster GD. Successful outcome of artificial urinary sphincters in men with post-prostatectomy urinary incontinence despite adverse implantation features. J Urol. Oct. 1992;148(4):1166-1170. Not eligible exposure. [pmid: 1404630].
514 Peschel RE, Colberg JW. Surgery, brachytherapy, and external-beam radiotherapy for early prostate cancer. Lancet Oncol. Apr. 2003;4(4):233-241. Review. [pmid: 12681267].
515 Peters N, Armstrong K. Racial differences in prostate cancer treatment outcomes: a systematic review. Cancer Nurs. Mar–Apr. 2005;28(2):108-118. Review. [pmid: 15815180].
516 Petrovich Z, Lieskovsky G, Langholz B, et al. Comparison of outcomes of radical prostatectomy with and without adjuvant pelvic irradiation in patients with pathologic stage C (T3N0) adenocarcinoma of the prostate. Am J Clin Oncol. Aug. 1999;22(4):323-331. Not eligible exposure. [pmid: 10440184].
517 Petrovich Z, Lieskovsky G, Langholz B, et al. Postoperative radiotherapy in 423 patients with pT3N0 prostate cancer. Int J Radiat Oncol Biol Phys. Jul 1. 2002;53(3):600-609. Not eligible exposure. [pmid: 12062603].
518 Philip J, Dutta Roy S, Scally J, et al. Importance of TURP in diagnosing prostate cancer in men with multiple negative biopsies. Prostate. Jul 1. 2005;64(2):200-202. Not eligible exposure. [pmid: 15712218].
519 Pisansky TM. External beam radiotherapy as curative treatment of prostate cancer. Mayo Clin Proc. Jul. 2005;80(7):883-898. Review. [pmid: 16007894].
520 Pisansky TM, Blute ML, Hillman DW, et al. The relevance of prostatectomy findings for brachytherapy selection in patients with localized prostate carcinoma. Cancer. Aug 1. 2002;95(3):513-519. Not eligible exposure. [pmid: 12209743].
521 Pisansky TM, Kozelsky TF, Myers RP, et al. Radiotherapy for isolated serum prostate specific antigen elevation after prostatectomy for prostate cancer. J Urol. Mar. 2000;163(3):845-850. Not eligible exposure. [pmid: 10687990].
522 Pisters LL. Salvage radical prostatectomy: refinement of an effective procedure. Semin Radiat Oncol. Apr. 2003;13(2):166-174. Review. [pmid: 12728446].
523 Pisters LL, English SF, Scott SM, et al. Salvage prostatectomy with continent catheterizable urinary reconstruction: a novel approach to recurrent prostate cancer after radiation therapy. J Urol. Jun. 2000;163(6):1771-1774. Not eligible exposure. [pmid: 10799179].
524 Pitts WR Jr. Outcome research after radical retropubic prostatectomy for prostate cancer. J Natl Cancer Inst. Jul 15. 1998;90(14):1107. Comment. [pmid: 9672264].
525 Pollack A, Zagars GK, Rosen II. Prostate cancer treatment with radiotherapy: maturing methods that minimize morbidity. Semin Oncol. Apr. 1999;26(2):150-161. Review. [pmid: 10597726].
526 Potosky AL, Legler J, Albertsen PC, et al. Health outcomes after prostatectomy or radiotherapy for prostate cancer: results from the Prostate Cancer Outcomes Study. J Natl Cancer Inst. Oct 4. 2000;92(19):1582-1592. Not eligible exposure. [pmid: 11018094].
527 Potosky AL, Miller BA, Albertsen PC, et al. The role of increasing detection in the rising incidence of prostate cancer. Jama. Feb 15. 1995;273(7):548-552. Not eligible exposure. [pmid: 7530782].
528 Potosky AL, Warren JL. Radical prostatectomy: does higher volume lead to better quality?. J Natl Cancer Inst. Nov 17. 1999;91(22):1906-1907. Comment. [pmid: 10564667].
529 Poulos CK, Daggy JK, Cheng L. Prostate needle biopsies: multiple variables are predictive of final tumor volume in radical prostatectomy specimens. Cancer. Aug 1. 2004;101(3):527-532. Not eligible exposure. [pmid: 15274065].
530 Pound CR, Walsh PC, Epstein JI, et al. Radical prostatectomy as treatment for prostate-specific antigen-detected stage T1c prostate cancer. World J Urol. 1997;15(6):373-377. Not eligible exposure. [pmid: 9436288].
531 Powell IJ, Banerjee M, Sakr W, et al. Should African-American men be tested for prostate carcinoma at an earlier age than white men?. Cancer. Jan 15. 1999;85(2):472-477. Not eligible exposure. [pmid: 10023717].
532 Prapotnich D, Fizazi K, Escudier B, et al. A 10-year clinical experience with intermittent hormonal therapy for prostate cancer. Eur Urol. Mar. 2003;43(3):233-239. discussion 239–240. Not eligible exposure. [pmid: 12600425].
533 Prepelica KL, Okeke Z, Murphy A, et al. Cryosurgical ablation of the prostate: high risk patient outcomes. Cancer. Apr 15. 2005;103(8):1625-1630. Not eligible exposure. [pmid: 15747374].
534 Prestidge BR, Prete JJ, Buchholz TA, et al. A survey of current clinical practice of permanent prostate brachytherapy in the United States. International Journal of Radiation Oncology*Biology*Physics. 1998/1/15 1998;40(2):461–465. Not eligible exposure.
535 Pruthi RS, Derksen JE, Moore D. A pilot study of use of the cyclooxygenase-2 inhibitor celecoxib in recurrent prostate cancer after definitive radiation therapy or radical prostatectomy. BJU Int. Feb. 2004;93(3):275-278. Not eligible exposure. [pmid: 14764122].
536 Pruthi RS, Johnstone I, Tu IP, et al. Prostate-specific antigen doubling times in patients who have failed radical prostatectomy: correlation with histologic characteristics of the primary cancer. Urology. May. 1997;49(5):737-742. Not eligible exposure. [pmid: 9145980].
537 Quaranta BP, Marks LB, Anscher MS. Prostatectomy vs brachytherapy for localized prostate cancer. Oncology (Williston Park). Nov. 2004;18(13):1582-1585. Comment. [pmid: 15648292].
538 Quaranta BP, Marks LB, Anscher MS. Comparing radical prostatectomy and brachytherapy for localized prostate cancer. Oncology (Williston Park). Sep. 2004;18(10):1289-1302. discussion 1302–1284, 1309. Review. [pmid: 15526832].
539 Queen J. Transperitoneal laparoscopic radical prostatectomy. Semin Perioper Nurs. Jan. 2001;10(1):24-28. Not eligible exposure. [pmid: 15129502].
540 Rabbani F, Stapleton AM, Kattan MW, et al. Factors predicting recovery of erections after radical prostatectomy. J Urol. Dec. 2000;164(6):1929-1934. Not eligible exposure. [pmid: 11061884].
541 Raboy A, Albert P, Ferzli G. Early experience with extraperitoneal endoscopic radical retropubic prostatectomy. Surg Endosc. Oct. 1998;12(10):1264-1267. Case report. [pmid: 9745069].
542 Ragde H, Korb LJ, Elgamal AA, et al. Modern prostate brachytherapy. Prostate specific antigen results in 219 patients with up to 12 years of observed follow-up. Cancer. Jul 1. 2000;89(1):135-141. Not eligible exposure. [pmid: 10897010].
543 Raina R, Lakin MM, Agarwal A, et al. Long-term effect of sildenafil citrate on erectile dysfunction after radical prostatectomy: 3-year follow-up. Urology. Jul. 2003;62(1):110-115. Not eligible exposure. [pmid: 12837433].
544 Rakozy C, Grignon DJ, Li Y, et al. p53 gene alterations in prostate cancer after radiation failure and their association with clinical outcome: a molecular and immunohistochemical analysis. Pathol Res Pract. 1999;195(3):129-135. Not eligible exposure. [pmid: 10220791].
545 Ramon J, Leandri P, Rossignol G, et al. Urinary continence following radical retropubic prostatectomy. Br J Urol. Jan. 1993;71(1):47-51. Not eligible exposure. [pmid: 8435736].
546 Rassweiler J, Frede T, Seemann O, et al. Telesurgical laparoscopic radical prostatectomy. Initial experience. Eur Urol. Jul. 2001;40(1):75-83. No provider characteristics. [pmid: 11528180].
547 Rassweiler J, Schulze M, Teber D, et al. Laparoscopic radical prostatectomy: functional and oncological outcomes. Curr Opin Urol. Mar. 2004;14(2):75-82. Review. [pmid: 15075834].
548 Rassweiler J, Sentker L, Seemann O, et al. Laparoscopic radical prostatectomy with the Heilbronn technique: an analysis of the first 180 cases. J Urol. Dec. 2001;166(6):2101-2108. No provider characteristics. [pmid: 11696715].
549 Rassweiler J, Sentker L, Seemann O, et al. Heilbronn laparoscopic radical prostatectomy. Technique and results after 100 cases. Eur Urol. Jul. 2001;40(1):54-64. No provider characteristics. [pmid: 11528177].
550 Rassweiler J, Stolzenburg J, Sulser T, et al. Laparoscopic radical prostatectomy—the experience of the German Laparoscopic Working Group. Eur Urol. Jan. 2006;49(1):113-119. No provider characteristics. [pmid: 16337330].
551 Ravery V, Chastang C, Toublanc M, et al. Percentage of cancer on biopsy cores accurately predicts extracapsular extension and biochemical relapse after radical prostatectomy for T1–T2 prostate cancer. Eur Urol. Apr. 2000;37(4):449-455. Not eligible exposure. [pmid: 10765076].
552 Ray ME, Dunn RL, Cooney KA, et al. Family history of prostate cancer and relapse after definitive external beam radiation therapy. Int J Radiat Oncol Biol Phys. Oct 1. 2003;57(2):371-376. Not eligible exposure. [pmid: 12957247].
553 Razvi HA, Song TY, Denstedt JD. Management of vesical calculi: comparison of lithotripsy devices. J Endourol. Dec. 1996;10(6):559-563. Not eligible target population. [pmid: 8972793].
554 Rebillard X, Gelet A, Davin JL, et al. Transrectal high-intensity focused ultrasound in the treatment of localized prostate cancer. J Endourol. Jul–Aug. 2005;19(6):693-701. Review. [pmid: 16053358].
555 Reeves MD, Myles PS. Does anaesthetic technique affect the outcome after transurethral resection of the prostate?. BJU Int. Dec. 1999;84(9):982-986. Not eligible exposure. [pmid: 10571624].
556 Rehman J, Ragab MM, Venkatesh R, et al. Laparoscopic radical prostatectomy: Washington University initial experience and prospective evaluation of quality of life. J Endourol. Apr. 2004;18(3):277-287. No provider characteristics. [pmid: 15225395].
557 Remzi M, Klingler HC, Tinzl MV, et al. Morbidity of laparoscopic extraperitoneal versus transperitoneal radical prostatectomy verus open retropubic radical prostatectomy. Eur Urol. Jul. 2005;48(1):83-89. discussion 89. No provider characteristics. [pmid: 15967256].
558 Rhee AC, Olgac S, Ohori M, et al. Mucinous adenocarcinoma of the prostate: a case report of long-term disease-free survival and a review of the literature. Urology. Apr. 2004;63(4):779-780. Case report. [pmid: 15072909].
559 Rhee HK, Triaca V, Sorcini A, et al. Transperitoneal laparoscopic radical prostatectomy: descending technique. J Endourol. Sep. 2004;18(7):601-604. discussion 604. Not eligible exposure. [pmid: 15597644].
560 Rioux-Leclercq NC, Chan DY, Epstein JI. Prediction of outcome after radical prostatectomy in men with organ-confined Gleason score 8 to 10 adenocarcinoma. Urology. Oct. 2002;60(4):666-669. Not eligible exposure. [pmid: 12385930].
561 Risbridger GP, Shibata A, Ferguson KL, et al. Elevated expression of inhibin alpha in prostate cancer. J Urol. Jan. 2004;171(1):192-196. Not eligible exposure. [pmid: 14665874].
562 Roach M 3rd. Neoadjuvant total androgen suppression and radiotherapy in the management of locally advanced prostate cancer. Semin Urol Oncol. May. 1996;14(2 Suppl 2):32-37. discussion 38. Review. [pmid: 8725889].
563 Roach M 3rd, Chen A, Song J, Diaz A, Presti J Jr, Carroll P. Pretreatment prostate-specific antigen and Gleason score predict the risk of extracapsular extension and the risk of failure following radiotherapy in patients with clinically localized prostate cancer. Semin Urol Oncol. May. 2000;18(2):108-114. Not eligible exposure. [pmid: 10875450].
564 Robinson L, Hughes LC, Adler DC, et al. Describing the work of nursing: the case of postsurgical nursing interventions for men with prostate cancer. Res Nurs Health. Aug. 1999;22(4):321-328. Not eligible exposure. [pmid: 10435549].
565 Rogers CG, Trock BP, Walsh PC. Preservation of accessory pudendal arteries during radical retropubic prostatectomy: surgical technique and results. Urology. Jul. 2004;64(1):148-151. Not eligible exposure. [pmid: 15245954].
566 Rogers E, Ohori M, Kassabian VS, et al. Salvage radical prostatectomy: outcome measured by serum prostate specific antigen levels. J Urol. Jan. 1995;153(1):104-110. Not eligible exposure. [pmid: 7526002].
567 Rollins G. Most treatments for localized prostate cancer have equal cure rates. Rep Med Guidel Outcomes Res. Feb 6 2004;15(3):1, 5–6. News.
568 Roos NP, Ramsey EW. A population-based study of prostatectomy: outcomes associated with differing surgical approaches. J Urol. Jun. 1987;137(6):1184-1188. Not eligible target population. [pmid: 3586151].
569 Rosenberg J, Small EJ. Prostate cancer update. Curr Opin Oncol. May. 2003;15(3):217-221. Review. [pmid: 12778015].
570 Roumeguere T, Bollens R, Vanden Bossche M, et al. Radical prostatectomy: a prospective comparison of oncological and functional results between open and laparoscopic approaches. World J Urol. May. 2003;20(6):360-366. Not eligible exposure. [pmid: 12682770].
571 Rozet F, Arroyo C, Cathelineau X, et al. Extraperitoneal standard laparoscopic radical prostatectomy. J Endourol. Sep. 2004;18(7):605-609. discussion 609–610. Not eligible exposure. [pmid: 15597645].
572 Ryan CJ, Small EJ. Role of secondary hormonal therapy in the management of recurrent prostate cancer. Urology. Dec 29. 2003;62(Suppl 1):87-94. Not eligible exposure. [pmid: 14747046].
573 Saffrin R, Chou P, Ray V, et al. Suramin as adjuvant therapy with radical prostatectomy. Prostate. May. 1996;28(5):325-327. Not eligible exposure. [pmid: 8610060].
574 Sakai I, Harada K, Hara I, et al. Intussusception of the bladder neck does not promote early restoration to urinary continence after non-nerve-sparing radical retropubic prostatectomy. Int J Urol. Mar. 2005;12(3):275-279. Not eligible exposure. [pmid: 15828955].
575 Saliken JC, Donnelly BJ, Brasher P, et al. Outcome and safety of transrectal US-guided percutaneous cryotherapy for localized prostate cancer. J Vasc Interv Radiol. Feb. 1999;10(2 Pt 1):199-208. Not eligible exposure. [pmid: 10082109].
576 Salomon CG, Kalbhen CL, Dudiak CM, et al. Prostate carcinoma: transrectal US after cryosurgical ablation. Radiology. Feb. 1998;206(2):533-538. Not eligible exposure. [pmid: 9457209].
577 Salomon L, Anastasiadis A, Saint F, et al. Introducing a new, simple scoring system to evaluate oncological and functional outcome after radical prostatectomy. Scand J Urol Nephrol. 2003;37(5):392-395. Not eligible exposure. [pmid: 14594687].
578 Salomon L, Anastasiadis AG, Katz R, et al. Urinary continence and erectile function: a prospective evaluation of functional results after radical laparoscopic prostatectomy. Eur Urol. Oct. 2002;42(4):338-343. Not eligible exposure. [pmid: 12361898].
579 Salomon L, Levrel O, Anastasiadis AG, et al. Outcome and complications of radical prostatectomy in patients with PSA <10 ng/ml: comparison between the retropubic, perineal and laparoscopic approach. Prostate Cancer Prostatic Dis. 2002;5(4):285-290. Not eligible exposure. [pmid: 12627213].
580 Salomon L, Levrel O, de la Taille A, et al. Radical prostatectomy by the retropubic, perineal and laparoscopic approach: 12 years of experience in one center. Eur Urol. Aug. 2002;42(2):104-110. discussion 110–101. Not eligible exposure. [pmid: 12160579].
581 Salomon L, Saint F, Anastasiadis AG, et al. Combined reporting of cancer control and functional results of radical prostatectomy. Eur Urol. Dec. 2003;44(6):656-660. Not eligible exposure. [pmid: 14644116].
582 Salonia A, Suardi N, Crescenti A, et al. Pfannenstiel versus vertical laparotomy in patients undergoing radical retropubic prostatectomy with spinal anesthesia: results of a prospective, randomized trial. Eur Urol. Feb. 2005;47(2):202-208. Not eligible exposure. [pmid: 15661415].
583 Sandhu DP, Mayor PE, Sambrook PA, et al. Outcome and prognostic factors in patients with advanced prostate cancer and obstructive uropathy. Br J Urol. Oct. 1992;70(4):412-416. Not eligible exposure. [pmid: 1450851].
584 Sanguineti G, Franzone P, Culp L, et al. Radiotherapy after prostatectomy. Tumori. Nov–Dec. 2002;88(6):445-452. Not eligible exposure. [pmid: 12597135].
585 Saranchuk JW, Kattan MW, Elkin E, et al. Achieving optimal outcomes after radical prostatectomy. J Clin Oncol. Jun 20. 2005;23(18):4146-4151. Not eligible exposure. [pmid: 15961762].
586 Sato K, Tsuchiya N, Habuchi T, et al. Total cystoprostatectomy in the treatment of locally advanced prostate carcinoma. Aktuelle Urol. Jul. 2003;34(4):259-261. Not eligible exposure. [pmid: 14566679].
587 Scardino PT, Carlton CE Jr. Re: Impact of transurethral resection on the long-term outcome of patients with prostatic carcinoma. J Urol. Sep. 1994;152(3):970. Comment. [pmid: 8051773].
588 Schaefer U, Witt F, Schueller P, et al. Prostate-specific antigen (PSA) in the monitoring of prostate cancer after radical prostatectomy and external beam radiation. Anticancer Res. Nov–Dec. 2000;20(6D):4989-4992. Not eligible exposure. [pmid: 11326654].
589 Schapira MM, Lawrence WF, Katz DA, et al. Effect of treatment on quality of life among men with clinically localized prostate cancer. Med Care. Mar. 2001;39(3):243-253. Not eligible exposure. [pmid: 11242319].
590 Schatzl G, Madersbacher S, Hofbauer J, et al. The impact of urinary extravasation after radical retropubic prostatectomy on urinary incontinence and anastomotic strictures. Eur Urol. Sep. 1999;36(3):187-190. Not eligible exposure. [pmid: 10450000].
591 Schild SE. Salvage radiotherapy for elevated PSA levels following prostatectomy. Cancer J. May–Jun. 2002;8(3):234-235. Comment. [pmid: 12074320].
592 Schild SE, Pisansky TM. The role of radiotherapy after radical prostatectomy. Urol Clin North Am. Aug 2001;28(3):629–637, x. Review
593 Schild SE, Wong WW, Grado GL, et al. Radiotherapy for isolated increases in serum prostate-specific antigen levels after radical prostatectomy. Mayo Clin Proc. Jul. 1994;69(7):613-619. Not eligible exposure. [pmid: 7516988].
594 Schild SE, Wong WW, Grado GL, et al. The result of radical retropubic prostatectomy and adjuvant therapy for pathologic stage C prostate cancer. Int J Radiat Oncol Biol Phys. Feb 1. 1996;34(3):535-541. Not eligible exposure. [pmid: 8621275].
595 Schmidt JD, Doyle J, Larison S. Prostate cryoablation: update 1998. CA Cancer J Clin. Jul–Aug. 1998;48(4):239-253. Review. [pmid: 9676539].
596 Schonberger B, Giessing M, Vogler H, et al. Relevance and meaning of prostate cancer in kidney transplantation. Transplant Proc. Sep. 2002;34(6):2225-2226. Case report. [pmid: 12270375].
597 Schuessler WW, Schulam PG, Clayman RV, et al. Laparoscopic radical prostatectomy: initial short-term experience. Urology. Dec. 1997;50(6):854-857. Not eligible exposure. [pmid: 9426713].
598 Schulman CC, Altwein JE, Zlotta AR. Treatment options after failure of local curative treatments in prostate cancer: a controversial issue. BJU Int. Dec. 2000;86(9):1014-1022. Review. [pmid: 11119094].
599 Schulman CC, Wildschutz T, Zlotta AR. Neoadjuvant hormonal treatment prior to radical prostatectomy: facts and open questions. Eur Urol. 1997;32(Suppl 3):41-47. Review. [pmid: 9267784].
600 Schulz RJ, Kagan AR. Long-term outcomes after radical prostatectomy performed in a community-based health maintenance organization. Cancer. Jul 1. 2004;101(1):208-209. author reply 209–210. Comment. [pmid: 15222011].
601 Sciarra A, Di Chiro C, Di Silverio F. Intermittent androgen deprivation (IAD) in patients with biochemical failure after radical retropubic prostatectomy (RRP) for clinically localized prostate cancer. World J Urol. Dec. 2000;18(6):392-400. Not eligible exposure. [pmid: 11204257].
602 Scolieri MJ, Altman A, Resnick MI. Neoadjuvant hormonal ablative therapy before radical prostatectomy: a review. Is it indicated?. J Urol. Nov. 2000;164(5):1465-1472. Not eligible exposure. [pmid: 11025684].
603 Scott PA, Scott PA, Perkash I, Mode D, et al. Prostate cancer diagnosed in spinal cord-injured patients is more commonly advanced stage than in able-bodied patients. Urology. Mar. 2004;63(3):509-512. Not eligible exposure. [pmid: 15028447].
604 Seaman EK, Whang IS, Cooner W, et al. Predictive value of prostate-specific antigen density for the presence of micrometastatic carcinoma of the prostate. Urology. May. 1994;43(5):645-648. Not eligible exposure. [pmid: 7513107].
605 Secin FP, Carver B, Kattan MW, et al. Current recommendations for delaying renal transplantation after localized prostate cancer treatment: are they still appropriate?. Transplantation. Sep 15. 2004;78(5):710-712. Not eligible exposure. [pmid: 15371673].
606 See WA. Adjuvant hormone therapy after radiation or surgery for localized or locally advanced prostate cancer. Curr Treat Options Oncol. Oct. 2003;4(5):351-362. Review. [pmid: 12941195].
607 Selek U, Lee A, Levy L, et al. Utility of the percentage of positive prostate biopsies in predicting PSA outcome after radiotherapy for patients with clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. Nov 15. 2003;57(4):963-967. Not eligible exposure. [pmid: 14575826].
608 Shaffer DR, Scher HI. Prostate cancer: a dynamic illness with shifting targets. Lancet Oncol. Jul. 2003;4(7):407-414. Review. [pmid: 12850191].
609 Shah R, Bassily N, Wei J, et al. Benign prostatic glands at surgical margins of radical prostatectomy specimens: frequency and associated risk factors. Urology. Nov 1. 2000;56(5):721-725. Not eligible exposure. [pmid: 11068287].
610 Shaheen A, Quinlan D. Feasibility of open simple prostatectomy with early vascular control. BJU Int. Feb. 2004;93(3):349-352. Not eligible target population. [pmid: 14764135].
611 Shanberg AM, Sawyer DE, Lee IS, et al. Depth of penetration of the neodymium: yttrium-aluminum-garnet laser in the human prostate and clinical results of high-dose laser energy in 50 patients. World J Urol. 1995;13(2):78-82. Not eligible exposure. [pmid: 7627209].
612 Shekarriz B, Upadhyay J, Pontes JE. Salvage radical prostatectomy. Urol Clin North Am. Aug. 2001;28(3):545-553. Review. [pmid: 11590813].
613 Shibata A, Ma J, Whittemore A. Prostate cancer incidence and mortality in the United States and the United Kingdom. J Natl Cancer Inst. August 19, 1998 1998;90(16):1230–1231. Review.
614 Shrader-Bogen CL, Kjellberg JL, McPherson CP, et al. Quality of life and treatment outcomes: prostate carcinoma patients' perspectives after prostatectomy or radiation therapy. Cancer. May 15. 1997;79(10):1977-1986. Not eligible exposure. [pmid: 9149026].
615 Shulman MJ, Benaim EA. Prognostic model of event-free survival for patients with androgen-independent prostate carcinoma. Cancer. Jun 1. 2005;103(11):2280-2286. Not eligible exposure. [pmid: 15844202].
616 Silber JH, Williams SV, Krakauer H, et al. Hospital and patient characteristics associated with death after surgery. A study of adverse occurrence and failure to rescue. Med Care. Jul. 1992;30(7):615-629. Not eligible outcomes. [pmid: 1614231].
617 Simonato A, Gregori A, Lissiani A, et al. Laparoscopic radical cystoprostatectomy: a technique illustrated step by step. Eur Urol. Jul. 2003;44(1):132-138. Not eligible target population. [pmid: 12814689].
618 Skinner EC, Glode LM. High-risk localized prostate cancer: primary surgery and adjuvant therapy. Urol Oncol. May–Jun. 2003;21(3):219-227. Review. [pmid: 12810210].
619 Small EJ. Prostate cancer, Incidence, management and outcomes. Drugs Aging. Jul. 1998;13(1):71-81. Review. [pmid: 9679210].
620 Small EJ, Roach M 3rd. Prostate-specific antigen in prostate cancer: a case study in the development of a tumor marker to monitor recurrence and assess response. Semin Oncol. Jun. 2002;29(3):264-273. Review. [pmid: 12063679].
621 Smart R. Outcomes of transrectal ultrasound scan of the prostate with sector biopsies for 323 New Zealand men with suspicion of prostate cancer. N Z Med J. Dec 10. 1999;112(1101):465-469. Not eligible exposure. [pmid: 10678211].
622 Smith DS, Carvalhal GF, Schneider K, et al. Quality-of-life outcomes for men with prostate carcinoma detected by screening. Cancer. Mar 15. 2000;88(6):1454-1463. Not eligible exposure. [pmid: 10717630].
623 Smith DS, Krygiel J, Nease RF Jr, et al. Patient preferences for outcomes associated with surgical management of prostate cancer. J Urol. May. 2002;167(5):2117-2122. Not eligible exposure. [pmid: 11956454].
624 Smith JA Jr. Stage T1c prostate cancer: perspectives on clinical management. Semin Urol Oncol. Aug. 1995;13(3):238-244. Review. [pmid: 8521137].
625 Smith JA Jr. Outcome after radical prostatectomy depends on surgical technique but not approach. Curr Urol Rep. Jun. 2002;3(3):179-181. Review. [pmid: 12084186].
626 Smith JA Jr. Robotically assisted laparoscopic prostatectomy: an assessment of its contemporary role in the surgical management of localized prostate cancer. Am J Surg. Oct. 2004;188(4A Suppl):63S-67S. Not eligible exposure. [pmid: 15476654].
627 Smith MR, Manola J, Kaufman DS, et al. Rosiglitazone versus placebo for men with prostate carcinoma and a rising serum prostate-specific antigen level after radical prostatectomy and/or radiation therapy. Cancer. Oct 1. 2004;101(7):1569-1574. Not eligible exposure. [pmid: 15468186].
628 Smith MR, McGovern FJ. Gonadotropin-releasing hormone agonist failure in a man with prostate cancer. J Urol. Jul. 2001;166(1):211. Not eligible exposure. [pmid: 11435862].
629 Smitt MC, Heltzel M. The results of radical prostatectomy at a community hospital during the prostate specific antigen era. Cancer. Mar 1. 1996;77(5):928-933. Not eligible exposure. [pmid: 8608486].
630 Soderdahl DW, Davis JW, Schellhammer PF, et al. Prospective longitudinal comparative study of health-related quality of life in patients undergoing invasive treatments for localized prostate cancer. J Endourol. Apr. 2005;19(3):318-326. Not eligible exposure. [pmid: 15865521].
631 Sodha S, Nagda S, Lackman RD, et al. Gamma probe assisted biopsy of suspected metastatic rib lesions. Clin Orthop Relat Res. May 2004(422):186–189. Not eligible target population.
632 Sohayda CJ, Kupelian PA, Altsman KA, et al. Race as an independent predictor of outcome after treatment for localized prostate cancer. J Urol. Oct. 1999;162(4):1331-1336. Not eligible exposure. [pmid: 10492191].
633 Solberg A, Angelsen A, Bergan U, et al. Frequency of lymphoceles after open and laparoscopic pelvic lymph node dissection in patients with prostate cancer. Scand J Urol Nephrol. 2003;37(3):218-221. Not eligible exposure. [pmid: 12775280].
634 Sole-Balcells F, Villavicencio H, Ortiz A. Postsurgical management of the patient undergoing radical prostatectomy. Br J Urol. Nov. 1992;70(Suppl 1):43-49. Not eligible exposure. [pmid: 1467877].
635 Soloway MS, Watson R. The role of induction androgen deprivation prior to radical prostatectomy. Eur Urol. 1996;29(Suppl 2):114-118. Review. [pmid: 8717473].
636 Speight JL, Shinohara K, Pickett B, et al. Prostate volume change after radioactive seed implantation: possible benefit of improved dose volume histogram with perioperative steroid. Int J Radiat Oncol Biol Phys. Dec 1. 2000;48(5):1461-1467. No provider characteristics. [pmid: 11121649].
637 Spieth ME, Lin YG, Nguyen TT. Diagnosing and treating small-cell carcinomas of prostatic origin. Clin Nucl Med. Jan. 2002;27(1):11-17. Not eligible target population. [pmid: 11805477].
638 Srougi M, Paranhos M, Leite KM, et al. The influence of bladder neck mucosal eversion and early urinary extravasation on patient outcome after radical retropubic prostatectomy: a prospective controlled trial. BJU Int. Apr. 2005;95(6):757-760. Not eligible exposure. [pmid: 15794777].
639 Stamey TA. Lower limits of detection, biological detection limits, functional sensitivity, or residual cancer detection limit? Sensitivity reports on prostate-specific antigen assays mislead clinicians. Clin Chem. Jun. 1996;42(6 Pt 1):849-852. Not eligible exposure. [pmid: 8665674].
640 Stamey TA, Caldwell M, McNeal JE, et al. The prostate specific antigen era in the United States is over for prostate cancer: what happened in the last 20 years?. J Urol. Oct. 2004;172(4 Pt 1):1297-1301. Not eligible exposure. [pmid: 15371827].
641 Stamey TA, McNeal JE, Yemoto CM, et al. Biological determinants of cancer progression in men with prostate cancer. Jama. Apr 21. 1999;281(15):1395-1400. Not eligible exposure. [pmid: 10217055].
642 Stamey TA, Yemoto CM, McNeal JE, et al. Prostate cancer is highly predictable: a prognostic equation based on all morphological variables in radical prostatectomy specimens. J Urol. Apr. 2000;163(4):1155-1160. Not eligible exposure. [pmid: 10737486].
643 Stanford JL, Feng Z, Hamilton AS, et al. Urinary and sexual function after radical prostatectomy for clinically localized prostate cancer: the Prostate Cancer Outcomes Study. Jama. Jan 19. 2000;283(3):354-360. Not eligible exposure. [pmid: 10647798].
644 Stattin P, Bergh A, Karlberg L, et al. Long-term outcome of conservative therapy in men presenting with voiding symptoms and prostate cancer. Eur Urol. 1997;32(4):404-409. Not eligible exposure. [pmid: 9412796].
645 Stav K, Rahimi-Levene N, Lindner A, et al. Retropubic radical prostatectomy: associated blood loss and transfusion requirements—a two-decade perspective review. Isr Med Assoc J. Feb. 2005;7(2):103-106. Review. [pmid: 15729961].
646 Stavridis S, Georgiev V, Popov Z, et al. Radical retropubic prostatectomy for prostate carcinoma; first results of the Clinic of Urology in Skopje. Acta Chir Iugosl. 2005;52(4):37-40. No provider characteristics. [pmid: 16673592].
647 Steinberg AP, Gill IS. Laparoscopic prostatectomy: a promising option in the treatment of prostate cancer. Cleve Clin J Med. Feb 2004;71(2):113–114, 117–121. Review
648 Steiner MS. Current results and patient selection for nerve-sparing radical retropubic prostatectomy. Semin Urol Oncol. Aug. 1995;13(3):204-214. Review. [pmid: 8521134].
649 Steiner MS. Neoadjuvant androgen ablation before radical prostatectomy reduces positive margin rate, but has no effect on 36-month post-treatment biochemical failure. Curr Urol Rep. Jun. 2001;2(3):193-194. Not eligible exposure. [pmid: 12084263].
650 Stephenson AJ, Slawin KM, Bianco FJ Jr, et al. Perspectives on the natural history of recurrent prostate cancer after radical prostatectomy, based on the response to salvage radiotherapy. BJU Int. Dec. 2004;94(9):1210-1212. Not eligible exposure. [pmid: 15610088].
651 Stolzenburg JU, Do M, Pfeiffer H, et al. The endoscopic extraperitoneal radical prostatectomy (EERPE): technique and initial experience. World J Urol. May. 2002;20(1):48-55. Not eligible exposure. [pmid: 12088191].
652 Stolzenburg JU, Rabenalt R, Dietel A, et al. Hernia repair during endoscopic (laparoscopic) radical prostatectomy. J Laparoendosc Adv Surg Tech A. Feb. 2003;13(1):27-31. Not eligible exposure. [pmid: 12676018].
653 Stolzenburg JU, Truss MC, Bekos A, et al. Does the extraperitoneal laparoscopic approach improve the outcome of radical prostatectomy?. Curr Urol Rep. Apr. 2004;5(2):115-122. Not eligible exposure. [pmid: 15028203].
654 Strom SS, Gu Y, Zhang H, et al. Androgen receptor polymorphisms and risk of biochemical failure among prostatectomy patients. Prostate. Sep 1. 2004;60(4):343-351. Not eligible exposure. [pmid: 15264247].
655 Studer UE. Radical prostatectomy or deferred treatment?. Semin Surg Oncol. Jan–Feb. 1995;11(1):46-49. Not eligible exposure. [pmid: 7538694].
656 Su LM, Link RE, Bhayani SB, et al. Nerve-sparing laparoscopic radical prostatectomy: replicating the open surgical technique. Urology. Jul. 2004;64(1):123-127. Not eligible exposure. [pmid: 15245948].
657 Sullivan LD, Weir MJ, Kinahan JF, et al. A comparison of the relative merits of radical perineal and radical retropubic prostatectomy. BJU Int. Jan. 2000;85(1):95-100. Not eligible exposure. [pmid: 10619954].
658 Summers JL. Reexamining interstitial radiotherapy for PCa. Contemp Urol. Apr 1994;6(4):17–24, 27. Review.
659 Sun GH, Fu YT, Wu CJ, et al. Povidone-iodine instillation for management of pelvic lymphocele after pelvic lymphadenectomy for staging prostate cancer. Arch Androl. Nov–Dec. 2003;49(6):463-466. Case report. [pmid: 14555330].
660 Svetec D, McCabe K, Peretsman S, et al. Prostate rebiopsy is a poor surrogate of treatment efficacy in localized prostate cancer. J Urol. May. 1998;159(5):1606-1608. Not eligible exposure. [pmid: 9554363].
661 Swanson GP, Riggs MW, Earle JD, et al. Long-term follow-up of radical retropubic prostatectomy for prostate cancer. Eur Urol. Sep. 2002;42(3):212-216. Not eligible exposure. [pmid: 12234504].
662 Swindle PW, Kattan MW, Scardino PT. Markers and meaning of primary treatment failure. Urol Clin North Am. May. 2003;30(2):377-401. Review. [pmid: 12735513].
663 Talcott JA, Rieker P, Propert KJ, et al. Patient-reported impotence and incontinence after nerve-sparing radical prostatectomy. J Natl Cancer Inst. Aug 6. 1997;89(15):1117-1123. Not eligible exposure. [pmid: 9262249].
664 Tammela T. Endocrine treatment of prostate cancer. J Steroid Biochem Mol Biol. Nov. 2004;92(4):287-295. Review. [pmid: 15663992].
665 Tarcan T, Ozveri H, Biren T, et al. Evaluation of prostate specific antigen density and transrectal ultrasonography-guided biopsies in 100 consecutive patients with a negative digital rectal examination and intermediate serum prostate specific antigen levels. Int J Urol. Jul. 1997;4(4):362-367. Review. [pmid: 9256325].
666 Teloken C. Management of erectile dysfunction secondary to treatment for localized prostate cancer. Cancer Control. Nov–Dec. 2001;8(6):540-545. Review. [pmid: 11807424].
667 Tempany CM. MR staging of prostate cancer. How we can improve our accuracy with decisions aids and optimal techniques. Magn Reson Imaging Clin N Am. Aug. 1996;4(3):519-532. Review. [pmid: 8873017].
668 Tewari A, El-Hakim A, Horninger W, et al. Nerve-sparing during robotic radical prostatectomy: use of computer modeling and anatomic data to establish critical steps and maneuvers. Curr Urol Rep. Mar. 2005;6(2):126-128. Review. [pmid: 15717970].
669 Tewari A, El-Hakim A, Leung RA. Robotic prostatectomy: a pooled analysis of published literature. Expert Rev Anticancer Ther. Jan. 2006;6(1):11-20. Review. [pmid: 16375639].
670 Tewari A, Kaul S, Menon M. Robotic radical prostatectomy: a minimally invasive therapy for prostate cancer. Curr Urol Rep. Feb. 2005;6(1):45-48. Not eligible exposure. [pmid: 15610696].
671 Tewari A, Menon M. Vattikuti Institute prostatectomy: surgical technique and current results. Curr Urol Rep. Apr. 2003;4(2):119-123. Not eligible exposure. [pmid: 12648428].
672 Tewari A, Peabody J, Sarle R, et al. Technique of da Vinci robot-assisted anatomic radical prostatectomy. Urology. Oct. 2002;60(4):569-572. Not eligible exposure. [pmid: 12385908].
673 Tewari A, Srivasatava A, Menon M. A prospective comparison of radical retropubic and robot-assisted prostatectomy: experience in one institution. BJU Int. Aug. 2003;92(3):205-210. Not eligible exposure. [pmid: 12887468].
674 Thompson IM, Canby-Hagino E, Lucia MS. Stage migration and grade inflation in prostate cancer: Will Rogers meets Garrison Keillor. J Natl Cancer Inst. Sep 7. 2005;97(17):1236-1237. Comment. [pmid: 16145036].
675 Thompson IM, Coltman CA. Screening for prostate cancer: opportunities for prevention. Semin Urol Oncol. May. 1996;14(2 Suppl 2):4-10. discussion 10–11. Review. [pmid: 8725886].
676 Thorpe AC, Cleary R, Coles J, et al. Nottingham health profile measurement in the assessment of clinical outcome after prostatectomy. Northern Regional Prostate Audit Group. Br J Urol. Oct. 1995;76(4):446-450. Not eligible exposure. [pmid: 7551879].
677 Tiguert R, Hurley PM, Gheiler EL, et al. Treatment outcome after radical prostatectomy is not adversely affected by a pre-existing penile prosthesis. Urology. Dec. 1998;52(6):1030-1033. Not eligible exposure. [pmid: 9836550].
678 Tiguert R, Rigaud J, Lacombe L, et al. Neoadjuvant hormone therapy before salvage radiotherapy for an increasing post-radical prostatectomy serum prostate specific antigen level. J Urol. Aug. 2003;170(2 Pt 1):447-450. Not eligible exposure. [pmid: 12853796].
679 Tobias-Machado M, Lasmar MT, Medina JJ, et al. Preliminary experience with extraperitoneal endoscopic radical prostatectomy through duplication of the open technique. Int Braz J Urol. May–Jun. 2005;31(3):228-235. No provider characteristics. [pmid: 15992425].
680 Tol-Fakkar M, Hermansson CG, Hugosson J, et al. Radical prostatectomy—long-term oncological outcome from a community hospital. Scand J Urol Nephrol. 2003;37(5):376-381. Not eligible exposure. [pmid: 14594684].
681 Tombal B, Van Cangh PJ, Loric S, et al. Prognostic value of circulating prostate cells in patients with a rising PSA after radical prostatectomy. Prostate. Aug 1. 2003;56(3):163-170. Not eligible exposure. [pmid: 12772185].
682 Touijer AK, Guillonneau B. Laparoscopic radical prostatectomy. Urol Oncol. Mar–Apr. 2004;22(2):133-138. Review. [pmid: 15082012].
683 Touma NJ, Izawa JI, Chin JL. Current status of local salvage therapies following radiation failure for prostate cancer. J Urol. Feb. 2005;173(2):373-379. Not eligible exposure. [pmid: 15643174].
684 Trabulsi EJ, Guillonneau B. Laparoscopic radical prostatectomy. J Urol. Apr. 2005;173(4):1072-1079. Review. [pmid: 15758704].
685 Trabulsi EJ, Hassen WA, Touijer AK, et al. Laparoscopic radical prostatectomy: a review of techniques and results worldwide. Minerva Urol Nefrol. Dec. 2003;55(4):239-250. Review. [pmid: 14765016].
686 Trachtenberg J. Appraisal of current therapies for prostate cancer. Eur Urol. 1996;29(Suppl 2):110-113. Review. [pmid: 8717472].
687 Tse E, Knaus R. Laparoscopic radical prostatectomy - results of 200 consecutive cases in a Canadian medical institution. Can J Urol. Apr. 2004;11(2):2172-2185. No provider characteristics. [pmid: 15182406].
688 Tsien C, Griffith KA, Sandler HM, et al. Long-term results of three-dimensional conformal adjuvant and salvage radiotherapy after radical prostatectomy. Urology. Jul. 2003;62(1):93-98. Not eligible exposure. [pmid: 12837430].
689 Tsien C, Sandler H. Salvage radiotherapy in the treatment of prostate cancer. Urology. Dec 29. 2003;62(Suppl 1):63-68. Review. [pmid: 14747043].
690 Tsihlias J, Kapusta LR, DeBoer G, et al. Loss of cyclin-dependent kinase inhibitor p27Kip1 is a novel prognostic factor in localized human prostate adenocarcinoma. Cancer Res. Feb 1. 1998;58(3):542-548. Not eligible exposure. [pmid: 9458103].
691 Tsui KH, Sun GH, Huang ST, et al. Minilaparotomy radical retropubic prostatectomy for prostate cancer. Arch Androl. Jan–Feb. 2004;50(1):23-25. Not eligible exposure. [pmid: 14660167].
692 Tucker RD. Use of interstitial temperature self-regulating thermal rods in the treatment of prostate cancer. J Endourol. Oct. 2003;17(8):601-607. Review. [pmid: 14622479].
693 Tunc M, Sanli O, Kandirali E, et al. Should high-grade prostatic intraepithelial neoplasia change our approach to infravesical obstruction?. Urol Int. 2005;74(4):332-336. Not eligible exposure. [pmid: 15897699].
694 Turk I, Deger S, Winkelmann B, et al. Laparoscopic radical prostatectomy. Technical aspects and experience with 125 cases. Eur Urol. Jul. 2001;40(1):46-52. discussion 53. No provider characteristics. [pmid: 11528176].
695 Underwood W 3rd, Wei J, Rubin MA, et al. Postprostatectomy cancer-free survival of African Americans is similar to non-African Americans after adjustment for baseline cancer severity. Urol Oncol. Jan–Feb. 2004;22(1):20-24. Not eligible exposure. [pmid: 14969799].
696 Ung JO, Richie JP, Chen MH, et al. Evolution of the presentation and pathologic and biochemical outcomes after radical prostatectomy for patients with clinically localized prostate cancer diagnosed during the PSA era. Urology. Sep. 2002;60(3):458-463. Not eligible exposure. [pmid: 12350484].
697 Valeri A, Fromont G, Sakr W, et al. High frequency of allelic losses in high-grade prostate cancer is associated with biochemical progression after radical prostatectomy. Urol Oncol. Mar–Apr. 2005;23(2):87-92. Not eligible exposure. [pmid: 15869992].
698 Valicenti RK, Chervoneva I, Gomella LG. Importance of margin extent as a predictor of outcome after adjuvant radiotherapy for Gleason score 7 pT3N0 prostate cancer. Int J Radiat Oncol Biol Phys. Mar 15. 2004;58(4):1093-1097. Not eligible exposure. [pmid: 15001249].
699 Valicenti RK, Gomella LG, El-Gabry EA, et al. The multidisciplinary clinic approach to prostate cancer counseling and treatment. Semin Urol Oncol. Aug. 2000;18(3):188-191. Not eligible exposure. [pmid: 10975490].
700 Valicenti RK, Gomella LG, Ismail M, et al. The efficacy of early adjuvant radiation therapy for pT3N0 prostate cancer: a matched-pair analysis. Int J Radiat Oncol Biol Phys. Aug 1. 1999;45(1):53-58. Not eligible exposure. [pmid: 10477006].
701 van den Brule FA, Waltregny D, Castronovo V. Increased expression of galectin-1 in carcinoma-associated stroma predicts poor outcome in prostate carcinoma patients. J Pathol. Jan. 2001;193(1):80-87. Not eligible exposure. [pmid: 11169519].
702 van den Ouden D, Hop WC, Kranse R, et al. Tumour control according to pathological variables in patients treated by radical prostatectomy for clinically localized carcinoma of the prostate. Br J Urol. Feb. 1997;79(2):203-211. Not eligible exposure. [pmid: 9052471].
703 van den Ouden D, Schroder FH. Management of locally advanced prostate cancer. 1. Staging, natural history, and results of radical surgery. World J Urol. Jun. 2000;18(3):194-203. Review. [pmid: 10926084].
704 van der Kwast TH, Labrie F, Tetu B. Prostatic intraepithelial neoplasia and endocrine manipulation. Eur Urol. 1999;35(56):508-510. Not eligible exposure. [pmid: 10325515].
705 Van Poppel H, Boulanger SF, Joniau S. Quality assurance issues in radical prostatectomy. Eur J Surg Oncol. Aug. 2005;31(6):650-655. Review. [pmid: 16023946].
706 Van Poppel H, Vanuytsel L, Petrovich Z, et al. Is postoperative irradiation after radical prostatectomy necessary?. Eur J Cancer. Dec. 1999;35(13):1763-1770. Review. [pmid: 10673989].
707 van Vulpen M, Raaymakers BW, Lagendijk JJ, et al. Three-dimensional controlled interstitial hyperthermia combined with radiotherapy for locally advanced prostate carcinoma—a feasibility study. Int J Radiat Oncol Biol Phys. May 1. 2002;53(1):116-126. No provider characteristics. [pmid: 12007949].
708 Vanasupa BP, Miller TA, Schwartz BF. Diagnosis of prostate adenocarcinoma using transurethral resection of the prostate after multiple negative transrectal biopsies and persistently elevated prostate-specific antigen level. Urology. Dec 20. 2000;56(6):1056. Not eligible exposure. [pmid: 11113765].
709 Vanasupa BP, Paquette EL, Wu H, et al. The role of radical prostatectomy in patients with pretreatment prostate-specific antigen > or = 40 ng/mL. Urol Oncol. Jul–Aug. 2002;7(4):167-172. Not eligible exposure. [pmid: 12474533].
710 Vargas C, Kestin LL, Weed DW, et al. Improved biochemical outcome with adjuvant radiotherapy after radical prostatectomy for prostate cancer with poor pathologic features. Int J Radiat Oncol Biol Phys. Mar 1. 2005;61(3):714-724. Not eligible exposure. [pmid: 15708249].
711 Varkarakis J, Pinggera GM, Sebe P, et al. Radical retropubic prostatectomy in men younger than 45 years diagnosed during early prostate cancer detection program. Urology. Feb. 2004;63(2):337-341. Not eligible exposure. [pmid: 14972485].
712 Vassilikos EJ, Yu H, Trachtenberg J, et al. Relapse and cure rates of prostate cancer patients after radical prostatectomy and 5 years of follow-up. Clin Biochem. Mar. 2000;33(2):115-123. Not eligible exposure. [pmid: 10751589].
713 Vellet AD, Saliken J, Donnelly B, et al. Prostatic cryosurgery: use of MR imaging in evaluation of success and technical modifications. Radiology. Jun. 1997;203(3):653-659. Not eligible exposure. [pmid: 9169684].
714 Vesalainen S, Lipponen P, Nordling S, et al. Results of the primary treatment in T1–3M0 prostatic adenocarcinoma are dependent on tumour biology. Anticancer Res. Mar–Apr. 1995;15(2):569-573. Not eligible exposure. [pmid: 7763039].
715 Vicini FA, Ziaja EL, Kestin LL, et al. Treatment outcome with adjuvant and salvage irradiation after radical prostatectomy for prostate cancer. Urology. Jul. 1999;54(1):111-117. Not eligible exposure. [pmid: 10414736].
716 Villa S, Bedini N, Fallai C, et al. External beam radiotherapy in elderly patients with clinically localized prostate adenocarcinoma: age is not a problem. Crit Rev Oncol Hematol. Nov. 2003;48(2):215-225. Not eligible exposure. [pmid: 14607384].
717 Vis AN, Noordzij MA, Fitoz K, et al. Prognostic value of cell cycle proteins p27(kip1) and MIB-1, and the cell adhesion protein CD44s in surgically treated patients with prostate cancer. J Urol. Dec. 2000;164(6):2156-2161. Not eligible exposure. [pmid: 11061947].
718 Vodopija N, Zupancic M, Korsic L, et al. Laparoscopic radical prostatectomy—analysis of our first 100 consecutive cases. Coll Antropol. Jun. 2004;28(1):429-437. No provider characteristics. [pmid: 15636102].
719 Voges GE, Mottrie AM, Stockle M, et al. Hormone therapy prior to radical prostatectomy in patients with clinical stage C prostate cancer. Prostate Suppl. 1994;5:4-8. Not eligible exposure. [pmid: 7513531].
720 Volavsek M, Masera A, Ovcak Z. Incidental prostatic carcinoma. A predictive role of neoangiogenesis and comparison with other prognostic factors. Pathol Oncol Res. 2000;6(3):191-196. Not eligible exposure. [pmid: 11033459].
721 Vollmer RT, Humphrey PA. The relative importance of anatomic and PSA factors to outcomes after radical prostatectomy for prostate cancer. Am J Clin Pathol. Dec. 2001;116(6):864-870. Not eligible exposure. [pmid: 11764075].
722 Vollmer RT, Keetch DW, Humphrey PA. Predicting the pathology results of radical prostatectomy from preoperative information: a validation study. Cancer. Oct 15. 1998;83(8):1567-1580. Not eligible exposure. [pmid: 9781951].
723 Walsh IK, Williams SG, Mahendra V, et al. Artificial urinary sphincter implantation in the irradiated patient: safety, efficacy and satisfaction. BJU Int. Mar. 2002;89(4):364-368. Not eligible exposure. [pmid: 11872025].
724 Walsh PC. Radical prostatectomy for localized prostate cancer provides durable cancer control with excellent quality of life: a structured debate. J Urol. Jun. 2000;163(6):1802-1807. Review. [pmid: 10799186].
725 Ward JF, Blute ML, Slezak J, et al. The long-term clinical impact of biochemical recurrence of prostate cancer 5 or more years after radical prostatectomy. J Urol. Nov. 2003;170(5):1872-1876. Not eligible exposure. [pmid: 14532796].
726 Ward JF, Moul JW. Biochemical recurrence after definitive prostate cancer therapy. Part I: defining and localizing biochemical recurrence of prostate cancer. Curr Opin Urol. May. 2005;15(3):181-186. Review. [pmid: 15815195].
727 Ward JF, Sebo TJ, Blute ML, et al. Salvage surgery for radiorecurrent prostate cancer: contemporary outcomes. J Urol. Apr. 2005;173(4):1156-1160. Not eligible exposure. [pmid: 15758726].
728 Ward JF, Slezak JM, Blute ML, et al. Radical prostatectomy for clinically advanced (cT3) prostate cancer since the advent of prostate-specific antigen testing: 15-year outcome. BJU Int. Apr. 2005;95(6):751-756. Not eligible exposure. [pmid: 15794776].
729 Warde P, Gospodarowicz MK. Progress in prostate cancer. Cmaj. Dec 15. 1997;157(12):1685-1686. Review. [pmid: 9418660].
730 Wasson J, Fleming C, Bruskewitz R, et al. The treatment of localized prostate cancer: what are we doing, what do we know, and what should we be doing? The Prostate Patient Outcome Research Team. Semin Urol. Feb. 1993;11(1):23-26. Not eligible exposure. [pmid: 8465125].
731 Watson R, Soloway MS. Is there a role for induction androgen deprivation prior to radical prostatectomy?. Hematol Oncol Clin North Am. Jun. 1996;10(3):627-641. Review. [pmid: 8773501].
732 Watson RB, Soloway MS. Neoadjuvant hormonal treatment before radical prostatectomy. Semin Urol Oncol. May. 1996;14(2 Suppl 2):48-55. discussion 55–46. Review. [pmid: 8725891].
733 Weber BA, Roberts BL, Resnick M, et al. The effect of dyadic intervention on self-efficacy, social support, and depression for men with prostate cancer. Psychooncology. Jan. 2004;13(1):47-60. Not eligible exposure. [pmid: 14745745].
734 Weldon VE. Technique of modern radical perineal prostatectomy. Urology. Oct. 2002;60(4):689-694. Review. [pmid: 12385936].
735 Wennberg J. Some considerations in outcomes research. J Vasc Interv Radiol. Nov–Dec. 1995;6(6 Pt 2 Su):102S-103S. Not eligible exposure. [pmid: 8770851].
736 Whelan P. The case against radical prostatectomy. Ann R Coll Surg Engl. May. 2005;87(3):161-162. Comment. [pmid: 15920789].
737 Wiegel T, Bressel M. Stage D1 prostate cancer—is radiotherapy and early hormonal therapy equivalent to radical prostatectomy, radiotherapy, and early hormonal therapy? regarding Sands et al., IJROBP 31:13–19; 1995. Int J Radiat Oncol Biol Phys. Jun 15. 1995;32(3):896-897. Comment. [pmid: 7790281].
738 Wiegel T, Hinkelbein W. Radiotherapy after radical prostatectomy in patients with prostate-specific antigen elevation. Front Radiat Ther Oncol. 2002;36:35-42. Review. [pmid: 11842753].
739 Wiegel T, Hinkelbein W. Adjuvant and salvage radiation therapy after radical prostatectomy for adenocarcinoma of the prostate. Radiother Oncol. Jan. 2002;62(1):115. Not eligible exposure. [pmid: 11830322].
740 Wiig JN, Waehre H, Larsen SG, et al. Radical prostatectomy for locally advanced primary or recurrent rectal cancer. Eur J Surg Oncol. Jun. 2003;29(5):455-458. Not eligible exposure. [pmid: 12798751].
741 Wilder RB, Hsiang JY, Ji M, et al. Preliminary results of three-dimensional conformal radiotherapy as salvage treatment for a rising prostate-specific antigen level postprostatectomy. Am J Clin Oncol. Apr. 2000;23(2):176-180. Not eligible exposure. [pmid: 10776980].
742 Grant William B. Geographic variation of prostate cancer mortality rates in the United States: Implications for prostate cancer risk related to vitamin D. International Journal of Cancer. 2004;111(3):470-471. Comment. [pmid: 15221981].
743 Williams RD. Prostate cancer outcomes studies—the pathway to improvement. J Urol. Jan. 1998;159(1):172. Comment. [pmid: 9400464].
744 Willie Underwood JJ III, Wei John T, Dunn Rodney, et al. Racial treatment trends in localized/regional prostate carcinoma: 1992-1999. Cancer. 2005;103(3):538-545. Not eligible exposure. [pmid: 15612083].
745 Wilson LC, Kennett KM, Gilling PJ. Laparoscopic radical prostatectomy: early safety and efficacy. ANZ J Surg. Dec. 2004;74(12):1065-1068. Not eligible exposure. [pmid: 15574150].
746 Wilt T. Prostate cancer: non-metastatic Clin Evid. Jun 2002(7):812–823. Review.
747 Wilt TJ. Prostate cancer screening: practice what the evidence preaches. Am J Med. Jun. 1998;104(6):602-604. Comment. [pmid: 9674725].
748 Wilt TJ. Prostate carcinoma practice patterns: what do they tell us about the diagnosis, treatment, and outcomes of patients with prostate carcinoma?. Cancer. Mar 15. 2000;88(6):1277-1281. Editorial. [pmid: 10717606].
749 Wilt TJ, Brawer MK. The Prostate Cancer Intervention Versus Observation Trial: a randomized trial comparing radical prostatectomy versus expectant management for the treatment of clinically localized prostate cancer. J Urol. Nov. 1994;152(5 Pt 2):1910-1914. Not eligible exposure. [pmid: 7523736].
750 Wilt TJ, Brawer MK. The Prostate Cancer Intervention Versus Observation Trial (PIVOT). Oncology (Williston Park). Aug. 1997;11(8):1133-1139. discussion 1139–1140, 1143. Review. [pmid: 9268976].
751 Winkler MH, Gillatt DA. Learning curve and stage migration of a radical retropubic prostatectomy series over a 10-y period. Prostate Cancer Prostatic Dis. 2004;7(3):258-262. No provider characteristics. [pmid: 15224089].
752 Wirth M, Tyrrell C, Delaere K, et al. Bicalutamide (‘Casodex’) 150 mg in addition to standard care in patients with nonmetastatic prostate cancer: updated results from a randomised double-blind phase III study (median follow-up 5.1 y) in the early prostate cancer programme. Prostate Cancer Prostatic Dis. 2005;8(2):194-200. Not eligible exposure. [pmid: 15931272].
753 Wirth MP, Froehner M. Perspectives in adjuvant treatment of prostate cancer. Urol Int. 2002;68(1):1-5. Review. [pmid: 11803260].
754 Wirth MP, Froehner M. Adjuvant hormonal treatment for prostate cancer: the bicalutamide early prostate cancer program. Oncology. 2003;65(Suppl 1):1-4. Review. [pmid: 12949426].
755 Wirth MP, Weissbach L, Marx FJ, et al. Prospective randomized trial comparing flutamide as adjuvant treatment versus observation after radical prostatectomy for locally advanced, lymph node-negative prostate cancer. Eur Urol. Mar. 2004;45(3):267-270. discussion 270. Not eligible exposure. [pmid: 15036669].
756 Wong WS, Chinn DO, Chinn M, et al. Cryosurgery as a treatment for prostate carcinoma: results and complications. Cancer. Mar 1. 1997;79(5):963-974. No provider characteristics. [pmid: 9041159].
757 Woo TC, Choo R, Jamieson M, et al. Pilot study: potential role of vitamin D (Cholecalciferol) in patients with PSA relapse after definitive therapy. Nutr Cancer. 2005;51(1):32-36. Not eligible exposure. [pmid: 15749627].
758 Yang G, Timme TL, Frolov A, et al. Combined c-Myc and caveolin-1 expression in human prostate carcinoma predicts prostate carcinoma progression. Cancer. Mar 15. 2005;103(6):1186-1194. Not eligible exposure. [pmid: 15712208].
759 Yoon JH, Chen MH, Renshaw AA, et al. Predictive factor analysis as the basis for the clinical utility of percent positive prostate biopsies in patients with intermediate-risk prostate cancer. Urology. Sep. 2002;60(3):454-457. Not eligible exposure. [pmid: 12350483].
760 Yoshimura K, Arai Y, Ichioka K, et al. A 3-y prospective study of health-related and disease-specific quality of life in patients with nonmetastatic prostate cancer treated with radical prostatectomy or external beam radiotherapy. Prostate Cancer Prostatic Dis. 2004;7(2):144-151. Not eligible exposure. [pmid: 15111981].
761 Yoshimura K, Ichioka K, Terada N, et al. Use of complementary and alternative medicine by patients with localized prostate carcinoma: study at a single institute in Japan. Int J Clin Oncol. Feb. 2003;8(1):26-30. Not eligible exposure. [pmid: 12601539].
762 Yoshimura K, Sumiyoshi Y, Hashimura T, et al. Neoadjuvant flutamide monotherapy for locally confined prostate cancer. Int J Urol. Apr. 2003;10(4):190-195. Not eligible exposure. [pmid: 12657097].
763 Youssef E, Forman JD, Tekyi-Mensah S, et al. Therapeutic postprostatectomy irradiation. Clin Prostate Cancer. Jun. 2002;1(1):31-36. Not eligible exposure. [pmid: 15046710].
764 Yu KK, Hricak H, Grossfeld GD, et al. Prediction of patient outcome after radical prostatectomy by imaging: choice of outcome measure. Acad Radiol. Sep. 1998;5(Suppl 2):S347-348. Not eligible exposure. [pmid: 9750850].
765 Yu Y, Schell MC, Rubin P. Circumventing the learning curve of dose and volume in intravascular brachytherapy. Cardiovasc Radiat Med. Apr–Jun. 1999;1(2):170-171. Editorial. [pmid: 11229551].
766 Zagars GK, von Eschenbach AC, Ayala AG. Prognostic factors in prostate cancer. Analysis of 874 patients treated with radiation therapy. Cancer. Sep 1. 1993;72(5):1709-1725. Not eligible exposure. [pmid: 7688659].
767 Zelefsky MJ, Whitmore WF Jr, Leibel SA, et al. Impact of transurethral resection on the long-term outcome of patients with prostatic carcinoma. J Urol. Dec. 1993;150(6):1860-1864. Not eligible exposure. [pmid: 8230519].
768 Zhang Y, Glass A, Bennett N, et al. Long-term outcomes after radical prostatectomy performed in a community-based health maintenance organization. Cancer. Jan 15. 2004;100(2):300-307. Not eligible exposure. [pmid: 14716764].
769 Zhang Y, Zippe CD, Van Lente F, et al. Combined nested reverse transcription-PCR assay for prostate-specific antigen and prostate-specific membrane antigen in detecting circulating prostatic cells. Clin Cancer Res. Jul. 1997;3(7):1215-1220. Not eligible exposure. [pmid: 9815802].
770 Ziada AM, Lisle TC, Snow PB, et al. Impact of different variables on the outcome of patients with clinically confined prostate carcinoma: prediction of pathologic stage and biochemical failure using an artificial neural network. Cancer. Apr 15. 2001;91(8 Suppl):1653-1660. Review. [pmid: 11309764].
771 Zietman AL, Edelstein RA, Coen JJ, et al. Radical prostatectomy for adenocarcinoma of the prostate: the influence of preoperative and pathologic findings on biochemical disease-free outcome. Urology. Jun. 1994;43(6):828-833. Not eligible exposure. [pmid: 7515206].
772 Zietman AL, Shipley WU, Coen JJ. Radical prostatectomy and radical radiation therapy for clinical stages T1 to 2 adenocarcinoma of the prostate: new insights into outcome from repeat biopsy and prostate specific antigen followup. J Urol. Nov. 1994;152(5 Pt 2):1806-1812. Review. [pmid: 7523726].
773 Zincke H. Radical prostatectomy and exenterative procedures for local failure after radiotherapy with curative intent: comparison of outcomes. J Urol. Mar. 1992;147(3 Pt 2):894-899. Not eligible exposure. [pmid: 1538491].
774 Zincke H, Oesterling JE, Blute ML, et al. Long-term (15 years) results after radical prostatectomy for clinically localized (stage T2c or lower) prostate cancer. J Urol. Nov. 1994;152(5 Pt 2):1850-1857. Not eligible exposure. [pmid: 7523733].
775 Zippe CD. Cryosurgery of the prostate: techniques and pitfalls. Urol Clin North Am. Feb. 1996;23(1):147-163. Review. [pmid: 8677533].